# Acknowledgments

The authors of this report thank the peer reviewers for the evidence report (alphabetical)—James Allison, MD, Carrie Klabunde, PhD, Ted Levin, MD, Perry Pickhardt, MD, Margaret Piper, PhD, MPH, David Ransohoff, MD, Laura Seef, MD, Robert Smith, PhD, and Steve Woolf, MD, MPH; and the staff at the Oregon Evidence-based Practice Center staff— Mark Helfand, MD, MS, MPH, Kevin Lutz, MA, and Daphne Plaut, MLS.