# Appendix D: Studies in progress

Study Chair/Principal Investigators | Title | Setting | Population | Intervention/Control | Outcomes | Status
Patterson, TL | STD Risk Reduction for Heterosexual Methamphetamine Users | Specific setting NR; study conducted in San Diego, CA | Both genders, ages 18 and older, current user of methamphetamine | (1) No maintenance counseling intervention program or (2) maintenance counseling program or (3) diet and exercise attention-control group | Sexual risk behaviors, HIV serostatus, STD infections | Completed
Stark, MJ | Reducing HIV and Domestic Violence Risk in Women Offenders | Specific setting NR; study conducted in Portland, OR | Females, ages 18 and older, who had been in jail or prison in the past year or currently on parole or probation; history of HIV-related behaviors in past year | (1) information on local HIV prevention resources or (2) up to 10 supportive counseling sessions based on motivational interviewing aimed to reduce HIV risk or (3) up to 10 supportive counseling sessions based on MI aimed to reduce HIV and domestic violence | Biological testing for HIV and STIs, HIV risk behavior, experineces of domestic violence | Completed
Williams, SP; Sperling, C. | An STD Prevention Intervention for Men Newly Released From Jail | Specific setting NR; study conducted in Decatur, GA | Men, ages 18–60, 45 days or less post release from Jail, self-reported HIV negative with substance use histories | 5-session intervention vs. control | STD infections, Sexual risk behaviors, condom use, substance use behavior | Completed
Kyung-Hee, C | Education Program to Promote Female Condom Use | Specific setting NR; study conducted in San Francisco, CA | African American, Asian American, Latina or White females, ages 18–39 | 4 session female condom skills training vs. 4 session women's general health promotion | Female condom use (primary), male or female condom use (secondary) | Currently recruiting
Morrison-Beedy, DC | Maintaining HIV Prevention Gains in Female Adolescents | Urban family planning clinics | Sexually active females, ages 15–19 | HIV-risk reduction intervention based on the Information-Motivation-Behavioral Skills model or equivalent health promotion control, both with booster sessions at 3 and 6 months | Biological test for STIs (chlamydia and gonorrhea), Sexual behaviors | Currently recruiting
O'Donnell, L | Testing the Effectiveness of VOICES as Implemented by STD and HIV Prevention Agencies in the US and PR | Urban STD clinics (New York and San Juan, Puerto Rico) | Both genders, STD+ at basline, ages 18 and older | Brief culturally-specific single-session intervention in small groups | STD incidence as determined by medical chart review and/or surveillance data | Currently recruiting
Rose, ES; Sales, J | HIV Prevention for African American Teens | Urban family planning clinic | Sexually active African American females, ages 14–20 | Sexual health education program, with periodic telephone contacts designed to either reinforce sexual health promotion (intervention ) or reinforce dietary practices (control) | HIV prevention behaviors. Unclear if study includes biological assesment of STIs at follow up (these are noted to be done at baseline) | Currently recruiting
Bull, SS | A Tailored Interactive Website for Promoting Condom Use Among Young Adults | Patients recruited from urban health clinic or Planned Parenthood | Both genders, ages 18–25 | Tailored interactive online risk reduction program vs. standard online risk reduction program (on reproductive health - not specific to condoms or STDs) | Condom use | No longer recruiting
Gold, MA | The S.A.F.E. Study: Computer-Aided Counseling to Prevent Teen Pregnancy/STDs | Inner-city, hospital-based clinic | Females, ages 13–21 | Computer-Assisted Motivational Intervention vs. Didactic Educational control | Protective sexual behaviors (for both pregnancy and STIs); abstinence | No longer recruiting
Klausner, JD; Rietmeijer, CA; Malotte K; O'Donnell, LN | Video-Based Intervention Study to Prevent HIV/Sexually Transmitted Diseases (STDs) Among STD Clinic Patients | Urban STD clinics | Sexually active adults, age 18 and older | Brief 23-minute waiting room educational video vs. standard waiting room experience | STD incidence as determined by medical record review and STD surveillance registry data; sexual behavior assessed in random sample of patients | No longer recruiting
Morokoff, P | Increasing Condom Use in People at Risk for HIV Infection | Health clinics serving local ethnic minority communities | At-risk, heterosexual; males and female, ages 18–44 | Computer-delivered individualized intervention vs. HIV information comparison group | Condom use, risk behaviors | No longer recruiting
Jemmott, LS | Effects on Sexual Risk Behavior and STD Rate of Brief HIV/STD Prevention Interventions for African American Women in Primary Care Settings. | Primary care setting | African American females; ages | 20-minute one-on-one HIV/STD behavioral skill-building intervention, 200-minute group HIV/STD behavioral skill-building intervention, 20-minute one-on-one HIV/STD information intervention, 200-minute group HIV/STD information intervention, or 200-minute health intervention control group | Risk behaviors, STI reduction | In Press