# Appendix C: Excluded studies table

## Reference Reason for exclusion

A gender and culture-specific HIV prevention programme significantly reduces risky sexual behaviours in African American adolescent girls. Evidence-Based Healthcare and Public Health 9(1):67–68, 2005. Excluded study design
Aggleton P, Rivers K. Interventions for adolescents. In: Gibbney, editor. Preventing HIV in Developing Countries: Biomedical and Behavioral Approaches. New York: Plenum Press, 1999: 231–255. Excluded study design
Anderson ES, Wagstaff DA, Heckman TG, et al. Information-Motivation-Behavioral Skills (IMB) Model: testing direct and mediated treatment effects on condom use among women in low-income housing. Ann Behav Med. 2006;31(1):70-79. Incorrect setting. [pmid: 16472041].
Artz L, Macaluso M, Meinzen-Derr J, et al. A randomized trial of clinician-delivered interventions promoting barrier contraception for sexually transmitted disease prevention. Sexually Transmitted Diseases. 2005;32(11):672-9. Does not meet USPSTF quality criteria. [pmid: 16254541].
Baker A, Heather N, Wodak A, et al. Evaluation of a cognitive-behavioural intervention for HIV prevention among injecting drug users. AIDS. 1993;7(2):247-56. Incorrect setting. [pmid: 8466688].
Belcher L, Kalichman S, Topping M, et al. A randomized trial of a brief HIV risk reduction counseling intervention for women. J Consult Clin Psychol. 1998;66(5):856-861. Comparative effectiveness study. [pmid: 9803706].
Bellingham K, Gillies P. Evaluation of an AIDS education programme for young adults. Journal of Epidemiology & Community Health. 1993;47(2):134-8. Incorrect population. [pmid: 8326271].
Berkman A, Pilowsky DJ, Zybert PA, et al. The impact of substance dependence on HIV sexual risk-reduction among men with severe mental illness. AIDS Care. 2005;17(5):635-639. Comparative effectiveness study. [pmid: 16036249].
Berkman A. Reducing Sexual Risk Behaviors of Men With Severe Mental Illness. Psychiatric Services. 2006;57(3):417. Comparative effectiveness study. [pmid: 16525006].
Booth RE, Zhang Y. The challenge of changing drug and sex risk behaviors of runaway and homeless adolescents. Child Abuse & Neglect. 1999;23(12):1295-1306. Incorrect setting. [pmid: 10626612].
Bowen AM. Predicting increased condom use with main partners: Potential approaches to intervention. Drugs & Society. 1996;Vol 9:57-74. Does not meet USPSTF quality criteria. [pmid: 12348011].
Boyer CB, Shafer MA, Shaffer RA, et al. Evaluation of a cognitive-behavioral, group, randomized controlled intervention trial to prevent sexually transmitted infections and unintended pregnancies in young women. Preventive Medicine. 2005;40(4):420-31. Incorrect setting. [pmid: 15530594].
Branson BM, Peterman TA, Cannon RO, et al. Group counseling to prevent sexually transmitted disease and HIV: a randomized controlled trial. Sex Transm Dis. 1998;25(10):553-560. Comparative effectiveness study. [pmid: 9858353].
Braverman PK. Abstinence and safer sex HIV risk-reduction interventions for African-American adolescents. Clin Pediatr (Phila). 1999;38(3):184-187. Excluded study design. [pmid: 10366287].
Bryan AD, Aiken LS, West SG. Increasing condom use: Evaluation of a theory-based intervention to prevent sexually transmitted diseases in young women. Health Psychology Vol 15(5) Sep 1996, 371–382 http://www apa org/journals/hea html (http://www.apa.org/journals/hea.html) 1996. Incorrect setting
Calsyn DA, Saxon AJ, Freeman G, et al. Ineffectiveness of AIDS education and HIV antibody testing in reducing high-risk behaviors among injection drug users. American Journal of Public Health. 1992;82(4):573-5. Incorrect population. [pmid: 1546776].
Calsyn DA, Saxon AJ, Wells EA, et al. Longitudinal sexual behavior changes in injecting drug users. AIDS. 1992;6(10):1207-11. Excluded study design. [pmid: 1466854].
Carballo-Dieguez A, Dolezal C, Leu CS, et al. A randomized controlled trial to test an HIV-prevention intervention for Latino gay and bisexual men: lessons learned. AIDS Care. 2005;17(3):314-28. Incorrect setting. [pmid: 15832879].
Carey MP, Braaten LS, Maisto SA, et al. Using information, motivational enhancement, and skills training to reduce the risk of HIV infection for low-income urban women: a second randomized clinical trial. Health Psychol. 2000;19(1):3-11. Incorrect setting. [pmid: 10711582].
Carey MP, Maisto SA, Kalichman SC, et al. Enhancing motivation to reduce the risk of HIV infection for economically disadvantaged urban women. Journal of Consulting & Clinical Psychology. 1997;65(4):531-41. Incorrect setting. [pmid: 9256553].
Chernoff RA, Davison GC. An evaluation of a brief HIV/AIDS prevention intervention for college students using normative feedback and goal setting. AIDS Education & Prevention. 2005;17(2):91-104. Does not report designated outcomes. [pmid: 15899748].
Choi KH, Lew S, Vittinghoff E, et al. The efficacy of brief group counseling in HIV risk reduction among homosexual Asian and Pacific Islander men. AIDS. 1996;10(1):81-7. Incorrect setting. [pmid: 8924256].
Clark LR, Brasseux C, Richmond D, et al. Effect of HIV counseling and testing on sexually transmitted diseases and condom use in an urban adolescent population. Archives of Pediatrics & Adolescent Medicine. 1998;152(3):269-73. Excluded study design. [pmid: 9529465].
Cohen D, Reardon K, Alleyne D, et al. Influencing spermicide use among low-income minority women. J Am Med Womens Assoc. 1995;50(1):11-13. Does not report designated outcomes. [pmid: 7860956].
Cohen DA, Dent C, MacKinnon D, et al. Condoms for men, not women. Results of brief promotion programs. Sex Transm Dis. 1992;19(5):245-251. Does not meet USPSTF quality criteria. [pmid: 1411840].
Cohen DA, MacKinnon DP, Dent C, et al. Group counseling at STD clinics to promote use of condoms. Public Health Rep. 1992;107(6):727-731. Does not meet USPSTF quality criteria. [pmid: 1454987].
Collins P. HIV Prevention for Mentally Ill Men and Women. Xth World Congress of Psychiatry, Madrid, Spain 23rd–28th August, 1996. Incorrect setting
Cottler LB, Compton WM, Ben Abdallah A, et al. Peer-delivered interventions reduce HIV risk behaviors among out-of-treatment drug abuSERs. Public Health Reports. 1998;113(Suppl 1):31-41. Comparative effectiveness study. [pmid: 9722808].
Coyle K, Basen-Engquist K, Kirby D, et al. Short-term impact of safer choices: a multicomponent, school-based HIV, other STD, and pregnancy prevention program. Journal of School Health. 1999;69(5):181-8. Incorrect setting. [pmid: 10363221].
Dallabetta G, Serwadda D, Mugrditchian D. Controlling Other Sexually Transmitted Diseases. 1999. Excluded study design
Dancy BL, Marcantonio R. The long-term effectiveness of an HIV prevention intervention for low-income African American women. AIDS education and prevention: official publication of the International Society for AIDS Education. 2000;2(2):95-108. Incorrect setting.
Deren S, Davis WR, Beardsley M, et al. Outcomes of a risk-reduction intervention with high-risk populations: the Harlem AIDS project. AIDS Education & Prevention. 1995;7(5):379-90. Incorrect setting. [pmid: 8672391].
DiClemente RJ, Wingood GM. A randomized controlled trial of an HIV sexual risk-reduction intervention for young African-American women. JAMA : the journal of the American Medical Association. 1995;274(16):1271-6. Incorrect setting. [pmid: 7563531].
Diers JA. Efficacy of a stage-based counseling intervention to reduce the risk of HIV in women. 2000. Incorrect setting
Dilley JW, Woods WJ, Sabatino J, et al. Changing sexual behavior among gay male repeat testers for HIV: a randomized, controlled trial of a single-session intervention. J Acquir Immune Defic Syndr. 2002;30(2):177-186. Comparative effectiveness study. [pmid: 12045680].
Downs JS, Murray PJ, Bruine dB, et al. Interactive video behavioral intervention to reduce adolescent females' STD risk: a randomized controlled trial. Social Science & Medicine. 2004;59(8):1561-72. Comparative effectiveness study. [pmid: 15279915].
Dworkin SL, Exner T, Melendez R, et al. Revisiting “Success”: Posttrial Analysis of a Gender-Specific HIV/STD Prevention Intervention. AIDS and Behavior. 2006;10(1):41-51. Excluded study design. [pmid: 16570217].
El Bassel N, Schilling RF. 15-month followup of women methadone patients taught skills to reduce heterosexual HIV transmission. Public Health Reports. 1992;107(5):500-4. Oct. Incorrect population. [pmid: 1410230].
El Bassel N, Witte SS, Gilbert L, et al. Long-term effects of an HIV/STI sexual risk reduction intervention for heterosexual couples. AIDS & Behavior. 2005;9(1):1-13. Comparative effectiveness study. [pmid: 15812609].
El Bassel N, Witte SS, Gilbert L, et al. The efficacy of a relationship-based HIV/STD prevention program for heterosexual couples. American Journal of Public Health. 2003;93(6):963-9. Comparative effectiveness study. [pmid: 12773363].
Feldblum PJ, Chen-Mok M, Bwayo JJ, et al. Intracluster correlation of STD prevalence in a community intervention trial in Kenya. Lancet. 1999;354(9187):1356-7. Does not report designated outcomes. [pmid: 10533869].
Feldblum PJ, Kuyoh M, Omari M, et al. Baseline STD prevalence in a community intervention trial of the female condom in Kenya. Sexually Transmitted Infections. 2000;76(6):454-6. Does not report designated outcomes. [pmid: 11221128].
Ferguson SL. Evaluation of the effects of peer counseling in a culturally-specific adolescent pregnancy prevention program for african american females. Disertation Abstracts International Section A: Humanities and Social Sciences Vol 60(9-A), Apr 2000, pp 3538 1996. Incorrect setting
Fisher JD, Fisher WA, Misovich SJ, et al. Changing AIDS risk behavior: effects of an intervention emphasizing AIDS risk reduction information, motivation, and behavioral skills in a college student population. Health Psychology. 1996;15(2):114-23. Incorrect setting. [pmid: 8681919].
Flaskerud JH, Nyamathi AM, Uman GC. Longitudinal effects of an HIV testing and counseling programme for low-income Latina women. Ethnicity & Health. 1997;2(12):89-103. Jun. Comparative effectiveness study. [pmid: 9395592].
Flowers P. Does bar-based, peer-led sexual health promotion have a community-level effect amongst gay men in Scotland?. Internation Journal of STD and AIDS. 2002;13(2):102-108. Incorrect setting.
Fogarty LA, Heilig CM, Armstrong K, et al. Long-term effectiveness of a peer-based intervention to promote condom and contraceptive use among HIV-positive and at-risk women. Public Health Rep. 2001;116(Suppl 1):103-119. Incorrect population. [pmid: 11889279].
From the Centers for Disease Control and Prevention. Contraceptive practices before and after an intervention promoting condom use to prevent HIV infection and other sexually transmitted diseases among women—selected US sites, 1993-1995. JAMA. 1997;277(22):1752-3. Excluded study design. [pmid: 9178777].
Gallagher TJ, Cottler LB, Compton WMI et al. Changes in HIV/AIDS risk behaviors in drug users in St. Louis: Applications of random regression models. Journal of Drug Issues Vol 27(2) Spr 1997, 399–416 http://www2 criminology fsu edu/~jdi/ (http://www2.criminology.fsu.edu/~jdi/) 1997. Incorrect population
Gibson DR, Lovelle-Drache J, Young M,et al. Effectiveness of brief counseling in reducing HIV risk behavior in injecting drug users: Final results of randomized trials of counseling with and without HIV testing. AIDS and Behavior Vol 3(1) Mar 1999, 3–12 http://www springeronline com/sgw/cda/frontpage/0,11855,4-40109-70-35538888-0,00 html?changeHeader=true (http://www.springeronline.com/sgw/cda/frontpage/0,11855,4-40109-70-35538888-0,00.html?changeHeader=true) 1999. Incorrect population
Gibson DR, Wermuth L, Lovelle-Drache J et al. Brief counseling to reduce AIDS risk in intravenous drug uSERs and their sexual partners: Preliminary results. Counselling Psychology Quarterly Vol 2(1) 1989, 15–19 http://www tandf co uk/journals/carfax/09515070 html (http://www.tandf.co.uk/journals/carfax/09515070.html) 1989. Incorrect population
Gielen AC, Fogarty LA. Promoting condom use with main partners: A behavioral intervention trial for women. AIDS & Behavior. 2001;5(3):193-204. Incorrect population.
Gielen AC, Faden RR, Kass NE, et al. Evaluation of an HIV/AIDS education program in an urban prenatal clinic. Womens Health Issues. 1997;7(4):269-78. Aug. Excluded study design. [pmid: 9283282].
Gillmore MR, Morrison DM, Richey CA, et al. Effects of a skill-based intervention to encourage condom use among high risk heterosexually active adolescents. AIDS Education & Prevention. 1997;9(1 Suppl):22-43. Comparative effectiveness study. [pmid: 9083597].
Gold R, Rosenthal DA. Preventing unprotected anal intercourse in gay men: A comparison of two intervention techniques. International Journal of STD & AIDS. 1995;6(2):89-94. Incorrect setting. [pmid: 7779937].
Gollub EL, French P, Loundou A, et al. A randomized trial of hierarchical counseling in a short, clinic-based intervention to reduce the risk of sexually transmitted diseases in women. AIDS. 2000;14(9):1249-55. Comparative effectiveness study. [pmid: 10894290].
Gollub EL. The female condom: tool for women's empowerment. American Journal of Public Health. 2000;90(9):1377-81. Study not evaluate bci. [pmid: 10983187].
Greenberg J, Hennessy M, MacGowan R, et al. Modeling intervention efficacy for high-risk women. The WINGS Project. Evaluation & the Health Professions. 2000;23(2):123-48. Incorrect setting. [pmid: 10947521].
Hajagos K, Geiser P, Parker B, et al. Safer-sex education for persons with mental illness. Journal of Psychosocial Nursing & Mental Health Services. 1998;36(8):33-7. Does not report designated outcomes. [pmid: 9726084].
Harris RM, Bausell RB, Scott DE, et al. An intervention for changing high-risk HIV behaviors of African American drug-dependent women. Res Nurs Health. 1998;21(3):239-250. Incorrect population. [pmid: 9609509].
Harvey SM, Henderston JT, Thorburn S, et al. A randomized study of a pregnancy and disease prevention intervention for Hispanic couples. Perspectives on sexual and reproductive health. 2004;36(4):162-9. Comparative effectiveness study. [pmid: 15321783].
Hetherington SE, Harris RM, Bausell RB, et al. AIDS prevention in high-risk African American women: behavioral, psychological, and gender issues. J Sex Marital Ther. 1996;22(1):9-21. Incorrect population. [pmid: 8699500].
Hewitt NB. Africentricity, HIV behavioral intervention, and HIV risk-associated behavior among African-American adolescents: A randomized controlled trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. Aug. 1999;Vol 60(2-B). Incorrect setting.
Hobfoll SE, Jackson AP, Lavin J, et al. Reducing inner-city women's AIDS risk activities: a study of single, pregnant women. Health Psychology. 1994;13(5):397-403. Does not meet USPSTF quality criteria. [pmid: 7805634].
Hobfoll SE, Jackson AP, Lavin J, et al. Effects and generalizability of communally oriented HIV-AIDS prevention versus general health promotion groups for single, inner-city women in urban clinics. Journal of Consulting & Clinical Psychology. 2002;70(4):950-60. Does not meet USPSTF quality criteria. [pmid: 12182278].
Hoffman JA, Klein H, Crosby H, et al. Project neighborhoods in action: an HIV-related intervention project targeting drug abusers in Washington, DC. J Urban Health. 1999;76(4):419-434. Comparative effectiveness study. [pmid: 10609592].
Imrie J, Stephenson JM, Cowan FM, et al. A cognitive behavioural intervention to reduce sexually transmitted infections among gay men: randomised trial. BMJ. 2001;322(7300):1451-1456. Comparative effectiveness study. [pmid: 11408300].
James NJ, Gillies PA, Bignell CJ. Evaluation of a randomized controlled trial of HIV and sexually transmitted disease prevention in a genitourinary medicine clinic setting. AIDS. 1998;12(10):1235-1242. Does not meet USPSTF quality criteria. [pmid: 9677173].
Jaworski BC, Carey MP. Effects of a brief, theory-based STD-prevention program for female college students. Journal of Adolescent Health. 2001;29(6):417-25. Does not report designated outcomes. [pmid: 11728891].
Jemmott JB III, Jemmott LS, Fong GT. Abstinence and safer sex HIV risk-reduction interventions for African American adolescents: a randomized controlled trial.[see comment]. JAMA. 1998;279(19):1529-36. Incorrect setting. [pmid: 9605896].
Jemmott JB III, Jemmott LS, Fong GT. Reductions in HIV risk-associated sexual behaviors among black male adolescents: effects of an AIDS prevention intervention.[erratum appears in Am J Public Health 1992 May;82(5):684]. American Journal of Public Health. 1992;82(3):372-7. Incorrect setting. [pmid: 1536352].
Jenkins PR, Jenkins RA, Nannis ED, et al. Reducing risk of sexually transmitted disease (STD) and human immunodeficiency virus infection in a military STD clinic: evaluation of a randomized preventive intervention trial. Clinical Infectious Diseases. 2000;30(4):730-5. Does not report designated outcomes. [pmid: 10770736].
Johnson-Mallard V. The effects of an education/behavioral intervention on knowledge, perceived risk and self-efficacy for sexually transmitted infections in women. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2006;66(9-B):4726. Does not report designated outcomes.
Kalichman SC, Cherry C, Browne-Sperling F. Effectiveness of a video-based motivational skills-building HIV risk-reduction intervention for inner-city African American men. Journal of Consulting & Clinical Psychology. 1999;67(6):959-66. Comparative effectiveness study. [pmid: 10596517].
Kalichman SC, Cherry C. Male polyurethane condoms do not enhance brief HIV-STD risk reduction interventions for heterosexually active men: results from a randomized test of concept. International Journal of STD & AIDS. 1999;10(8):548-53. Incorrect population. [pmid: 10471107].
Kalichman SC, Rompa D, Coley B. Experimental component analysis of a behavioral HIV-AIDS prevention intervention for inner-city women. Journal of Consulting & Clinical Psychology. 1996;64(4):687-93. Comparative effectiveness study. [pmid: 8803358].
Kalichman SC, Williams E, Nachimson D. Brief behavioural skills building intervention for female controlled methods of STD-HIV prevention: outcomes of a randomized clinical field trial. International Journal of STD & AIDS. 1999;10(3):174-81. Incorrect population. [pmid: 10340198].
Kelly JA, McAuliffe TL, Sikkema KJ, et al. Reduction in risk behavior among adults with severe mental illness who learned to advocate for HIV prevention. Psychiatric Services. 1997;48(10):1283-8. Comparative effectiveness study. [pmid: 9323747].
Kelly JA, Murphy DA, Washington CD, et al. The effects of HIV/AIDS intervention groups for high-risk women in urban clinics. American Journal of Public Health. 1994;84(12):1918-22. Does not meet USPSTF quality criteria. [pmid: 7998630].
Kelly JA, St Lawrence JS, Hood HV, et al. Behavioral intervention to reduce AIDS risk activities. Journal of Consulting & Clinical Psychology. 1989;57(1):60-7. Does not report designated outcomes. [pmid: 2925974].
Kelly JA. Outcomes of hiv prevention interventions integrated in community clinics that serve persons with severe mental illness. 152nd Annual Meeting of the American Psychiatric Association Washington DC, USA 15–20th May, 1999. Does not meet USPSTF quality criteria
Kennedy MG, Mizuno Y, Hoffman R, et al. The effect of tailoring a model HIV prevention program for local adolescent target audiences. AIDS Education & Prevention. 2000;12(3):225-38. Does not report designated outcomes. [pmid: 10926126].
Kiene SM, Barta WD. A brief individualized computer-delivered sexual risk reduction intervention increases HIV/AIDS preventive behavior. Journal of Adolescent Health. 2006;39(3):404-10. Does not report designated outcomes. [pmid: 16919803].
Kirby D. Six school-based clinics: their reproductive health services and impact on sexual behavior. Family Planning Perspectives. 1991;Vol 23:6-16. Study not evaluate bci. [pmid: 2029947].
Koblin B, Chesney M, Coates T. Effects of a behavioural intervention to reduce acquisition of HIV infection among men who have sex with men: the EXPLORE randomised controlled study. Lancet. 2004;364(9428):41-50. Incorrect setting. [pmid: 15234855].
Koniak-Griffin D, Stein JA. Predictors of sexual risk behaviors among adolescent mothers in a human immunodeficiency virus prevention program. Journal of Adolescent Health 38(3):297 e1 –11, 2006. Incorrect setting
Kotranski L, Semaan S, Collier K, et al. Effectiveness of an HIV risk reduction counseling intervention for out-of-treatment drug users. AIDS Education & Prevention. 1998;10(1):19-33. Comparative effectiveness study. [pmid: 9505096].
Krauss BJ, Goldsamt L, Bula E, et al. Pretest assessment as a component of safer sex intervention: a pilot study of brief one-session interventions for women partners of male injection drug users in New York City. Journal of Urban Health. 2000;77(3):383-95. Does not report designated outcomes. [pmid: 10976612].
Landis SE, Earp JL, Koch GG. Impact of HIV testing and counseling on subsequent sexual behavior. AIDS Education & Prevention. 1992;4(1):61-70. Excluded study design. [pmid: 1543646].
Latkin CA, Sherman S, Knowlton A. HIV prevention among drug users: outcome of a network-oriented peer outreach intervention. Health Psychol. 2003;22(4):332-339. Incorrect population. [pmid: 12940388].
Latkin CA. A personal network approach to AIDS prevention: an experimental peer group intervention for street-injecting drug users: the SAFE study. NIDA Research Monograph. 1995;151:181-95. Incorrect setting. [pmid: 8742766].
Lederman RP, Mian TS. The parent-adolescent relationship education (PARE) program: a curriculum for prevention of STDs and pregnancy in middle school youth. Behavioral Medicine. 2003;29(1):33-41. Does not report designated outcomes. [pmid: 14977246].
Lee SK. Limitations of a university AIDS prevention program. ACHPER Healthy Lifestyles J. 1994;41(4):4-8. Incorrect setting.
Legardy JK, Macaluso M, Artz L, Brill I. Do participant characteristics influence the effectiveness of behavioral interventions? Promoting condom use to women. Sexually Transmitted Diseases. 2005;32(11):665-71. Does not meet USPSTF quality criteria. [pmid: 16254540].
Leukefeld C, Roberto H, Hiller M, Webster M, Logan TK, Staton-Tindall M. HIV prevention among high-risk and hard-to-reach rural residents. Journal of Psychoactive Drugs. 2003;35(4):427-34. Dec. Comparative effectiveness study. [pmid: 14986871].
Leviton LC, Valdiserri RO, Lyter DW, Callahan CM, Kingsley LA, Huggins J, et al. Preventing HIV infection in gay and bisexual men: experimental evaluation of attitude change from two risk reduction interventions. AIDS Education & Prevention. 1990;2(2):95-108. Incorrect population. [pmid: 2393625].
Li X, Stanton B, Feigelman S. Unprotected sex among African-American adolescents: a three-year study. J Natl Med Assoc. 2002;94(9):789-796. Comparative effectiveness study. [pmid: 12392042].
Lindenberg CS, Solorzano RM, Bear D, et al. Reducing substance use and risky sexual behavior among young, low-income, Mexican-American women: comparison of two interventions. Applied Nursing Research. 2002;15(3):137-48. Comparative effectiveness study. [pmid: 12173165].
Linn JG, Neff JA, Theriot R, et al. Reaching impaired populations with HIV prevention programs: a clinical trial for homeless mentally ill African-American men. Cellular & Molecular Biology. 2003;49(7):1167-75. Comparative effectiveness study. [pmid: 14682400].
Maher JE, Peterman TA, Osewe PL, et al. Evaluation of a community-based organization's intervention to reduce the incidence of sexually transmitted diseases: a randomized, controlled trial. South Med J. 2003;96(3):248-253. Does not meet USPSTF quality criteria. [pmid: 12661534].
Makulowich GS. Culturally relevant behavioral intervention dramatically reduces STDs. AIDS Patient Care STDS. 1999;13(4):251-252. Excluded study design.
Makulowich GS. HIV and STD prevention update. Multisite HIV prevention trial. AIDS Patient Care & Stds. 1998;12(9):725-7. Excluded study design. [pmid: 15468447].
Margolin A, Beitel M, Schuman-Olivier Z. A controlled study of a spirituality-focused intervention for increasing motivation for HIV prevention among drug users. AIDS Education & Prevention. 2006;18(4):311-22. Does not report designated outcomes. [pmid: 16961448].
Margolis HS, Handsfield HH, Jacobs RJ, et al. Evaluation of office-based intervention to improve prevention counseling for patients at risk for sexually acquired hepatitis B virus infection. Hepatitis B-WARE Study Group. American Journal of Obstetrics & Gynecology. 2000;182(1 Pt 1):1-6. Does not report designated outcomes. [pmid: 10649147].
Marsch LA, Bickel WK. Efficacy of computer-based HIV/AIDS education for injection drug users. American Journal of Health Behavior. 2004;28(4):316-27. Aug. Incorrect setting. [pmid: 15228968].
Martin SS, O'Connell DJ, Inciardi JA, et al. HIV/AIDS among probationers: an assessment of risk and results from a brief intervention. Journal of Psychoactive Drugs. 2003;35(4):435-43. Dec. Comparative effectiveness study. [pmid: 14986872].
McCoy CB, Chitwood DD, Khoury EL et al. The implementation of an experimental research design in the evaluation of an intervention to prevent AIDS among IV drug users. Journal of Drug Issues Vol 20(2) Spr 1990, 215–222 http://www2 criminology fsu edu/~jdi/ (http://www2.criminology.fsu.edu/~jdi/) 1990. Comparative effectiveness study
McCoy HV, Dodds SE, Nolan C. AIDS intervention design for program evaluation: The Miami Community Outreach Project. Journal of Drug Issues Vol 20(2) Spr 1990, 223–243 http://www2 criminology fsu edu/~jdi/ (http://www2.criminology.fsu.edu/~jdi/) 1990. Comparative effectiveness study
McCoy HV, McCoy CB, Lai S. Effectiveness of HIV interventions among women drug uSERs. Women & Health. 1998;27(12):49-66. Comparative effectiveness study. [pmid: 9640634].
McKay A. Evaluation of a cognitive-behavioral, group, randomized controlled intervention trial to prevent sexually transmitted infections and unintended pregnancies in young women. Preventive Medicine 40, 420–431. Canadian Journal of Human Sexuality. 2004;13(2):124-125. Excluded study design.
Metcalf CA, Douglas JM Jr, Malotte CK, et al. Relative efficacy of prevention counseling with rapid and standard HIV testing: a randomized, controlled trial (RESPECT-2). Sex Transm Dis. 2005;32(2):130-138. Comparative effectiveness study. [pmid: 15668621].
Metzler CW, Biglan A, Noell J et al. A randomized controlled trial of a behavioral intervention to reduce high-risk sexual behavior among adolescents in STD clinics. Behavior Therapy Vol 31(1) Win 2000, 27–54 2000. Does not meet USPSTF quality criteria
Miller B, Norton M, Jenson G et al. Impact Evaluation of Facts & Feelings A Home-based Video Sex Education Curriculum. Family Relations 1993;392–400. Incorrect setting
Miller LC, Murphy ST, Clark LF, et al. Hierarchical messages for introducing multiple HIV prevention options: promise and pitfalls. AIDS Education & Prevention. 2004;16(6):509-25. Does not report designated outcomes. [pmid: 15585428].
Miller RL, Klotz D. HIV prevention with male prostitutes and patrons of hustler bars: replication of an HIV preventive intervention. American Journal Of Community Psychology. 1998;26(1):97-131. Incorrect setting. [pmid: 9574500].
Morrison-Beedy D, Carey MP, Kowalski J, et al. Group-based HIV risk reduction intervention for adolescent girls: evidence of feasibility and efficacy. Research in Nursing & Health. 2005;28(1):3-15. Does not meet USPSTF quality criteria. [pmid: 15625713].
Neaigus A, Sufian M, Friedman SR, et al. Effects of outreach intervention on risk reduction among intravenous drug users. AIDS Education & Prevention. 1990;2(4):253-71. Excluded study design. [pmid: 2099157].
Nyamathi A, Flaskerud J, Keenan C, et al. Effectiveness of a specialized vs. traditional AIDS education program attended by homeless and drug-addicted women alone or with supportive persons. AIDS Education & Prevention. 1998;10(5):433-46. Incorrect setting. [pmid: 9799939].
Nyamathi AM, Kington RS, Flaskerud J, et al. Two-year follow-up of AIDS education programs for impoverished women. Western Journal of Nursing Research. 1999;21(3):405-25. Incorrect population. [pmid: 11512206].
Oakeshott P, Kerry S, Hay S, et al. Condom promotion in women attending inner city general practices for cervical smears: a randomized controlled trial. Family Practice. 2000;17(1):56-9. Does not report designated outcomes. [pmid: 10673490].
O'Donnell CR, O'Donnell L, San Doval A, et al. Reductions in STD infections subsequent to an STD clinic visit. Using video-based patient education to supplement provider interactions. Sexually Transmitted Diseases. 1998;25(3):161-8. Does not meet USPSTF quality criteria. [pmid: 9524995].
O'Leary A, Ambrose TK, Raffaelli M, et al. Effects of an HIV risk reduction project on sexual risk behavior of low-income STD patients. AIDS Education & Prevention. 1998;10(6):483-92. Does not meet USPSTF quality criteria. [pmid: 9883284].
O'Neill K, Baker A, Cooke M, et al. Evaluation of a cognitive-behavioural intervention for pregnant injecting drug users at risk of HIV infection. Addiction. 1996;91(8):1115-25. Incorrect population. [pmid: 8828240].
Orr DP, Langefeld CD, Katz BP, et al. Behavioral intervention to increase condom use among high-risk female adolescents. J Pediatr. 1996;128(2):288-295. Does not meet USPSTF quality criteria. [pmid: 8636834].
Otto-Salaj LL, Kelly JS, Stevenson Ly, et al. Outcomes of a randomized small-group HIV prevention intervention trial for people with serious mental illness. Community Mental Health Journal. 2001;37(2):123-44. Does not meet USPSTF quality criteria. [pmid: 11318241].
Peragallo N, Deforge B, O'Campo P, et al. A randomized clinical trial of an HIV-risk-reduction intervention among low-income Latina women. Nursing Research. 2005;54(2):108-18. Apr. Does not meet USPSTF quality criteria. [pmid: 15778652].
Peterman TA, Tian LH, Metcalf CA, et al. High incidence of new sexually transmitted infections in the year following a sexually transmitted infection: a case for rescreening. Annals of Internal Medicine. 2006;145(8):564-72. Study not evaluate bci. [pmid: 17043338].
Peterson JL, Coates TJ, Catania J, et al. Evaluation of an HIV risk reduction intervention among African-American homosexual and bisexual men. AIDS. 1996;10(3):319-25. Incorrect setting. [pmid: 8882672].
Picciano JF, Roffman RA, Kalichman SC et al. A telephone based brief intervention using motivational enhancement to facilitate HIV risk reduction among MSM: A pilot study. AIDS and Behavior Vol 5(3) Sep 2001, 251–262 2001. Does not report designated outcomes
Ploem C. The effects of two AIDS risk-reduction interventions on heterosexual college women's AIDS-related knowledge, attitudes and condom use. Journal of Psychology & Human Sexuality. 1997;9(1):1-24. Does not report designated outcomes. [pmid: 12348049].
Porche DJ. Condom effectiveness. Journal of the Association of Nurses in AIDS Care. 1998;9(3):91-4. Jun. Excluded study design. [pmid: 9589424].
Read SJ, Miller LC, Appleby PR et al. Socially Optimized Learning in a Virtual Environment: Reducing Risky Sexual Behavior Among Men Who Have Sex With Men. a 6 A.D. Comparative effectiveness study
Reduction of high-risk sexual behaviour among heterosexuals undergoing HIV antibody testing: a randomized clinical trial. Disease Markers 9(6):354–5, 1991;-Dec. Country not applicable to us population
Rickert VI, Gottlieb A, Jay MS. A comparison of three clinic-based AIDS education programs on female adolescents' knowledge, attitudes, and behavior. Journal of Adolescent Health Care. 1990;11(4):298-303. Does not report designated outcomes. [pmid: 2365604].
Roffman RA, Picciano JE. HIV-prevention group counseling delivered by telephone: an efficacy trial with gay and bisexual men. AIDS and Behavior. 1997;1(2):137-154. Incorrect setting.
Ros, Bockting WO, Rugg DL, Robinson BB, et al. A randomized controlled intervention trial of a sexual health approach to long-term HIV risk reduction for men who have sex with men: effects of the intervention on unsafe sexual behavior. AIDS Education & Prevention. 2002;14(3 Suppl A):59-71. Incorrect setting. [pmid: 12092938].
Rotheram-Borus MJ, Gwadz M, Fernandez MI, et al. Timing of HIV interventions on reductions in sexual risk among adolescents. American Journal of Community Psychology. 1998;26(1):73-96. Incorrect setting. [pmid: 9574499].
Rotheram-Borus MJ, Murphy DA, Fernandez MI, et al. A brief HIV intervention for adolescents and young adults. American Journal of Orthopsychiatry. 1998;68(4):553-564. Incorrect setting. [pmid: 9809115].
Rotheram-Borus MJ, Song J, Gwadz M, et al. Reductions in HIV risk among runaway youth. Prevention Science. 2003;4(3):173-87. Incorrect setting. [pmid: 12940468].
Rotheram-Borus MJ. HIV prevention with persons with mental health problems. Psychology, Health & Medicine. 2006;11(2):142-154. Comparative effectiveness study.
Roye C, Silverman PP, Krauss B. A Brief, Low-Cost, Theory-Based Intervention to Promote Dual Method Use by Black and Latina Female Adolescents: A Randomized Clinical Trial. Health Educ Behav 2006;. Does not report designated outcomes
Russell NK, Boekeloo BO, Rafi IZ, et al. Using unannounced simulated patients to evaluate sexual risk assessment and risk reduction skills of practicing physicians. Academic Medicine. 1991;66(9 Suppl):S37-9. Study not evaluate bci. [pmid: 1930522].
Sanderson CA, Jemmott JBI. Moderation and mediation of HIV-prevention interventions: Relationship status, intentions, and condom use among college students. Journal of Applied Social Psychology Vol 26(23) Dec 1996, 2076–2099 http://www bellpub com/jasp/index htm (http://www.bellpub.com/jasp/index.htm) 1996. Incorrect setting
Schilling RF, El Bassel N, Schinke SP, et al. Building skills of recovering women drug users to reduce heterosexual AIDS transmission. Public Health Reports. 1991;106(3):297-304. Jun. Incorrect population. [pmid: 1905051].
Schinke SP, Gordon AN, Weston RE. Self-instruction to prevent HIV infection among African-American and Hispanic-American adolescents. Journal of Consulting & Clinical Psychology. 1990;58(4):432-6. Does not report designated outcomes. [pmid: 2212180].
School-based interventions to prevent unprotected sex and HIV among adolescents. 1994. Incorrect setting
Schroeder JR, Epstein DH, Umbricht A, et al. Changes in HIV risk behaviors among patients receiving combined pharmacological and behavioral interventions for heroin and cocaine dependence. Addict Behav. 2006;31(5):868-879. Incorrect population. [pmid: 16085366].
Sellers DE, McGraw SA, McKinlay JB. Does the promotion and distribution of condoms increase teen sexual activity? Evidence from an HIV prevention program for Latino youth. Am J Public Health. 1994;84(12):1952-1959. Incorrect setting. [pmid: 7998636].
Shlay JC, Mayhugh B, Foster M, et al. Initiating contraception in sexually transmitted disease clinic setting: a randomized trial. American Journal of Obstetrics & Gynecology. 2003;189(2):473-81. Comparative effectiveness study. [pmid: 14520221].
Shoptaw S, Frosch D, Rawson RA, et al. Cocaine abuse counseling as HIV prevention. AIDS Education & Prevention. 1997;9(6):511-20. Study not evaluate bci. [pmid: 9451479].
Shrier LA, Ancheta R, Goodman E, et al. Randomized controlled trial of a safer sex intervention for high-risk adolescent girls. Archives of Pediatrics & Adolescent Medicine. 2001;155(1):73-9. Incorrect population. [pmid: 11177066].
Siegel DM, Aten MJ. Early effects of a school-based human immunodeficiency virus infection and sexual risk prevention intervention. Archives of Pediatrics and Adolescent Medicine. 1998;Vol 152:961-942. Incorrect setting. [pmid: 9790605].
Simbayi LC, Kalichman SC, Skinner D, et al. Theory-based HIV risk reduction counseling for sexually transmitted infection clinic patients in Cape Town, South Africa. Sexually Transmitted Diseases. 2004;31(12):727-33. Comparative effectiveness study. [pmid: 15608587].
Slap GB, Plotkin SL, Khalid N, et al. A human immunodeficiency virus peer education program for adolescent females. Journal of Adolescent Health. 1991;12(6):434-42. Excluded study design. [pmid: 1768696].
Smith PB, Weinman ML, Parrilli J. The role of condom motivation education in the reduction of new and reinfection rates of sexually transmitted diseases among inner-city female adolescents. Patient Education & Counseling. 1997;31(1):77-81. Does not report designated outcomes. [pmid: 9197805].
Social-cognitive theory mediators of behavior change in the National Institute of Mental Health Multisite HIV Prevention Trial. Health Psychology 2001;(5):369–376. Comparative effectiveness study
Solomon B, McGuinn L, Hoerlein M, et al. Is human immunodeficiency virus sexual risk prevention intervention effective?. Archives of Pediatrics & Adolescent Medicine. 2001;155(10):1127-30. Excluded study design. [pmid: 11576007].
Soper D, Shoupe D. Prevention of vaginal trichomoniasis by compliant use of the female condom. Sexually Transmitted Diseases 1993;(3). Does not meet USPSTF quality criteria
Sorensen JL, London J, Heitzmann C, et al. Psychoeducational group approach: HIV risk reduction in drug users. AIDS Education & Prevention. 1994;6(2):95-112. Incorrect population. [pmid: 8018443].
St Lawrence JS, Brasfield TL, Jefferson KW, et al. Cognitive-behavioral intervention to reduce African American adolescents' risk for HIV infection. Journal of Consulting & Clinical Psychology. 1995;63(2):221-37. Comparative effectiveness study. [pmid: 7751483].
Stanton B, Fang X, Li X, et al. Evolution of risk behaviors over 2 years among a cohort of urban African American adolescents. Archives of Pediatrics & Adolescent Medicine. 1997;151(4):398-406. Incorrect setting. [pmid: 9111440].
Stanton B, Guo J, Cottrell L, et al. The complex business of adapting effective interventions to new populations: an urban to rural transfer. Journal of Adolescent Health. 2005;37(2):163. Incorrect setting. [pmid: 16026728].
Stanton B, Harris C, Cottrell L, et al. Trial of an urban adolescent sexual risk-reduction intervention for rural youth: a promising but imperfect fit. Journal of Adolescent Health. 2006;38(1):55. Incorrect setting. [pmid: 16387250].
Stanton BF, Li X, Galbraith J, et al. Sexually transmitted diseases, human immunodeficiency virus, and pregnancy prevention. Combined contraceptive practices among urban African-American early adolescents. Archives of Pediatrics & Adolescent Medicine. 1996;150(1):17-24. Incorrect setting. [pmid: 8542001].
Stanton BF, Li X, Ricardo I, et al. A randomized, controlled effectiveness trial of an AIDS prevention program for low-income African-American youths. Archives of Pediatrics & Adolescent Medicine. 1996;150(4):363-72. Incorrect setting. [pmid: 8634730].
Steiner MJ, Hertz-Picciotto I, Taylor D, et al. Retrospective vs. prospective coital frequency and menstrual cycle length in a contraceptive effectiveness trial. Annals of Epidemiology. 2001;11(6):428-33. Study not evaluate bci. [pmid: 11454502].
Sterk CE, Theall KP, Elifson KW, et al. HIV risk reduction among African-American women who inject drugs: a randomized controlled trial. AIDS & Behavior. 2003;7(1):73-86. Comparative effectiveness study. [pmid: 14534392].
Sterk CE, Theall KP, Elifson KW. Effectiveness of a risk reduction intervention among African American women who use crack cocaine. AIDS Education & Prevention. 2003;15(1):15-32. Comparative effectiveness study. [pmid: 12627741].
Stevens SJ, Estrada AL, Estrada BD. HIV sex and drug risk behavior and behavior change in a national sample of injection drug and crack cocaine using women. Women & Health. 1998;27(12):25-48. Comparative effectiveness study. [pmid: 9640633].
St Lawrence JS. Cognitive-behavioral group intervention to assist substance-dependent adolescents in lowering HIV infection risk. AIDS Education and Prevention. 1994;Vol 6:425-435. Excluded study design. [pmid: 7818978].
Susser EV. Human immunodeficiency virus sexual risk reduction in homeless men with mental illness. Archives of General Psychiatry. 1998;55(3):266-72. Incorrect setting. [pmid: 9510221].
The NIMH Multisite HIV Prevention Trial: reducing HIV sexual risk behavior. The National Institute of Mental Health (NIMH) Multisite HIV Prevention Trial Group. Science 1998; 280(5371):1889–1894. Comparative effectiveness study
Thompson SC, Kyle D, Swan J, et al. Increasing condom use by undermining perceived invulnerability to HIV. AIDS Education & Prevention. 2002;14(6):505-14. Incorrect setting. [pmid: 12512851].
Towards effective intervention: Evaluating HIV prevention and sexual health education interventions. 1996. Incorrect setting
Tucker T, Fry CL, Lintzeris N, et al. Randomized controlled trial of a brief behavioural intervention for reducing hepatitis C virus risk practices among injecting drug uSERs. Addiction. 2004;99(9):1157-66. Comparative effectiveness study. [pmid: 15317636].
Turner JC, Korpita E, Mohn LA, et al. Reduction in sexual risk behaviors among college students following a comprehensive health education intervention. Journal of American College Health. 1993;41(5):187-93. Incorrect setting. [pmid: 8482756].
Turner R. HIV counseling, testing do not necessarily change women's sexual behavior. Family Planning Perspectives. 1994;Vol 26:282-3. Excluded study design.
Valdiserri RO, Lyter DW, Leviton LC, et al. AIDS prevention in homosexual and bisexual men: results of a randomized trial evaluating two risk reduction interventions. AIDS. 1989;3(1):21-6. Comparative effectiveness study. [pmid: 2496707].
Van Devanter N, Gonzales V, Merzel C, et al. Effect of an STD/HIV behavioral intervention on women's use of the female condom. American Journal of Public Health. 2002;92(1):109-15. Incorrect setting. [pmid: 11772772].
Villarruel AM, Jemmott JB III, Jemmott LS. A randomized controlled trial testing an HIV prevention intervention for Latino youth. Archives of Pediatrics & Adolescent Medicine. 2006;160(8):772-7. Incorrect setting. [pmid: 16894074].
Wagstaff DA, Delamater JD, Havens KK. Subsequent infection among adolescent African-American males attending a sexually transmitted disease clinic. Journal of Adolescent Health. 1999;25(3):217-26. Excluded study design. [pmid: 10475498].
Walker Z, Townsend J, Oakley L, et al. Health promotion for adolescents in primary care: randomised controlled trial. BMJ. 2002;325(7363):524. Does not report designated outcomes. [pmid: 12217993].
Warner BD, Leukefeld CG. Assessing the differential impact of an hiv prevention intervention: who's putting the message into practice?. AIDS Education & Prevention. 2001;13(6):479-94. Comparative effectiveness study. [pmid: 11791781].
Wechsberg WM, Lam WK, Zule WA, et al. Efficacy of a woman-focused intervention to reduce HIV risk and increase self-sufficiency among African American crack abusers. American Journal of Public Health. 2004;94(7):1165-73. Incorrect setting. [pmid: 15226138].
Weinhardt LS, Carey MP, Carey KB, et al. Increasing assertiveness skills to reduce HIV risk among women living with a severe and persistent mental illness. Journal of Consulting & Clinical Psychology. 1998;66(4):680-4. Does not meet USPSTF quality criteria. [pmid: 9735586].
Welsh MJ, Feldblum PJ, Kuyoh MA, et al. Condom use during a community intervention trial in Kenya. International Journal of STD & AIDS. 2001;12(7):469-74. Does not report designated outcomes. [pmid: 11394984].
West SK, Munoz B. Risk factors for constant, severe trachoma among preschool children in Kongwa, Tanzania. American journal of epidemiology. 1996;143(1):73-8. Country not applicable to us population. [pmid: 8533749].
Williams ML, Bowen AM, Timpson SC, et al. HIV prevention and street-based male sex workers: an evaluation of brief interventions. AIDS Educ Prev. 2006;18(3):204-215. Incorrect setting. [pmid: 16774463].
Witte SS, El-Bassel N, Gilbert L, et al. Promoting female condom use to heterosexual couples: findings from a randomized clinical trial. Perspectives on Sexual & Reproductive Health. 2006;38(3):148-54. Comparative effectiveness study. [pmid: 16963388].
Xu J, Wang J, Zhao N, et al. The effectiveness of an intervention program in the promotion of condom use among sexually transmitted disease patients. Chung-Hua Liu Hsing Ping Hsueh Tsa Chih Chinese Journal of Epidemiology. 2002;23(3):218-20. Non-english article. [pmid: 12411094].
Zimmerman MA, Ramirez-Valles J, Suarez E, et al. An HIV/AIDS prevention project for Mexican homosexual men: an empowerment approach. Health Educ Behav. 1997;24(2):177-190. Excluded study design. [pmid: 9079577].
Zimmers E, Privette G, Lowe RH, et al. Increasing use of the female condom through video instruction. Perceptual & Motor Skills. 1999;88(3 Pt 2):1071-7. Does not report designated outcomes. [pmid: 10485084].