# Appendix B: Evidence Tables

Table 1 Evidence Table for KQ1,2,3, 4

Study Characteristics/Design | | Study Population | | Study Intervention | | | Study Outcomes
Study Reference USPSTF Quality | Study Design Locatation Population | Participant Inclusion/Exclusion Criteria | Baseline Demographics | Intervention theory description | Study Intervention | Follow-Up | Biologic Outcomes | UAI or UVI (without condom unless otherwise specified) | Use of condom (male condom unless otherwise specified) | # of sex partners | Abstinence | Other behavioral outcomes | Adverse Outcomes | Other positive outcomes | Comments (concerns about external validity) research role in intervention delivery incentives (Y,N); type
Adult
Carey 2004 ^13^ Fair | RCT Syracuse, NY; urban Outpatient psychiatric Adults with mental illness plus co-morbid alcohol or substance abuse | Inclusion: Ages 18 and over ; sexually active in past year; alcohol or drug use in past year; diagnosis of major mood or thought disorder per SCID; ability to participate per MMSE; minimal literacy per REALM Exclusion: NR | N Randomized Total:408 [underlined: IG:] [underlined: 1]42 [underlined: CG1:] 140 [underlined: CG2:] 126 Age(median) Total:36.5 [underlined: IG:] 57.7 [underlined: CG1:] 37.2 [underlined: CG2:] 36.8 %Male Total:46% [underlined: IG:] 44% [underlined: CG1:] 46% [underlined: CG2:] 47% Race [underlined: %African-American] Total: 21% [underlined: IG:] 26% [underlined: CG1:] 20% [underlined: CG2:] 16% SES No HS graduation: 33% Employed:17% Other: % with hx STI: 38% Frequency unprotected sex acts in past 3 -mo [underlined: IG:] 14.0 [underlined: CG1:] 10.8 [underlined: CG2:] 11.6 # of partners in past 3 mo [underlined: IG:] 1.25 [underlined: CG1:] 1.41 [underlined: CG2:] 1.24 | HIV Risk-reduction; information, role-play, harm reduction, motivational techniques to enhance readiness to change | Intervention Arms [underlined: IG:] Standard outpatient psychiatric care, which included HIV education at discretion of provider + 10-session HIV risk reduction intervention [underlined: CG1:] Standard outpatient psychiatric care, which included HIV education at discretion of provider + 10-session substance use reduction intervention [underlined: CG2]: Standard outpatient psychiatric care, which included HIV education at discretion of provider Format [underlined: IG:]Group [underlined: CG1:] Group [underlined: CG2:] Usual Care Intensity [underlined: IG:] 10 sessions over 5 wks [underlined: CG1:] 10 sessions over 5 wks [underlined: CG2:] Usual Care Delivery [underlined: IG:] 1 male + 1 female facilitator, masters or doctoral level mental health clinician [underlined: CG1:] 1 male + 1 female facilitator, masters or doctoral level mental health clinician [underlined: CG2:] Usual Care | F/U Time Approximately 3-, 6-, 9-mo %F/U(overall) 3-mo=92% 6-mo=89% 9-mo=88% | 6-mo % with self-report of newly dx STI N, % at baseline, % mean, p [underlined: IG:] 123, 10%, 2% [underlined: CG1:] 121, 8%, 8%, p<0.013 [underlined: CG2:] 110, 7%, 5%, p<0.046 p values adjusted for STI at baseline, (odds ratios are not reported) | Mean # of UVI acts in past 3 mo 3-mo N, Mean # UVI [underlined: IG:] 123, 9.5 [underlined: CG1:] 121, 8.1 [underlined: CG2:] 110, 10.0 6-mo N, Mean # UVI [underlined: IG:] 123, 7.2 [underlined: CG1:] 121, 8.8 [underlined: CG2:] 110, 8.0 (p values for condition × time interaction effects) IG vs. CG1: p=0.001 IG vs. CG2:p=0.004 | N | mean # of partners in past 3 mo (p values for condition × time interaction effects) 3-mo N, mean # partners [underlined: IG:] 123, 0.93 [underlined: CG1:] 121, 1.02 [underlined: CG2:] 110, 1.12 6-mo [underlined: IG:] 123, 0.97 [underlined: CG1:] 121, 0.95 [underlined: CG2:] 110, 0.07 (p values for condition × time interaction effects) IG vs. CG1:, p=0.339 IG vs. CG2:, p=0.037 mean # of casual partners in past 3 mo 3-mo N, mean # partners [underlined: IG:] (n=123); 0.21 [underlined: CG1:](n=121); 0.33 [underlined: CG2:](n=110); 0.47 6-mo N, mean # partners [underlined: IG:] 123, 0.30 [underlined: CG1:] 121, 0.30 [underlined: CG2:] 110, 0.48 (p values for condition × time interaction effects) IG vs. CG1: p=0.015 IG vs. CG2: p=0.001 | N | N | No increase in number of sex partners No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self-report) | N (only reported on knowledge, attitudes and skills) | generalizability best for those in treatment with mental health conditions $10 for each intervention session to offset travel expenses
Shain 2004 ^17^ Project SAFE 2 Fair | RCT TX; urban PHC- (STI clinic) Hispanic and African American women; non-viral STI positive | Inclusion: age 15–45, women, nonviral STI, English speaking Exclusion: if <18 and used ‘hard’ drugs and dropped out of school | N Randomized Total: 690, data for those with f/u at years 1 and 2 (N=775 originially randomized) [underlined: IG1:] 209 [underlined: IG2:] 232 [underlined: CG:] 249 Age [underlined: IG1:] 20.4 [underlined: IG2:] 20.8 [underlined: CG:] 21.6 % Male Total: 0% Race [underlined: % Hispanic] [underlined: IG1:] 73.7% [underlined: IG2:] 81.9% [underlined: CG:] 74.7% [underlined: % African American] [underlined: IG1:] 26.3% [underlined: IG2:] 18.1 % [underlined: CG:] 25.3% SES [underlined: Annual Income per capita] [underlined: IG1: $] 3852 [underlined: IG2:] $3348 [underlined: CG:] $3720 [underlined: Education (yr)] [underlined: IG1:] 10.8 [underlined: IG2:] 10.5 [underlined: CG:] 10.8 STI risk % with STI (current) GC IG1: 21.1%, IG2: 22.8%, CG: 18.1% Chlamydia IG1: 78.5%, IG2: 82.3%, CG: 73.1% Trichomonas IG1: 16.7%, IG2: 11.6%, CG: 17.7% Syphilis IG1: 2.9%, IG2: 3.9%, CG: 6.8% % with multiple partners in past year IG1: 63.5% IG2: 64.0% CG: 66.5% | Cultural and sex specific adaptation of AIDS Risk Reduction Model (ARRM) | Intervention [underlined: IG1:] CG standard counseling plus multicomponent sessions including discussions, games, video, behavior modeling and role play (see previous Project SAFE) [underlined: IG2:] CG standard counseling plus IG1 intervention with the option of attending 5 monthly support group sessions [underlined: CG:] Standard counseling by CDC guidelines Format [underlined: IG1:] Small group (not specified) [underlined: IG2:] Small group (not specified) [underlined: CG:] Individual Intensity IG1: Three sessions, 3 hours, 1× week for 3 consecutive weeks [underlined: IG2:] Three sessions, 3 hours, 1× week for 3 consecutive weeks, plus option of attending 5 monthly support group sessions of unspecified duration [underlined: CG:] One 15 minute session Delivery [underlined: IG1:] Trained female faciliator, matched ethnicity [underlined: IG2:] Trained female faciliator, matched ethnicity [underlined: CG:] Nurse Clinician | F/U Time 1 year, 2 year retention rates % F/U [underlined: 1 year] 91.4% Biological outcomes: 91.4% [underlined: IG1:] 92.4% [underlined: IG2:] 90.1% [underlined: CG:] 92.8% [underlined: 2 year] 91.2% Biological outcomes: 90.7% [underlined: IG1:] 89.9% [underlined: IG2:] 90.8% [underlined: CG:] 92.8% | % with episodes of reinfection (with gonorrhea, chlamydia, or both) 1-year [underlined: IG1:] 25.1%(55/219) [underlined: IG2:] 20.3%(48/236) [underlined: CG:] 26.8%(68/254) 2-year [underlined: IG1:] 18.5% (39/211) [underlined: IG2:] 20.7% (49/237) CG: 23.1% (59/255) adjusted infection rate, adjusting for age, ethnicity, education, exposure time, and substance abuse risk 1-year [underlined: IG1:] 15.7%, p=0.006 [underlined: IG2:] 15.4%, p=0.004 [underlined: CG:] 26.8% 2-year IG1=14.7%, p=0.03 IG2=14.8%, p,0.03 CG=23.1% odds ratio of those with recurrent STI, adjusting for age, ethnicity, education, exposure time, and substance abuse risk 1-year [underlined: IG1:] 0.51 (0.31–0.83) [underlined: IG2]: 0.50 (0.31–0.80) 2-year IG1: 0.57 (0.34–0.96) IG2: 0.58 (0.36–0.94) | NR (outcomes were collected) | N | % reporting multiple partners (more than 1) over past year 1-year IG1: 42.5%, p=0.001 IG2: 43.2%, p=0.01 CG: 55.3% 2-year IG1: 37.6%, p<0.005 IG2: 36.2%, p<0.002 CG: 50.8% | N | % with unprotected sex with untreated or incompletely treated partner (year 1 only) IG1: 7.8%, p=0.001 IG2: 10.2%, p=0.01 CG: 18.1% | No increase in number of sex partners No increase in STI incidence (by testing) | N (other than compliance, see other behavioral outcomes) | intervention was tailored by extensive gathering of qualitative data in target communities done in research clinic incentive $15–25 per session
Scholes 2003 ^15^ Fair | RCT WA, NC; NR Managed care practice Young adult women; non-mongamous sexually active | Inclusion: Clinic visit in past 6-mo; Unmarried, sexual intercourse with male partner in last 6 mo Exclusion: Pregnant, in monogamous relationship > 12-mo | N Randomized Total: 1210 [underlined: IG:] 596 [underlined: CG:] 614 Age Total: 21 [underlined: IG:] 21 [underlined: CG:] 21 % male 0 Race [underlined: %African American] Total: 19% [underlined: IG:] 19% [underlined: CG:] 19% [underlined: %Other] Total: 12% [underlined: IG:] 12% [underlined: CG:] 12% SES Employed fulltime Total: 42% [underlined: IG:] 42% [underlined: CG:] 43 % STI risk [underlined: % with hx/dx of STI] Total: 27% [underlined: IG:] 27% [underlined: CG:] 26% [underlined: Proportion unprotected sex (c)] Total: 46% IG: 46% CG: 45% [underlined: % multiple partners in past year] Total: 18% IG: 17% CG: 19% | Tailored minimal self-help intervention, based in multiple social science theories (e.g., transtheoretical model, AIDS risk-reduction, theory of reasoned action), designed to increase condom use | Intervention [underlined: IG:] tailored self-help intervention consisting of two rounds of individually tailored materials - a 12-page self-help magazine-style booklet (which included male and female condoms, a condom carrying case and instructions on using condoms) and a tailored booster feedback newsletter, send after the 3-mo survey. [underlined: CG:] Usual Care (not specified) Format [underlined: IG:] Print [underlined: CG:] NR Intensity [underlined: IG:] 2 sets of tailored materials - one after baseline and the 2nd after the 3 mo survey [underlined: CG:] NR Delivery [underlined: IG:] Self-administered [underlined: CG:] NR | F/U Time 3 mo (not reported separately); 6 mo (reported separately and combined w 3-mo) % F/U 3-mo [underlined: IG:] 91% [underlined: CG:] 87% 6-mo [underlined: IG:] 88% [underlined: CG:] 85% | 6-mo % with self reported STI dx in past 3 mo Mean%, [underlined: IG:] 3.5% [underlined: CG:] 3.6% OR unadjusted 0.95 (0.49, 1.83) OR adjusted 0.97 (0.48, 1.96), p=0.93 | | 6-mo % with ANY use of condoms in past 3mo IG: 72.8% CG: 63.0% OR unadjusted 1.57 (1.18, 2.10) OR adjusted 1.86 (1.32, 2.65), p=0.0005 % with CONSISTENT use of condoms in past 3mo IG: 33.5% CG: 36.8% OR unadjusted 1.16 (0.87, 1.54) OR adjusted 1.24 (0.89, 1.73), p=0.21 | N | N | N | No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self report) | N (only reported on knowledge, attitudes and skills) | research conducted in two managed care plans incentives: 30 min phone card for 3-mo survey; $10 for completion of 6-mo survey
Ehrhardt 2002 ^22^ Hoffman 2003 ^61^ Project FIO Good | RCT Brooklyn, NY; urban Planned Parenthood clinic adult heterosexual women | Inclusion: clients of the clinic, age 18–30; fluent comprehension of English; heterosexual activity within prior year Exclusion: Blood transfusion 1980-1985; IVDU in past year; HIV+; pregnant or trying to get pregnant | N Randomized Total:360 IG1: 128 IG2: 112 CG: 120 Age Total: 22.3 % Male 0 Race [underlined: Total] %African American: 72.5% %Hispanic: 16.9% SES [underlined: Total] Below poverty line:26% mean 12.8 years of education median per capita income $6057 STI risk % with hx of STI: 58.3% frequency unprotected sex acts in past 3 mo: 17.23 % with multiple partners in past 3 mo: 23.4% For subgroup analysis % with reported recent intimate partner physical violence= 42% | AIDS Risk Reduction Model (ARRM) Goals: (1) increase knowledge; (2) improve communication and decision-making; (3) identify/modify risk factors and antecedents | Intervention [underlined: IG1:] 4 week STD/HIV prevention intervention [underlined: IG2:] 8-week STD/HIV prevention intervention [underlined: CG:] Assessment only Format [underlined: IG1:] Group [underlined: IG2:] Group [underlined: CG:] N/A Intensity [underlined: IG1:] Four 2 hour sessions + 1 booster session at 9 months [underlined: IG2:] Eight 2 hours sessions + 1 booster session at 9 months [underlined: CG:] N/A Delivery [underlined: IG1:] NR [underlined: IG2:] NR [underlined: CG:] N/A | F/U Time 6-mo; 12-mo %F/U [underlined: 6-mo] [underlined: IG1:] 95% [underlined: IG2:] 89% [underlined: CG:] 87% [underlined: 12-mo] [underlined: IG1:] 96% [underlined: IG:] 98% [underlined: CG:] 96% | N | 12-mo ‘model predicted’ mean # unprotected acts in past 3 mo text reads IG2 had on average 4 fewer UVI/UAI than control, p=0.00 % maintaining or improving safer sex behavior (proportion decreasing number of unprotected acts or maintaining no unprotected acts) [underlined: IG1:] 66.4% [underlined: IG2:] 72.7% [underlined: CG:] 61.7% adjusted OR (IG2 to CG) 1.65 (0.94, 2.90) | 12-mo % using condom (male/female) in past 3-mo [underlined: IG1:] NR [underlined: IG2:] 18% increase, p=0.06 [underlined: CG:] NR | N | N | Alternative risk reduction strategy (# sex occasions; outercourse; refusing sex; leaving relationship; choosing not to get involved with new partner; mutual HIV testing) at 12 mo text states no difference between groups at 12-mo f/u | No increase in unprotected sex or decrease in condom use | N (other than alternative risk reduction strategies and communication skills)
Melendez 2003 ^47^ Project FIO Fair | | Inclusion: report of recent intimate partner violence in past 12 months on baseline assessement | N Randomized Total:152 Age Total: 23 Race [underlined: Total] %African American: 75% %Hispanic: 21% SES [underlined: Total] Below poverty line:37% STI risk % with hx of STI: 75% | | | | | 6-mo % maintaining or improving safer sex behavior (proportion decreasing number of unprotected acts or maintaining no unprotected acts) IG1: 64% IG2: 74% CG: 64% adjusted OR (IG2 to CG) 1.63 (0.68, 3.89) 12-mo % maintaining or improving safer sex behavior (proportion decreasing number of unprotected acts or maintaining no unprotected acts) IG1: 69% IG2: 82% CG: 61% adjusted OR (IG2 to CG) 2.88 (1.17, 7.10) | | | | 6-mo % using alternative strategy (defined above) IG1: 17% IG2: 25% CG: 12% adjusted OR (IG2 to CG) 2.70 (0.90, 8.14) 12-mo % using alternative strategy (defined above) IG1: 23% IG2: 19% CG: 25% adjusted OR (IG2 to CG) 0.71 (0.26, 1.90) | | | Unclear if subgroup analysis specified a priori
Shain 1999 ^16^ Project SAFE (named in subsequent article) Good | RCT TX; urban PHC- (STI clinic) Hispanic and African American women; non-viral STI positive | Inclusion: Women, ages 15–45, nonviral STI, English speaking Exclusion: NR | N Randomized Total: 617 (n=549 in analysis) [underlined: IG:] 313 (n=285), [underlined: CG:] 304 (n=264) Age [underlined: IG:] 21.8, [underlined: CG:] 21.3 % Male 0 Race [underlined: %Hispanic] [underlined: IG:] 69.8 [underlined: CG:] 68.2 [underlined: %African American] [underlined: IG:] 30.2, [underlined: CG:] 31.8 SES [underlined: Mo Income per capita] [underlined: IG:] 243 [underlined: CG:] 267 [underlined: Education (yr)] [underlined: IG:] 10.8, [underlined: CG:] 10.8 STI risk [underlined: % with STI (current)] GC [underlined: IG:] 21.4%, [underlined: CG:] 20.8% Chlamydia [underlined: IG:] 67.0%, [underlined: CG:] 70.5% Trichomonas [underlined: IG:] 26.3%, [underlined: CG:] 20.8% Syphilis [underlined: IG:] 6.0% [underlined: CG:] 6.1% # sex partners in past 3 mo [underlined: IG:] 1.57 [underlined: CG:] 1.37 % pregnant [underlined: IG:] 27.2% [underlined: CG:] 33.3% | Cultural and sex specific adaptation of AIDS Risk Reduction Model (ARRM) | Intervention [underlined: IG:] Behavioral cognitive multicomponent sessions-discussions, games, videotape, behavior modleing, and role play (see Table 1) [underlined: CG:] Standard counseling by CDC guidelines Format [underlined: IG:] Small group (3–12 participants) [underlined: CG:] Individual Intensity [underlined: IG:] Three sessions, 3–4 hours each, 1× week for 3 consecutive weeks [underlined: CG:] One 15 minute session Delivery [underlined: IG:] Trained female facilitator; matched ethnicity [underlined: CG:] Nurse clinician | Time Frame 6-mo; 12-mo % F/U [underlined: 6-mo] [underlined: IG:] 84%, [underlined: CG:] 80% [underlined: 12-mo] [underlined: IG:] 91%, [underlined: CG:] 87% [underlined: Total f/u at both 6 and 12mo] [underlined: IG:] 79.6% [underlined: CG:] 75.0% Korte 2004 [underlined: 6-mo] 100% (b/c excluded those lost to f/u not included in analyses) | % with # episodes of infection (with gonorrhea, chlamydia, or both) during 12 mo study period p=0.01 between group assignments [underlined: IG] zero infections: 83.2% (237/285) one infection: 11.2% (32/285) two or more infections:5.6% (16/285) [underlined: CG] zero infections: 73.1% (193/264) one infection: 19.3% (51 /264) two or more infections: 7.6% (20/264) % or odds ratio of those with recurrent STI 6-mo [underlined: IG:] 11.3% (30/265) [underlined: CG:] 17.2% (42/244) odds ratio (controlled for age and number of sex partners preceeding enrollment) OR: 0.58 (0.34–0.99), p=0.05 12-mo [underlined: IG:] 16.8% (48/285) [underlined: CG:] 26.9% (71/264) OR: 0.52 (0.34–0.81), p=0.004 | N | N | N | N | # sex occasions; outercourse; refusing sex; leaving relationship; choosing not to get involved with new partner; mutual HIV testing | No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self report) | N (other than compliance, see other behavioral outcomes) | intervention was tailored by extensive gathering of qualitative data in target communities done in research clinic incentive $15–25 per session
Korte 2004 ^27^ Project SAFE Fair | | Inclusion: subset analyses of 477 women who attended all 3 study visits (for reinfection rates do report on 549 women) Exclusion: NR | N Randomized Total: 477 (or for reinfection rates n=549) [underlined: IG:] 249 [underlined: CG:] 228 Age age band reported by ethnicity % men 0 Race [underlined: % African American (calculated)] [underlined: IG:] 30.1% [underlined: CG:] 32.5% [underlined: % Hispanic (calculated)] [underlined: IG:] 69.9% [underlined: CG:] 67.5% SES Reported by ethnicity STI risk see Shain | | | | GC/chalmydia testing 12-mo % with reinfection over 12 mo (entire study period) [underlined: African American] [underlined: IG:] 23.3% (20/86) [underlined: CG:] 34.5% (29/84) p=0.10 [underlined: Hispanic] [underlined: IG:] 14.1%(28/199) [underlined: CG:] 23.3% (42/180) p=0.02 | N | N | 12-mo % reporting multiple partners [underlined: African American] [underlined: IG:] 61.3%(46/75) [underlined: CG:] 78.4%(58/74) p=0.02 [underlined: Hispanic] [underlined: IG:] 49.4%(86/174) [underlined: CG:] 54.5%(84/154) p=0.35 | N | 12-mo % non-compliant (sex with untreated or incompletely treated partner) over past year [underlined: African American] [underlined: IG:] 8.0%(6/75) [underlined: CG:] 13.5%(10/74) p=0.28 [underlined: Hispanic] [underlined: IG:] 10.9%(19/174) [underlined: CG:] 18.2%(28/154) p=0.06 | No increase in number of sex partners No increase in unprotected sex or decrease in condom use No increase in STI incidence (by testing) | N (only reported communication skills) | unclear if powered to look at differences between ethnic groups
Kamb 1998 ^14^ Project RESPECT Fair | RCT MD, CO, CA, NJ; urban Public STD clinics General heterosexual population attending STI clinics | Inclusion: Ages 14 and over; agree to have HIV test, English speaking Exclusion: men who had male sexual partner in past 12 mo or who self-identified as bi- or homo-sexual | N Randomized Total: 5758 [underlined: IG1:] 1438 [underlined: IG2:] 1447 [underlined: CG1]: 1443 [underlined: CG2]: 1430 Age (median age) Total: 25 % Male Total: 57% Race [underlined: Total] %African American: 59% %Hispanic: 19% %White: 16% %Other: 6% SES [underlined: Total] Annual income <$5000: 42% Unemployed: 54% STI risk % with STI (current) [underlined: IG1:] 33% [underlined: IG2:] 31% [underlined: CG1:] 30% [underlined: CG2:] 33% # sex partners in past 3 mo [underlined: IG1:] 2.1 [underlined: IG2:] 2.3 [underlined: CG1:] 2.5 [underlined: CG2:] 2.4 | Various risk reduction counseling models (IG) versus didactic (CG) [underlined: IG1:] Enhanced, based on theory of reasoned action and social cognitive theory. [underlined: IG2:] CDC's client centered HIV prevention counseling model. [underlined: CG1 & CG2:] Didactic messages (informational only); CG2 had no scheduled f/u | Intervention [underlined: IG1:] Four sessions, included behavioral goal setting, delivery of test results, formulating a risk -reduction plan [underlined: IG2:] Two same components as in IG1 but in 2 brief sessions [underlined: CG1 and CG2:] Two very brief didactic sessions, didactic prevention messages pertinent to their reported risks, and delivery of test results Format [underlined: IG1:] Individual [underlined: IG2:] Individual [underlined: CG1 and CG2:] Individual Intensity [underlined: IG1:] Four sessions, total of 200 mintes, completed over 3–4 wks [underlined: IG2:] Two sessions, total 40 minutes over 7–10 days [underlined: CG1 and CG2:] Two sessions, total 10 minutes over 7–10 days Delivery [underlined: IG1:] Trained counselors [underlined: IG2:] Trained counselors [underlined: CG1 and CG2:] Clinicians for session 1, counselor for session 2 | F/U Time 3-mo; 6-mo; 9-mo; 12-mo for IG1; IG2; CG1. CG2 N/A % F/U 3-mo: 71%; 6-mo: 70%, 9-mo: 64%, 12-mo: 66% (follow up not reported for each IG, but in text stated no significant difference in f/u between groups) | GC/chalymdia, syphillis, HIV mean % testing positive for new STI 6-mo [underlined: IG1:] 7.2%; RR 0.69 (0.54–0.88) [underlined: IG2:] 7.3%; RR 0.71 (0.58–0.89) [underlined: CG1:] 10.4% 12-mo [underlined: IG1:] 11.5%; RR=0.78 (0.64–0.94) [underlined: IG2:] 12.0%; RR=0.81 (0.67–0.98) [underlined: CG1:] 14.6% | mean % no unprotected sex, consistent (100%) condom use (and relative risk to CG1) 3-mo IG1: 46%; RR=1.21 (1.09–1.35) IG2: 44%; RR=1.15 (1.03–1.27) CG1: 38% 6-mo IG1: 39%; RR 1.14 (1.01–1.28) IG2: 39%; RR 1.12 (1.00–1.25) CG1: 34% 9 and 12 mo no sig difference, numbers not reported | mean % reporting any condom use 3-mo [underlined: IG1:] 83%, p<0.05 [underlined: IG2:] 79% [underlined: CG1:] 76% 6-mo [underlined: IG1:] 78%, p<0.05 [underlined: IG2:] 73% [underlined: CG1:] 73% | % with 2 or more sex partners over past 3 mo (c) 3-mo [underlined: IG1:] 29%, p<0.05 [underlined: IG2:] 28%, p<0.05 [underlined: CG1:] 34% 6-mo [underlined: IG1:] 30% [underlined: IG2:] 30% [underlined: CG1:] 34% % with casual partners (c) 3-mo [underlined: IG1:] 30% [underlined: IG2:] 27%, p<0.05 [underlined: CG1:] 34% 6-mo [underlined: IG1:] 31% [underlined: IG2:] 30% [underlined: CG1:] 34% | N | N | No increase in number of sex partners No increase in unprotected sex or decrease in condom use No increase in STI incidence (by testing) | N (only reported communication skills)
Bolu 2004 ^21^ Project RESPECT Fair | | | | | | | GC/chalymdia, syphillis, HIV mean % with newly dx STI, (adjusted) risk ratios for dx of new STI [underlined: Adolescents (<20)] [underlined: IG1:] 17.2%; RR 0.57 (0.37–0.90) [underlined: IG2:] 17.5%; RR 0.58 (0.37–0.92) [underlined: CG1:] 26.6% [underlined: Young adults (20–25)] [underlined: IG1:] 13.1%; RR 0.82 (0.56–1.2) [underlined: IG2:] 13.8%; RR 0.91 (0.62–1.3) [underlined: CG1:] 14.8% [underlined: Adults (>25)] [underlined: IG1:] 8.3%; RR 0.79 (0.54–1.16) [underlined: IG2:] 8.7%; RR 0.78 (0.53–1.13) [underlined: CG1:] 10.1% [underlined: Male] [underlined: IG1:] 11.4%; RR 0.73 (0.53–1.01) [underlined: IG2:] 12.6%; RR 0.76 (0.56–1.04) [underlined: CG1:] 14.3% [underlined: Female] [underlined: IG1:] 11.6%; RR 0.76 (0.53–1.08) [underlined: IG2: 1]1.1%; RR 0.73 (0.51–1.04) [underlined: CG1:] 15.0% | N | N | N | N | N | No increase in STI incidence (by testing) | N
Gottlieb ^36^ 2004 Project RESPECT Fair | | Inclusion: Agree to have HIV test, English speaking Exclusion: HSV2 seropositive or clinical dx of herpes, study participants who did not f/u with serologic testing | N Randomized Total: 1766, Age(median) Total: 24 % Male Total: 63 Race % African American: 52% STI risk see Kamb | | | | GC/chalmydia, HSV incident HSV per 100py 12-mo [underlined: IG1:] 10.3/100py; HR=0.80 (0.6–1.1) [underlined: IG2:] 11.8/100py; HR=0.9 (0.7–1.3) [underlined: CG1:] 12.9/100py | | N | N | N | N | No increase in STI incidence (by testing- HSV only) | N
Boyer 1997 ^12^ Fair | RCT San Francisco, CA; urban Public Health STD clinic Heterosexual adults with either: (1) previous STD, (2) current symptoms of STD, (3) sexual contact with person diagnosed with STD | Inclusion: Attended specific public health STD clinic; age 18–35; heterosexual; residing in S.F.; high risk (previous STD;current symptoms of STD; sexual contact with person diagnosed with STD) Exclusion: non-English speaking; attending clinic for follow-up exam | N Randomized Total:393 Age 18–35 %male Total: 67 (c) Race [underlined: Total] %African American: 46% %Hispanic: 15% %Caucasian: 29% %Other: 10% SES NR STI Risk % with hx of STI: 62% (c) | AIDS Risk Reduction Model (ARRM) Goals: Increase knowledge; improve communication and decision-making; identify/modify risk factors and antecedents | Intervention Arms [underlined: IG:] risk assessment, video, written and verbal information, condoms and anatomical model, and interactive discussion to achieve goals of ARRM model. [underlined: CG:] standardized risk-reduction counseling Intervention format [underlined: IG:] Individual, in-person [underlined: CG:] Individual, in-person Intensity [underlined: IG:] Four 60-min sessions over 4 wks [underlined: CG:] One 15-min session Delivery [underlined: IG:] Trained counselors [underlined: CG:] Trained counselors | F/U Time 3-mo; 5- mo; assessed at any unscheduled visits at clinic within 6-mo of baseline interview % F/U [underlined: IG:] 67% [underlined: CG:] 75% | chlamydia, gonorrhea, syphilis, trichomoniasis, HIV, HSV, HPV, BV 6-mo % with New/Probable STI [underlined: Male] IG: 6.8% (8/118) CG: 7.0% (10/143) [underlined: Female] IG: 21.8% (17/78) CG: 22% (11/50) | # UVI in past 2 mo (mean # UVI, N) 3-mo [underlined: Male] [underlined: IG:] 8.6, 66 [underlined: CG:] 11.0, 96 [underlined: Female] [underlined: IG:] 5.6, 56 [underlined: CG:] 9.7, 40 5-mo [underlined: Male] [underlined: IG:] 9.1, 62 [underlined: CG:] 10.8, 94 [underlined: Female] [underlined: IG:] 6.2, 59 [underlined: CG:] 12.9, 39 | Mean sex with condom past 2 mo (mean %, N) 3-mo Male* IG: 56%, 66 CG: 42.3.0%, 96 *=p<0.05 at 3-mo Female IG: 52.9%, 56 CG: 48.9%, 40 5-mo Male IG: 52.4%, 62 CG: 44.5%, 94 Female IG: 43.3%, 59 CG: 45.1%, 39 | # sex partners w/o condom use, in past 2 mo (mean # sex partners, N) 3-mo [underlined: Male] [underlined: IG:] 0.8, 66 [underlined: CG:] 0.9, 96 [underlined: Female] [underlined: IG:] 0.8, 56 [underlined: CG:] 0.7, 40 5-mo (*=p<0.01 for men at 5mo) [underlined: Male] [underlined: IG:] 0.6, 62 [underlined: CG:] 0.9*, 94 [underlined: Female] [underlined: IG:] 0.8, 59 [underlined: CG:] 0.7, 39 | N | N | No increase in unprotected sex acts. No increase in STI incidence (by self-report) No increase in number of sex partners | N (only reported on knowledge, attitudes and skills) | high rate of refusal to participate in study $20 for baseline, $25 for 3-mo, $30 for 5-mo assessments
Wenger 1992 ^24^ Fair | RCT CA University Health Clinic Heterosexual adults; university students | Inclusion: Student seeking care at university health clinic, 18 or older, literate in English, able to give informed consent Exclusion: men who self-identified as homo/bi-sexual | N Randomized Total: 370 [underlined: IG1:] 144 [underlined: IG2:] 136 [underlined: CG:] 90 Age Total: 23 [underlined: IG1:] 22 [underlined: IG2:] 23 [underlined: CG:] 23 % Male Total: 28% [underlined: IG1:] 28% [underlined: IG2:] 31% [underlined: CG:] 22% Race [underlined: % white,] Total: 61% [underlined: IG1:] 58% [underlined: IG2:] 58% [underlined: CG:] 69% SES NR STI risk % with STI (ever) Total: 23% [underlined: IG1:] 20% [underlined: IG2:] 25% [underlined: CG:] 26% median # of lifetime sexual partners Total: 4 [underlined: IG1:] 4 [underlined: IG2:] 4 [underlined: CG:] 4 | NR | Intervention [underlined: IG1:] Education only [underlined: IG2:] Education plus HIV testing education consisted of video, lecture, role-play, discussion, and distribution of written material [underlined: CG:] No further participation until f/u questionnaire offered a list of locations for free, anonymous HIV Ab testing Format IG: Small group (mean 8 students) [underlined: CG:] N/A Intensity [underlined: IG:] One session, approx 1 hour [underlined: CG:] N/A Delivery [underlined: IG:] MD [underlined: CG:] N/A | F/U Time 6 mo. % F/U [underlined: IG1:] 91%, [underlined: IG2:] 90%, [underlined: CG:] 81% | N | % with UVI/UAI with last sex partner 6-mo [underlined: IG1:] 68% [underlined: IG2:] 63% [underlined: CG:] 61% p>0.15 | N | mean number sex partners in last mo 6-mo [underlined: IG1:] 0.70 [underlined: IG2:] 0.84 [underlined: CG:] 0.72 p>0.15 | N | N | No increase in number of sex partners No increase in unprotected sex or decrease in condom use | NR (only reported on communication skills)
Proude 2004 ^23^ Fair | RCT Australia; urban (implied) FP practices Young adults | Inclusion: (inclusion criteria for FP recruitment not specified); patient at participating FP practice, age 18–25 years, sufficient levels of English Exclusion: NR | N Randomized Total: 312 [underlined: IG:] 156 [underlined: CG:] 156 Age median age NR % Age 18–21, [underlined: IG:] 47% [underlined: CG:] 485% Age 22–25 [underlined: IG:] 53% [underlined: CG:] 52% % Male [underlined: IG:] 29 [underlined: CG:] 28 Race NR SES % equivalent of HS graduate [underlined: IG:] 68% [underlined: CG:] 67% STI risk % with multiple partners in past year IG: 14% CG: 14% | NR | Intervention [underlined: IG:] Behavioral advice based on brief risk assessment, and resources including- condoms, educational pamphlets on condom use, STIs and HIV, hep B (including on vaccination), alcohol and drug info services [underlined: CG:] Tobacco screening/counseling Format [underlined: IG:] Individual [underlined: CG:] Individual Intensity [underlined: IG:] One session, unspecified duration (‘brief’) [underlined: CG:] One session, unspecified duration Delivery [underlined: IG:] MD [underlined: CG:] MD | F/U Time 3-mo % F/U (agreed to f/U) [underlined: IG:] 66% (74%) [underlined: CG:] 69% (78%) | N | N | % with condom use on first sex occasion with new partner 3-mo [underlined: IG]: 73%(8/11) [underlined: CG]: 77%(10/13) p=0.813 | new sex partners over past 3 mo (c) [underlined: IG1]: 11/156 [underlined: CG]: 13/156 | N | N | No increase in number of sex partners No increase in unprotected sex or decrease in condom use | N (only reported on communication skills) | in Australia
Adolescent, Sexually Active
Jemmott 2005 ^20^ Good | RCT PA; urban Adolescent medicine clinic Sexually active African American and Hispanic girls | Inclusion: African-American or Hispanic; patients of adolescent clinic; sexually experienced; Ages 12–19; read and speak English Exclusion: Pregnant; planned on moving out of area | N Randomized Total: 682 [underlined: IG1:] 235 [underlined: IG2:] 228 [underlined: CG]: 219 Age [underlined: IG1:] 15.53 [underlined: IG2:] 15.49 [underlined: CG:] 15.52 % male Total: 0 Race [underlined: %African American] [underlined: IG1:] 68.1 [underlined: IG2:] 68 [underlined: CG:] 67.6 [underlined: %Hispanic] [underlined: IG1:] 31.9 [underlined: IG2:] 32.0 [underlined: CG:] 32.4 SES NR STI risk [underlined: % with STI (current)] [underlined: IG1:] 22.8 [underlined: IG2:] 26.0 [underlined: CG:] 16.9 [underlined: % sexually active in past 3 mo] [underlined: IG1:] 85.6 [underlined: IG2:] 85.8 [underlined: CG:] 89.9 [underlined: # days unprotected sex in past 3 mo] IG1: 2.52 IG2: 3.22 CG: 3.02 [underlined: % with multiple partners in past 3 mo] IG1: 12.3% IG2: 18.9% CG: 16.4% | Culturally and developmentally appropriate interventions based on cognitive behavioral theories | Intervention [underlined: IG1:] Skills based HIV/STD risk reduction [underlined: IG2:] Information based HIV/STD risk reduction [underlined: CG:] Health promotion control that covered beliefs and skills relevant to behavior associatiated with risk of heart disease, cancse and stroke Format [underlined: IG1:] small group (2–10 participants); (groups discussions, videotapes, games, experiential excercises) [underlined: IG2:] small group (2–10 participants); (groups discussions, videotapes, games, experiential excercises) [underlined: CG:] small group (2–10 participants); (groups discussions, videotapes, games, experiential excercises) Intensity [underlined: IG1:] One session, 250 minutes [underlined: IG2:] One session, 250 minutes [underlined: CG:] One session, 250 minutes Delivery [underlined: IG1:] bachelors-level facilitator (African American females) with experience working with inner-city adolescents [underlined: IG2:] bachelors-level facilitator (African Americn females) with experience working with inner-city adolescents [underlined: CG:] bachelors-level facilitator (African American females) with experience working with inner-city adolescents | F/U Time 3 mo, 6 mo, 12 mo % F/U [underlined: 3 mo] Overall: 94.3% [underlined: IG1:] 96% (calc all subgroup rates) [underlined: IG2:] 92% [underlined: CG:] 95% [underlined: 6 mo] Overall: 92.8% [underlined: IG1:] 94% (calc all subgroup rates) [underlined: IG2:] 90% [underlined: CG:] 94% [underlined: 12 mo] Overall: 88.6% [underlined: IG1:] 89% (calc all subgroup rates) [underlined: IG2:] 86% [underlined: CG:] 91% | GC, Chlamydia, Trich. mean % testing positive for STI 6-mo Unadjusted %, Adjusted % [underlined: IG1:] 15.5%, 15.8%, p=0.80 [underlined: IG2:] 16.0%, 15.5%, p=0.89 [underlined: CG:] 14.6%, 14.8% 12-mo Unadjusted %, Adjusted % [underlined: IG1:] 10.8%, 10.5%, p=0.05 [underlined: IG2:] 16.0%, 14.4%, p=0.44 [underlined: CG:] 17.4%, 18.2% | mean # days of sex w/o condom use in past 3 mo 3-mo Unadjusted, Adjusted [underlined: IG1:] 3.66, 3.71, p=0.95 [underlined: IG2:] 3.83, 3.56, p=0.89 [underlined: CG:] 3.52, 3.46 6-mo Unadjusted, Adjusted [underlined: IG1:] 2.99, 2.88, p=0.66 [underlined: IG2:] 3.17, 2.60, p=0.43 [underlined: CG:] 3.47, 3.26 12-mo Unadjusted, Adjusted [underlined: IG1:] 2.80, 2.27, p=0.002 [underlined: IG2:] 5.04, 4.04, p=0.32 [underlined: CG:] 5.73, 5.05 | N | mean % reporting multiple partners in past 3-mo 3-mo Unadjusted, Adjusted [underlined: IG1:] 10.7%, 10.9%, p=0.29 [underlined: IG2:] 15.8%, 15.1%, p=0.76 [underlined: CG:] 14.9%, 14.2% 6-mo Unadjusted, Adjusted [underlined: IG1:] 9.5%, 9.7%, p=0.12 [underlined: IG2:] 13.2%, 12.5%, p=0.54 [underlined: CG:] 15.1%, 14.3% 12-mo Unadjusted, Adjusted [underlined: IG1:] 7.4%, 6.9%, p=0.002 [underlined: IG2]: 11.4%, 10.7%, p=0.09 [underlined: CG:] 17.5%, 16.6% | N | mean # of days of sex while intoxicated past 3 mo 3-mo Unadjusted, Adjusted [underlined: IG1:] 0.11, 0.10, p=0.03 [underlined: IG2:] 0.35, 0.29, p=0.98 [underlined: CG:] 0.29, 0.26 6-mo Unadjusted, Adjusted [underlined: IG1:] 0.10, 0.07, p=0.005 [underlined: IG2:] 0.20, 0.15, p=0.10 [underlined: CG:] 0.36, 0.31 12-mo [underlined: IG1:] 0.32, 0.42, p=0.37 [underlined: IG2:] 0.55, 0.53, p=0.65 [underlined: CG:] 0.65, 0.66 | No increase in number of sex partners No increase in unprotected sex or decrease in condom use No increase in STI incidence (by testing) | N (only reported on knowledge, attitudes and skills) | research role: 8-hr facilitator training Incentives: up to $120 for completing study
DiClemente 2004 ^19^ Good | RCT GA, urban Community health agencies Sexually active, African American girls | Inclusion: 14–18y, African American, female, sexually active (vaginal intercourse past 6mo) Exclusion: NR | N Randomized Total: 522 [underlined: IG:] 251 [underlined: CG:] 271 Age [underlined: IG:] 15.99 [underlined: CG:] 15.97 % Male Total: 0% Race % African American: 100% SES [underlined: Recipient of public assistance] [underlined: IG:] 17.9% [underlined: CG:] 18.5% [underlined: Education % did not complete 10th grade] [underlined: IG:] 45.8 [underlined: CG:] 48.7 STI risk [underlined: % with STI (current)] GC [underlined: IG:] 5.6% [underlined: CG:] 4.8% Chlamydia [underlined: IG:] 19.2% [underlined: CG:] 15.9% Trichomonas [underlined: IG1:] 13.4% [underlined: CG:] 12.4% [underlined: Frequency unprotected sex in past 6 mo] [underlined: IG:] 4.81 [underlined: CG:] 4.23 [underlined: % with new partner in past 30 days] [underlined: IG:] 4.4% [underlined: CG:] 7.4% | Social cognitive theory and theory of gender and power as a basis for HIV prevention intervention; culturally tailored | Intervention [underlined: IG:] Multicomponent sessions including discussions, behavior modeling and role play [underlined: CG:] Multicomponent sessions on nutrition and exercise Format [underlined: IG:] Small group (10–12 participants) [underlined: CG:] Small group (10–12 participants) Intensity [underlined: IG:] Four sessions, 4 hours, on consecutive Saturdays [underlined: CG:] Four sessions, 4 hours, 1× on consecutive Saturdays Delivery [underlined: IG:] Trained AA female health educator and two peers [underlined: CG:] NR | F/U Time 6-mo; 12-mo % F/U [underlined: 6-mo] [underlined: IG:] 90%, [underlined: CG:] 89.7% [underlined: 12mo] [underlined: IG:] 87.3%, [underlined: CG:] 88.9% | STD incidence (crude) and OR over 12mo [underlined: chlamydia] [underlined: IG:] 2.1 per 100 person mo [underlined: CG:] 2.0 per 100 person mo OR: 0.17 (0.03–0.92) [underlined: gonorrhea] [underlined: IG:] 0.9 per 100 person mo [underlined: CG:] 0.7 per 100 person mo OR: 0.14 (0.01–3.02) [underlined: trichomonas] [underlined: IG:] 0.9 per 100 person mo [underlined: CG:] 1.2 per 100 person mo OR: 0.37 (0.09–1.46) | episodes UVI past 30d (relative % change), past 6mo 6-mo [underlined: IG:] 1.02, 3.77 [underlined: CG:] 2.02, 9.24 -50.69%, p=0.46; -64.23%, p=0.006 12-mo [underlined: IG:] 1.15, 5.77 [underlined: CG:] 2.04, 10.25 -39.26%, p=0.002; -39.31%, p=0.02 | % consistent condom use past 30d, past 6mo 6-mo [underlined: IG:] 75.3, 61.3 [underlined: CG:] 58.2, 42.6 OR: 1.77 (0.97–3.20) OR: 2.48 (1.44–4.26) 12-mo [underlined: IG:] 73.3, 58.1 [underlined: CG:] 56.5, 45.3 OR: 2.23 (1.17–4.27), OR= 2.14 (1.20–3.84) | % with new sex partner in past 30d 6-mo [underlined: IG:] 2.7 [underlined: CG:] 7.4 OR: 0.29 (0.11–0.77), p=0.01 12-mo [underlined: IG:] 3.6 [underlined: CG:] 5.6 OR: 0.59 (0.19–1.84), p=0.36 | N | N | No increase in unprotected sex or decrease in condom use No increase in STI incidence (by testing) | self-reported pregnancy (unadjusted %, OR) 6-mo [underlined: IG:] 3.6 [underlined: CG:] 7.0 OR 0.38 (0.15–0.96) 12-mo [underlined: IG:] 6.0 [underlined: CG:] 8.5 OR 0.74 (0.30–1.82) (also reported on knowledge, attitudes and skills) | culturally tailored, use of peer educators $25 incentives
Boekeloo 1999 ^18^ Fair | RCT DC; urban/suburban HMO Young adolescents | Inclusion: 12–15 years old, with appointment to see physician participating in study (primary care pediatrician at one of 5 practice sites, n=19) Exclusion: NR | N Randomized(N at exit interview) Total: 219 (215) [underlined: IG:] 105 (101) [underlined: CG:] 114 (114) Age [underlined: Age 12–13] [underlined: IG:] 57%, [underlined: CG:] 49% % Male [underlined: IG:] 52% [underlined: CG:] 48% Race [underlined: African American] [underlined: IG:] 60% [underlined: CG:] 68% [underlined: Caucasian] [underlined: IG:] 21%, [underlined: CG:] 17% [underlined: Hispanic] [underlined: IG:] 4% [underlined: CG:] 3% [underlined: Other] [underlined: IG:] 15% [underlined: CG:] 12% SES NR STI risk % been treated for STI in past 3 mo [underlined: IG:] 7.5% [underlined: CG:] 4.5% % with vaginal intercourse in past 3 mo [underlined: IG:] 20% [underlined: CG:] 23% | ASSESS (Awareness, Skills, Self-efficacy/Self-esteem, and Social Support) based on social-cognitive theory and the Theory of Reasoned Action | Intervention [underlined: IG:] 15 minute audiotape which includes risk assessment; physician review of risk assessment and discussion, with props and brochures [underlined: CG:] Usual care with primary care pediatrician Format [underlined: IG:] Individual with audiotape portion [underlined: CG:] N/A Intensity [underlined: IG:] One session incorporated into general health exam and waiting period [underlined: CG:] N/A Delivery [underlined: IG:] Audiotape (two physicians); and primary care pediatrician [underlined: CG:] N/A | F/U Time 3-mo; 9-mo % F/U [underlined: 3-mo] [underlined: IG:] 89%, [underlined: CG:] 94% [underlined: 9-mo] [underlined: IG:] 89%, [underlined: CG:] 90% | % told by doctor/nurse they had STD (self-reported) 3-mo [underlined: IG] (n=93): 1.1% [underlined: CG] (n=107): 0.9% 9-mo [underlined: IG] (n=94): 0% [underlined: CG] (n=103): 2.9% % been treated for an STD (self-reported) 3-mo [underlined: IG] (n=93): 2.2% [underlined: CG] (n=107): 4.7% 9-mo [underlined: IG] (n=94): 1.1% [underlined: CG] (n=103): 5.8% | N | % and odds ratio with condom use at last vaginal intercourse among those who were sexually active over past 3 mo 3-mo [underlined: IG:] 92%(23/25) [underlined: CG:] 57% (12/21) OR: 18.05 (1.27, 256.03) 9-mo [underlined: IG:] 71%(22/31) [underlined: CG:] 70%(21/30) OR: 1.00 (0.31, 3.24) | N | % with vaginal sex in past 3 -mo 3-mo IG: 27%(25/93) CG: 20%(21/107) OR: 2.46 (1.04, 5.84) 9-mo IG: 31/94=33% CG: 30/103=29% OR: 1.64 (0.81, 3.34) % with any (vaginal, oral, anal) sex in past 3 mo 3-mo IG: 29%(27/93) CG: 26%(30/107) OR: 1.55 (0.73, 3.32) 9-mo IG: 39%(37/94) CG: 34%(35/103) OR=1.56 (0.79, 3.08) | N | Does report increase in % having vaginal sex at 3-mo. IG=27% CG=20% OR -2.46 (1.04, 5.84) (Not at 9-mo, Not for ‘Any’ vaginal, oral, and anal sex) No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self report) | % self-reported pregnancy (gotten someone or been pregnant) baseline, 3-mo IG: 1.0%, 0% CG: 1.8%, 1.9% NS, p>0.05 baseline, 6-mo IG: 1.0%, 1.1% CG: 1.8%, 5.9% NS, p>0.05 (also reported on knowledge, attitudes and skills) | no incentives reported
Danielson 1990 ^25^ Fair | RCT OR,WA; urban HMO High school aged boys | Inclusion: boys 15–18 years receiving care at HMO Exclusion: NR | N Randomized Total: 1195 [underlined: IG:] NR [underlined: CG:] NR Age Reported % by year in High school Freshmen: 18% Sophomores: 34% Juniors: 24% Seniors: 24% % Male Total: 100% Race %African American: <5% %Asian Pacific Islander <4% SES Father employed full time: 86% Father graduated 4-year college: 44% STI risk % sexually active in the past year: 37% | NR | Intervention [underlined: IG:] Slide tape program with photos and information on sexual health, couple communication, and access to health services; and visit with health practionner- Q&A based on patient's interests, risk reduction counseling, modeling and rehearsing discussing sex and contraception with girlfriend [underlined: CG:] Scheduled consultation (intervention) was after the 1 year f/u assessment. Format IG: Individual CG: NR Intensity [underlined: IG:] One session, 1-hour medical appointment (30 min slide-tape/30min health practioner) [underlined: CG:] NR Delivery [underlined: IG:] Trained NP, PA or RN [underlined: CG:] NR | F/U Time 12-mo % F/U 12-mo: 81.3% (c) | N | 12-mo main method of contraception used over past 12 mo, % by contraception for pill use see ‘other positive outcomes’ % using any contraceptive at most recent intercourse 12-mo IG (n=262) 69.9% CG (n=260) 65.8% OR adjusted 1.51, p<0.05 OR adjusted for those who had not been sex active at baseline 2.53, p<0.01 | 12-mo % using condom at most recent intercourse IG (n=262) 33.3% CG (n=260) 35.8% | N | mean % teen male sex active 12-mo IG: 90% CG: 91% mean % teen male sex active (of those not previously sex active ) IG: 30% CG: 34% | N | No increase in unprotected sex or decrease in condom use No earlier sexual debut | 12-mo % with partner using pill at most recent sexual intercourse, and adjusted OR IG (n=262) 32.4% CG (n=260) 23.9% OR 1.66, p<0.05 | no incentives reported, travel reimbursement

Table 2 Evidence table key question 5

Study Characteristics/Design | | Study Population | | Study Intervention | | Study Outcomes/Results
Study Reference | Study Design Location Target population | Inclusion/Exclusion Criteria | Baseline Demographics | Study Intervention | Follow-up | Outcomes/Results
French 2003 ^31^ Fair | RCT US; urban public STI clinic adult, female; low-income, minority | Inclusion: women attending clinic Exclusion: women attending solely for purpose of anonymous HIV testing, or brought to clinic as part of contact-tracing | N Randomized Total: 1442 IG: 855 CG: 587 Age IG: 28.1 CG: 28.8 % Female 100% Race % African American IG=85.4% CG=87.2% SES NR | IG: interactive, multimedia, small group sessions (up to five women) with video, condom samples, posters, pamphlets, and pelvic and penis models to practice condom application; lasting 10–20 minutes; given free female condoms during study period encouraged to use the female condom during vaginal and anal sex and were instructed to purchase flavored male condoms for oral sex (not advised to stop using other methods) CG: interactive, multimedia, small group sessions (up to five women) with video, condom samples, posters, pamphlets, and pelvic and penis models to practice condom application; lasting 10–20 minutes; given free male condoms during study period (format same as IG) encouraged to use male condoms during all types of sexual intercourse (not encouraged to stop using any other method of protection) | F/U Time not fixed, up to 1 year % F/U IG: 50.2% CG: 51.1% mean number F/U visits IG: 2.2 CG: 2.3 | gonorrhea, chlamydia, early syphilis, trichomonas STI diagnosed at follow-up IG: 12.4%(106/855) CG: 15.8%( 93/587) unadjusted OR- 0.75 (0.56–1.01), p=0.06 STI incidence at follow-up IG: 6.8 per 100 women months CG: 8.5 per 100 women months OR- 0.79 (0.59–1.06), p=0.11
Fontanet 1998 ^30^ Fair | RCT Thailand; urban sex establishments Adult; Female; sex workers | Inclusion: Sex establishment-workers with reported multiple clients per day; by individual-18+, willing to use condoms as instructed, willing to keep a pictorial coital log for all sex acts (with client and non-commercial sex partners) Exclusion: using diaphragm, cervical cap and vaginal spermicides, evidence of IVDU | N Randomized [underlined: IG:] 249 [underlined: CG:] 255 Age < 20 years IG: 15%, CG: 17% 20–24 years IG: 40%, CG: 38% >24 years IG: 45% CG: 44% % Female 100% SES no education IG:19%, CG:24% <6 y education, IG:72% CG:65% >6 y education IG: 9% CG: 12% | IG: male/female condom group-women propose a male condom to their clients as a first choice, but would have option of using female condom when clients refused or could not use a male condom also given counseling regarding transmission of HIV and other STIs, given free supply of condoms CG: male condom group- women propose a male condom to their clients, and if clients refused or could not use male condoms, they were instructed not to have sex also given counseling regarding transmission of HIV and other STIs, given free supply of condoms (same as IG) | F/U Time every 2 weeks for 24 weeks (about 6 months) % F/U [underlined: IG:] 95.7% [underlined: CG:] 88.3% | gonorrhea, chlamydia, trichomonas, or genital ulcer disease incidence rate of STIs (weighted geometric mean per 100 woman-weeks) IG: 2.81 CG: 3.69 incidence rate ratio (95% CI): 0.76 (0.50–1.16) coital log recorded acts with male and female condoms, failures (torn/slippage), unprotected acts percent with acts male condom IG: 88.2% CG: 97.5% percent with acts female condom IG: 12.0% CG: 0%
Feldblum 2001 ^29^ Feldblum 2000 ^62^ Good | cluster RCT Kenya; rural agricultural sites adult, female; employed as agricultural worker | Inclusion: permanent employee, 18–50 yo, sexually active, willing to return for follow-up visits, give urine/vaginal samples, and answer questions about sexual activity and condom use Exclusion: pregnant, desire to become pregnant in coming year, using spermicidal contraceptive | N Randomized Total: 12 sites (1929 women) IG: 6sites (969 women) CG: 6 (960 women) Age: 33.1 % Female 100% SES completed primary school or less- “about 90%” | IG: Program relied on large/small group meetings, video presentations, puppetry, and other folk media, printed materials, individual counseling, given male and female condoms for all adults program delivered by trained clinic service providers, outreach workers, and plantation managers CG: Similar prevention program excluding information on female condoms, only given male condoms | F/U Time 6-mo, 12-mo % F/U [underlined: 6-mo] IG: 90.0%(881/969) CG: 89.2%(856/960) [underlined: 12-mo] IG: 82.2%(797/969) CG: 83.1%(798/960) at least one f/u 91% both f/u 82% | gonorrhea, chlamydia, or trichomonas crude prevalence of STI% [underlined: 6-mo] IG: 17.1% CG: 17.6% [underlined: 12-mo] IG: 18.2% CG: 18.4% association of STI prevalence IG: OR- 1.0 CG: OR- 1.1 (0.8, 1.6) consistent male condom use [underlined: 6-mo] IG: 14% CG: 23% [underlined: 12-mo] IG: 22% CG: 24% consistent female condom use [underlined: 6-mo] IG=11% CG=NA [underlined: 12-mo] IG: 7% CG: NA

Table 3 Abbreviations for evidence tables

Abbreviation | Description
(c) | calculated
BV | Bacterial Vaginosis
CASI | computer assisted survey interviewing
CG | comparison or control group
dx | diagnosis
GC | gonococcus=gonorrhea
HMO | health maintenance organization
hosp | hospitalization
HPV | Human Papillomavirus
HR | high risk
HS | high school
HSV | Herpes Simplex Virus
hx | history of
IG | intervention group
IVDU | Injection (intravenous) drug use
mh | mental health
MMSE | Mini Mental Status Exam
N | No
NR | not reported
NYC-DOH | New York City Department of Health
oth | other
PC-C | primary care conducted
PC-F | primary care feasible
PC-R | primary care referable
PHC | public health clinic
PID | pelvic inflammatory disease
pos | positive
psych | psychiatric
rand | randomized/randomization
REALM | Rapid Assessment of Adult Literacy
s/s | signs and symptoms
SCID | Schedule of Affective Disorders
STi | Sexually Transmitted infection
sx | symptom(s)
U | Unsure
UAI | unprotected anal intercourse
UVI | unprotected vaginal intercourse
w | with
w/o | without
Y | Yes
yo | years old
HR | Hazard ratio
N/A | Not applicable
NP | Nurse practitioner
PA | Physicians Assistant
RN | Registered Nurse
PY | Person years
SES | Socioeconomic status
States are cited as postal abbreviations