# References

(1) U.S.Preventive Services Task Force. Preventing HIV and other STDs. In: Williams & Wilkins, editor. Guide to Clinical Preventive Services. Baltimore: 1996: 723–737.
(2) Weinstock H, Berman S, Cates W. Sexually transmitted diseases among American youth: incidence and prevalence estimates, 2000. Perspect Sex Reprod Health. 2004;36(1):6-10. [pmid: 14982671].
(3) Center for Disease Control. Trends in Reportable Sexually Transmitted Diseases in the United States, 2004.
(4) Gallant JE. HIV counseling, testing, and referral. Am Fam Physician. 2004;70(2):295-302. [pmid: 15291088].
(5) Chesson HW, Blandford JM, Gift TL, et al. The estimated direct medical cost of sexually transmitted diseases among American youth, 2000. Perspect Sex Reprod Health. 2004;36(1):11-19. [pmid: 14982672].
(6) Henderson Z, Tao G, Irwin K. Sexually transmitted disease care in managed care organizations. Infect Dis Clin North Am. 2005;2005(2):491-511. [pmid: 15963885].
(7) Fairbrother G, Scheinmann R, Osthimer B, et al. Factors that influence adolescent reports of counseling by physicians on risky behavior. J Adolesc Health. 2005;37(6):467-76. [pmid: 16310124].
(8) Millstein SG, Igra V, Gans J. Delivery of STD/HIV preventive services to adolescents by primary care physicians. J Adolesc Health. 1996;1919(4):249-57. [pmid: 8897102].
(9) Koumans EH, Sternberg MR, Motamed C,et, al.. Sexually Transmitted Disease Services at US Colleges and Universities. 2005.
(10) Ashton MR, Cook RL, Wiesenfeld HC, et al. Primary care physician attitudes regarding sexually transmitted diseases. Sex Transm Dis. 2002;29(4):246-51. [pmid: 11912468].
(11) Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
(12) Boyer CB, Barrett DC, Peterman TA, et al. Sexually transmitted disease (STD) and HIV risk in heterosexual adults attending a public STD clinic: evaluation of a randomized controlled behavioral risk-reduction intervention trial. AIDS. 1997;11(3):359-367. [pmid: 9147428].
(13) Carey MP, Carey KB, Maisto SA, et al. Reducing HIV-risk behavior among adults receiving outpatient psychiatric treatment: results from a randomized controlled trial. J Consult Clin Psychol. 2004;72(2):252-268. [pmid: 15065959].
(14) Kamb ML, Fishbein M, Douglas JM Jr, et al. Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: a randomized controlled trial. Project RESPECT Study Group. JAMA. 1998;280(13):1161-1167. [pmid: 9777816].
(15) Scholes D, McBride CM, Grothaus L, et al. A tailored minimal self-help intervention to promote condom use in young women: results from a randomized trial.[see comment]. AIDS. 2003;17(10):1547-56. [pmid: 12824793].
(16) Shain RN, Piper JM, Newton ER, et al. A randomized, controlled trial of a behavioral intervention to prevent sexually transmitted disease among minority women. N Engl J Med. 1999;340(2):93-100. [pmid: 9887160].
(17) Shain RN, Piper JM, Holden AE, et al. Prevention of gonorrhea and Chlamydia through behavioral intervention: results of a two-year controlled randomized trial in minority women. Sex Transm Dis. 2004;31(7):401-408. [pmid: 15215694].
(18) Boekeloo BO, Schamus LA, Simmens SJ, et al. A STD/HIV prevention trial among adolescents in managed care. Peds. 1999;103(1):107-15.
(19) DiClemente RJ, Wingood GM, Harrington KF, et al. Efficacy of an HIV prevention intervention for African American adolescent girls: a randomized controlled trial. JAMA. 2004;292(2):171-179. [pmid: 15249566].
(20) Jemmott JB III, Jemmott LS, Braverman PK, et al. HIV/STD risk reduction interventions for African American and Latino adolescent girls at an adolescent medicine clinic: a randomized controlled trial. Arch Pediatr Adolesc Med. 2005;159(5):440-449. [pmid: 15867118].
(21) Bolu OO, Lindsey C. Is HIV/sexually transmitted disease prevention counseling effective among vulnerable populations?: a subset analysis of data collected for a randomized, controlled trial evaluating counseling efficacy (Project RESPECT). Sex Transm Dis. 2004;31(8):469-74. [pmid: 15273579].
(22) Ehrhardt AA, Exner TM, Hoffman S, et al. A gender-specific HIV/STD risk reduction intervention for women in a health care setting: short- and long-term results of a randomized clinical trial. AIDS Care. 2002;14(2):147-61. [pmid: 11940275].
(23) Proude EM, D'Este C, Ward JE. Randomized trial in family practice of a brief intervention to reduce STI risk in young adults. Fam Pract. 2004;21(5):537-544. [pmid: 15367476].
(24) Wenger NS, Greenberg JM, Hilborne LH, et al. Effect of HIV antibody testing and AIDS education on communication about HIV risk and sexual behavior. A randomized, controlled trial in college students. Annals of Internal Medicine. 1992;117(11):905-11. [pmid: 1443951].
(25) Danielson R. Reproductive health counseling for young men: what does it do?. Family Planning Perspectives. 1990;22(3):115-21. [pmid: 2379568].
(26) Hobfoll SE, Jackson AP, Lavin J, et al. Reducing inner-city women's AIDS risk activities: a study of single, pregnant women. Health Psychology. 1994;13(5):397-403. [pmid: 7805634].
(27) Korte JE, Shain RN, Holden AE, Piper JM, Perdue ST, Champion JD, et al. Reduction in sexual risk behaviors and infection rates among African Americans and Mexican Americans. Sexually Transmitted Diseases. 2004;31(3):166-73. [pmid: 15076930].
(28) Soper D, Shoupe D. Prevention of vaginal trichomoniasis by compliant use of the female condom. Sexually Transmitted Diseases 1993;(3).
(29) Feldblum PJ, Kuyoh MA, Bwayo JJ, et al. Female condom introduction and sexually transmitted infection prevalence: results of a community intervention trial in Kenya. AIDS. 2001;15(8):1037-44. [pmid: 11399986].
(30) Fontanet AL, Saba J, Chandelying V, et al. Protection against sexually transmitted diseases by granting sex workers in Thailand the choice of using the male or female condom: results from a randomized controlled trial. AIDS. 1998;12(14):1851-9. [pmid: 9792386].
(31) French PP, Latka M, Gollub EL, et al. Use-effectiveness of the female versus male condom in preventing sexually transmitted disease in women.[comment]. Sex Transm Dis. 2003;30(5):433-9. [pmid: 12916135].
(32) Koblin B, Chesney M, Coates T. Effects of a behavioural intervention to reduce acquisition of HIV infection among men who have sex with men: the EXPLORE randomised controlled study. Lancet. 2004;364(9428):41-50. [pmid: 15234855].
(33) Li X, Stanton B, Feigelman S, et al. Unprotected sex among African-American adolescents: a three-year study. J Natl Med Assoc. 2002;94(9):789-796. [pmid: 12392042].
(34) Metcalf CA, Malotte CK, Douglas JM Jr, et al. Efficacy of a booster counseling session 6 months after HIV testing and counseling: a randomized, controlled trial (RESPECT-2). Sex Transm Dis. 2005;32(2):123-129. [pmid: 15668620].
(35) Nyamathi AM, Kington RS, Flaskerud J, et al. Two-year follow-up of AIDS education programs for impoverished women. Western Journal of Nursing Research. 1999;21(3):405-25. [pmid: 11512206].
(36) Gottlieb SL, Douglas JM Jr, Foster M, et al. Incidence of herpes simplex virus type 2 infection in 5 sexually transmitted disease (STD) clinics and the effect of HIV/STD risk-reduction counseling. J Infect Dis. 2004;190(6):1059-1067. [pmid: 15319854].
(37) Harvey SM, Henderson JT, Beckman S, et al. A randomized study of a pregnancy and disease prevention intervention for Hispanic couples. Perspectives on sexual and reproductive health. 2004;36(4):162-9. [pmid: 15321783].
(38) Smoak ND, Scott-Sheldon LA, Johnson BT, et al. Sexual risk reduction interventions do not inadvertently increase the overall frequency of sexual behavior: a meta-analysis of 174 studies with 116,735 participants. J Acquir Immune Defic Syndr. 2006;41(3):374-384. [pmid: 16540941].
(39) Pealer LN, Peterman TA, Newman DR, et al. Are counselor demographics associated with successful human immunodeficiency virus/sexually transmitted disease prevention counseling?. Sex Transm Dis. 2004;31(1):52-56. [pmid: 14695958].
(40) Jemmott JB III, Jemmott LS, Fong GT, et al. Reducing HIV risk-associated sexual behavior among African American adolescents: testing the generality of intervention effects. Am J Community Psychol. 1999;27(2):161-187. [pmid: 10425698].
(41) Weller S, Davis K. Condom effectiveness in reducing heterosexual HIV transmission. Cochrane Database Syst Rev 2001;(3):CD003255.
(42) Weller S, Davis-Beaty K. The effectiveness of male condoms in prevention of sexually transmitted diseases. Cochrane Database of Systematic Reviews 2005;(4).
(43) Ness RB, Randall H, Richter HE, et al. Condom use and the risk of recurrent pelvic inflammatory disease, chronic pelvic pain, or infertility following an episode of pelvic inflammatory disease. Am J Public Health. 2004;94(8):1327-1329. [pmid: 15284036].
(44) Manhart LE, Koutsky LA. Do condoms prevent genital HPV infection, external genital warts, or cervical neoplasia? A meta-analysis. Sex Transm Dis. 2002;29(11):725-735. [pmid: 12438912].
(45) Wald A, Langenberg AG, Link K, et al. Effect of condoms on reducing the transmission of herpes simplex virus type 2 from men to women.[see comment]. JAMA. 2001;285(24):3100-6. [pmid: 11427138].
(46) Minnis AM, Padian NS. Effectiveness of female controlled barrier methods in preventing sexually transmitted infections and HIV: current evidence and future research directions. Sexually Transmitted Infections. 2005;81(3):193-200. [pmid: 15923284].
(47) Melendez RM, Hoffman S, Exner T, et al. Intimate partner violence and safer sex negotiation: effects of a gender-specific intervention. Archiv Sexual Beh. 2003;32(6):499-511.
(48) Wingood GM, DiClemente RJ, Harrington KF, et al. Efficacy of an HIV Prevention Program Among Female Adolescents Experiencing Gender-Based Violence. American Journal of Public Health. 2006;96(6):1085-1090. [pmid: 16670238].
(49) Sweat M, O'Donnell C, O'Donnell L. Cost-effectiveness of a brief video-based HIV intervention for African American and Latino sexually transmitted disease clinic clients. AIDS. 2001;15(6):781-7. [pmid: 11371693].
(50) Cohen DA, Wu SY, Farley TA. Comparing the cost-effectiveness of HIV prevention interventions. J Acquir Immune Defic Syndr. 2004;37(3):1404-1414. [pmid: 15483470].
(51) O'Donnell CR, O'Donnell L, San Doval A, et al. Reductions in STD infections subsequent to an STD clinic visit. Using video-based patient education to supplement provider interactions. Sexually Transmitted Diseases. 1998;25(3):161-8. [pmid: 9524995].
(52) Cohen DA, Wu SY, Farley TA. Comparing the cost-effectiveness of HIV prevention interventions. J Acquir Immune Defic Syndr. 2004;37(3):1404-1414. [pmid: 15483470].
(53) Harrington KF, DiClemente RJ, Wingood GM, et al. Validity of self-reported sexually transmitted diseases among African American female adolescents participating in an HIV/STD prevention intervention trial. SexTransm Dis. 2001;28(8):468-71.
(54) Zenilman JM. Behavioral interventions—rationale, measurement, and effectiveness. Infectious Disease Clinics of North America 2005;(2):541–562.
(55) Peterman TA, Lin LS, Newman DR, et al. Does measured behavior reflect STD risk? An analysis of data from a randomized controlled behavioral intervention study. Project RESPECT Study Group. Sex Transm Dis. 2000;27(8):446-51. [pmid: 10987449].
(56) Shain RN, Perdue ST, Piper JM, et al. Behaviors changed by intervention are associated with reduced STD recurrence: The importance of context in measurement. Sex Transm Dis. 2002;29(9):520-529. [pmid: 12218843].
(57) Johnson WD, Hedges LV, Diaz RM et al. Interventions to modify sexual risk behaviors for preventing HIV infection in men who have sex with men. Cochrane Database of Systematic Reviews 2005.
(58) Coyle SL, Needle RH, Normand J. Outreach-based HIV prevention for injecting drug users: a review of published outcome data. Public Health. 1999;113(Supplement 1):19-30. [pmid: 10823744].
(59) Herbst JH, Beeker C, Mathew A, et al. The Effectiveness of Individual-, Group-, and Community-Level HIV Behavioral Risk-Reduction Interventions for Adult Men Who Have Sex with Men A Systematic Review. Am J Prev Med. 2007;32(4 Suppl):38-67. [pmid: 17218189].
(60) Chou R, Huffman LH, Fu R, et al. Screening for HIV: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2005;143(1):55-73. [pmid: 15998755].
(61) Hoffman S, Exner TM, Leu CS, et al. Female-condom use in a gender-specific family planning clinic trial. American Journal of Public Health. 2003;93(11):1897-903. [pmid: 14600063].
(62) Feldblum PJ BJK. The female condom and STDs: design of a community intervention trial. Annals of epidemiology 1910;(6).