# Results

## Key Question 1. Is there direct evidence that behavioral counseling interventions to reduce risky sexual behaviors and increase protective sexual behaviors reduce STI incidence and/or related morbidity and mortality?

### Summary of results

[underlined: Adults.] We identified six fair-to-good quality trials in adults examining the impact of primary care feasible behavioral counseling interventions on reducing STI incidence (Table 1). ^12^ – ^17^ One RCT was conducted in a psychiatric outpatient clinic; ^13^ four RCTs were conducted in STI clinics, ^12,^ ^14,^ ^16,^ ^17^ and only one RCT was conducted in a primary care setting. ^15^ Behavioral counseling interventions ranged from low intensity (e.g., distribution of tailored self-help materials) to high intensity (e.g., multiple session counseling interventions up to 10 sessions). All trials focused on urban and ethnically diverse patient populations (20–60 percent African American). All trials conducted in STI clinics used laboratory or clinically diagnosed STI as their outcome measure, while the other two trials not conducted in STI clinics used self-reported measures of STI.

Table 1 Biological outcomes adults (KQ1)

Study Reference Quality | Setting | Baseline Demographics | Study Intervention/Intensity | Biologic Outcomes
Shain 2004 ^17^ Project SAFE 2 Fair | STI clinic | N: 775 (690 in analysis) 100% Female Hispanic: 77% African American: 23% with GC (c):20.6% with Chlamydia (c): 77.8% with Trichomonas (c): 15.4% with syphilis (c): 4.6% | Culturally tailored ARRM. IG1 & IG2: High- 9 hours total; 3 group sessions +/- optional support group sessions CG: usual care, 15 minute CDC standard counseling | % Re-infection (newly dx GC, chlamydia, or both) mean %, p values
Shain 2004 ^17^ Project SAFE 2 Fair | STI clinic | N: 775 (690 in analysis) 100% Female Hispanic: 77% African American: 23% with GC (c):20.6% with Chlamydia (c): 77.8% with Trichomonas (c): 15.4% with syphilis (c): 4.6% | Culturally tailored ARRM. IG1 & IG2: High- 9 hours total; 3 group sessions +/- optional support group sessions CG: usual care, 15 minute CDC standard counseling | 1-year [underlined: IG1:] 15.7%, p=0.006 [underlined: IG2:] 15.4%, p=0.004 [underlined: CG:] 26.8% | 2-year [underlined: IG1:] 14.7%, p=0.03 [underlined: IG2:] 14.8%, p, 0.03 [underlined: CG:] 23.1%
Shain 2004 ^17^ Project SAFE 2 Fair | STI clinic | N: 775 (690 in analysis) 100% Female Hispanic: 77% African American: 23% with GC (c):20.6% with Chlamydia (c): 77.8% with Trichomonas (c): 15.4% with syphilis (c): 4.6% | Culturally tailored ARRM. IG1 & IG2: High- 9 hours total; 3 group sessions +/- optional support group sessions CG: usual care, 15 minute CDC standard counseling | OR (adjusted) with recurrent STI
[underlined: IG1:] 0.51 (0.31–0.83) [underlined: IG2]: 0.50 (0.31–0.80) | [underlined: IG1:] 0.57 (0.34–0.96) [underlined: IG2:] 0.58 (0.36–0.94)
Shain 1999 ^16^ Project SAFE Good | STI clinic | N: 617 (549 in analysis) 100% Female Hispanic: 69% African American: 31% with GC (c): 22.8% with chlamydia (c): 68.7 with trichomonas (c): 23.7% with syphilis(c): 6.0% | Culturally tailored ARRM. IG: High- 9–12 hours total; 3 group sessions CG: usual care, 15 minute CDC standard counseling | % Re-infection (newly dx GC, chlamydia, or both) mean % at 12 mo, p=0.01 between group assignments
Shain 1999 ^16^ Project SAFE Good | STI clinic | N: 617 (549 in analysis) 100% Female Hispanic: 69% African American: 31% with GC (c): 22.8% with chlamydia (c): 68.7 with trichomonas (c): 23.7% with syphilis(c): 6.0% | Culturally tailored ARRM. IG: High- 9–12 hours total; 3 group sessions CG: usual care, 15 minute CDC standard counseling | [underlined: IG:] 16.8% (48/285) | [underlined: CG:] 26.9% (71 /264)
Shain 1999 ^16^ Project SAFE Good | STI clinic | N: 617 (549 in analysis) 100% Female Hispanic: 69% African American: 31% with GC (c): 22.8% with chlamydia (c): 68.7 with trichomonas (c): 23.7% with syphilis(c): 6.0% | Culturally tailored ARRM. IG: High- 9–12 hours total; 3 group sessions CG: usual care, 15 minute CDC standard counseling | OR (adjusted) with recurrent STI
6-mo [underlined: IG:] 11.3% (30/265) [underlined: CG:] 17.2% (42/244) OR: 0.58 (0.34–0.99), p=0.05 | 12-mo [underlined: IG:] 16.8% (48/285) [underlined: CG:] 26.9% (71/264) OR: 0.52 (0.34–0.81), p=0.004
Kamb 1998 ^14^ Project RESPECT Fair | STI clinics | N: 5758 Male: 57% African American: 59% Hispanic: 19% Other race: 6% with STI (c): 31.8% | CDC's client centered HIV prevention counseling model; enhanced version based on multiple social science theories. IG1: High- 200 minutes total; 4 individual sessions; IG2- Moderate- 40 minutes total; 2 individual sessions CG: usual care, 10 minute information only | mean % with new STI (GC/chlamydia, syphilis, HIV), RR (adjusted) for new STI
6-mo [underlined: IG1:] 7.2% RR 0.69 (0.54–0.88) [underlined: IG2:] 7.3% RR 0.71 (0.58–0.89) [underlined: CG1:] 10.4% | 12-mo [underlined: IG1:] 11.5% RR 0.78 (0.64–0.94) [underlined: IG2:] 12.0% RR 0.81 (0.67–0.98) [underlined: CG1:] 14.6%
Boyer 1997 ^12^ Fair | STI clinic | N: 393 African American: 46% Male (c): 67% Hispanic: 15% Other race: 10% with hx of STI (c): 62% | ARRM. IG: High- 4 hours total; 4 individual sessions CG: usual care, 15 minute standard counseling | % New/Probable STI (GC, chlamydia, syphilis, trichomonas, HIV, HSV, HPV, BV)
Male % Mean [underlined: IG:] 6.8% [underlined: CG:] 7.0% | Female% Mean [underlined: IG:] 21.8% [underlined: CG:] 22%
Carey 2004 ^13^ Fair | Outpatient psychiatric | N: 408 Male: 46% African-American: 21% | HIV harm reduction, motivational techniques to enhance readiness to change. IG: High- unknown total hours; 10 group sessions CG1 & CG2: matched substance abuse counseling, or usual care | % Self-report of newly dx STI N, % at baseline, mean %, p values (adjusted) [underlined: IG:] 123, 10%, 2% [underlined: CG1:] 121, 8%, 8%, p<0.013 [underlined: CG2:] 110, 7%, 5%, p<0.046 OR not reported
Scholes 2003 ^15^ Fair | Medical clinic | N: 1210 100% Female African American: 19% Other race: 12% With hx/dx of STI: 27% | Individually tailored self-help printed materials based on multiple social science theories. IG: Low- 2 mailings, 12-page booklet and booster newsletter CG: usual care, details NR | % Self reported STI dx in past 3 mo Mean % [underlined: IG:] 3.5% [underlined: CG:] 3.6% OR (adjusted): 0.97 (0.48, 1.96), p=0.93

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

The majority of evidence (four RCTs, n=7558) ^13,^ ^14,^ ^16,^ ^17^ suggests a modest reduction in STI at 6 or 12 months among “at-risk” adults receiving multiple intervention sessions. Three of the four trials conducted in STI clinics (three RCTs, n=7150) ^14,^ ^16,^ ^17^ showed a moderate decrease in bacterial STI incidence at 12 months, compared to usual care that included only minimal counseling. One of these trials, Project SAFE 2, reported a similar magnitude of reduction in STI incidence at 2 years. One trial, Project RESPECT, combined HIV counseling with testing. ^14^ In contrast, one fair-quality trial conducted in an STI clinic (n=393) did not show an effect on STI incidence at 6 months. ^12^ In a fair-quality RCT (n=408), psychiatric clinic outpatients with a history of alcohol or other substance abuse who received 10 sessions of group counseling on sexual risk reduction had a lower incidence of self-reported STI at 6 months, compared to those receiving similarly formatted substance abuse counseling. ^13^

In the single fair-quality RCT conducted in an HMO primary care setting (n=1210), young nonmonogamous women receiving two rounds of tailored printed materials did not show a significant difference in self-reported STIs at 6 months, compared with usual care. ^15^

In general, all trials were well conducted RCTs. Project RESPECT, however, had only 70 percent followup at 6 months, and 66 percent followup at 12 months. Similarly, an RCT by Boyer et al. with non-significant intervention effects had approximately 70 percent followup at 6 months. Two trials, one by Carey et al. and one by Scholes et al., used self-reported measures of STI incidence.

[underlined: Adolescents.] We identified four fair-to-good-quality RCTs that examined the impact of primary care feasible behavioral counseling interventions on reducing STI incidence explicitly in adolescents (Table 2). ^14,^ ^18^ – ^21^ Three of the four trials focused on sexually active adolescents, ^14,^ ^19,^ ^21^ and one included both sexually active and pre-sexually active adolescents (aged 12 to 15 years old). ^18^ All trials focused on urban and ethnically diverse patient populations (60 to 100 percent African American). Two trials included only female adolescents. Interventions ranged from one to four sessions in an individual or small-group format. The three trials in sexually active adolescents used laboratory or clinically diagnosed STIs as their outcome measure, while the one trial with both sexually active and pre-sexually active adolescents used self-reported STI measures.

Table 2 Biological outcomes adolescents (KQ1)

Study Reference Quality | Setting | Population | Study Intervention/Intensity | Biologic Outcomes
Jemmott 2005 ^20^ Good | Adolescent medicine clinic | N: 682 100% Female African American: 68% Hispanic: 32% with any STI: 21.9% | Culturally tailored skills-based intervention based on cognitive behavioral theories. IG1 & IG2: High- 250 minutes total; one group session; +/- skills training CG: matched general health promotion counseling | Mean % testing positive for STI (GC, chlamydia, Trichomonas), p value (adjusted)
6-mo [underlined: IG1:] 15.8%, p=0.80 [underlined: IG2:] 15.5%, p=0.89 [underlined: CG:] 14.8% | 12-mo [underlined: IG1:] 10.5%, p=0.05 [underlined: IG2:] 14.4%, p=0.44 [underlined: CG:] 18.2%
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | STI incidence per 100 person (crude), OR (adjusted) over 12mo chlamydia
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | [underlined: IG:] 2.1 | [underlined: CG:] 2.0
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | OR: 0.17 (0.03–0.92) Gonorrhea
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | [underlined: IG:] 0.9 | [underlined: CG:] 0.7
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | OR: 0.14 (0.01–3.02) Trichomonas
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | [underlined: IG:] 0.9 | [underlined: CG:] 1.2
OR: 0.37 (0.09–1.46
Kamb 1998 ^14^ Bolu 2004 ^21^ Project RESPECT Fair | STI clinics | N: 764 Male: NR for subgroup Race: NR for subgroup with any STI: NR for subgroup | CDC's client centered HIV prevention counseling model; enhanced version based on multiple social science theories. IG1: High- 200 minutes total; 4 individual sessions; IG2- Moderate- 40 minutes total; 2 individual sessions CG: usual care, 10 minute information only | mean % with new STI (GC/chlamydia, syphilis, HIV), RR (adjusted) for new STI at 12 mo
[underlined: IG1:] 17.2% RR 0.57 (0.37–0.90) [underlined: IG2:] 17.5% RR 0.58 (0.37–0.92) [underlined: CG1:] 26.6%
Boekeloo 1999 ^18^ Fair | HMO | N: 219 Male: 50.2% African American: 64% Hispanic: 3% Other race: 14% | Physician counseling based on 15 minute audiotape risk assessment done in waiting period. IG: Low- unknown total duration; ‘brief’ individual session CG: usual care, details NR | % Told by doctor/nurse they had STI (self-reported)
Boekeloo 1999 ^18^ Fair | HMO | N: 219 Male: 50.2% African American: 64% Hispanic: 3% Other race: 14% | Physician counseling based on 15 minute audiotape risk assessment done in waiting period. IG: Low- unknown total duration; ‘brief’ individual session CG: usual care, details NR | 3-mo [underlined: IG]: 1.1% [underlined: CG]: 0.9% | 9-mo [underlined: IG]: 0% [underlined: CG]: 2.9%
Boekeloo 1999 ^18^ Fair | HMO | N: 219 Male: 50.2% African American: 64% Hispanic: 3% Other race: 14% | Physician counseling based on 15 minute audiotape risk assessment done in waiting period. IG: Low- unknown total duration; ‘brief’ individual session CG: usual care, details NR | % treated for an STD (self-reported)
3-mo [underlined: IG]: 2.2% [underlined: CG]: 4.7% | 9-mo [underlined: IG]: 1.1% [underlined: CG]: 5.8%

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

The majority of evidence (three RCTs, n= 1998) showed a modest reduction in STI incidence at 12 months in sexually active adolescents. All three RCTs in sexually active adolescents, who had much higher baseline risks for STIs, showed a decrease in laboratory positive STIs at 12 months. One of these trials, Project RESPECT, combined HIV counseling with testing. We only found one fair-quality RCT that included pre-sexually active adolescents (n=219), in which those who received a low-intensity counseling intervention (15 minute standardized risk assessment and discussion of risk with pediatrician) did not have a significant difference in self-reported STIs at 3 or 9 months. ^18^

The RCT by Boekeloo et al. with non-significant intervention effects was likely not powered to show a difference in STI incidence, given the small sample size and low percentages of incident STI. In addition, this RCT used self-reported measures of STI incidence.

[underlined: Pregnant women.] We found no studies that met our inclusion criteria specifically addressing pregnant women. One study by Shain et al. included about 30% pregnant women. Their results, however, were not reported separately for this subgroup. ^16^

### Study Details

[underlined: Adults: laboratory diagnosed STIs.] The four trials that used laboratory diagnosed STIs were all conducted in STI clinics. Shain et al ^16,^ ^17^ conducted two trials, Project SAFE and Project SAFE 2, in an urban STI clinic that included low-income Hispanic and African American women, aged 15 to 45 years, who were nonviral STI positive. However, results were not reported separately for the adolescent age group. In Project SAFE (n=617), women were randomized to either a three-session, small-group counseling intervention that was a cultural adaptation of the AIDS Risk Reduction Model (ARRM) or standardized usual care consisting of 15 minute counseling by CDC guidelines. ^16^ At baseline, women were on average about 21 years old, about 70 percent were Hispanic, and about 30 percent were pregnant. At 6 months, with about 80 percent followup, 11.3 percent in the intervention group and 17.2 percent in the control group had laboratory diagnosed gonorrhea or chlamydia, adjusted OR 0.58, 95 percent CI (0.34, 0.99). At 12 months, with about 90 percent followup, 16.8 percent in the intervention group and 26.9 percent in the control group were STI positive, adjusted OR 0.52, 95 percent CI (0.34–0.81). In Project SAFE 2 (n=775), women were randomized to the same culturally tailored ARRM intervention, an enhanced intervention with the option of five additional monthly support-group sessions or a usual care control group. ^17^ Women at baseline were on average about 21 years old, about 75 percent were Hispanic, and about 25 percent were African American. This trial had about 90 percent followup at 1 and 2 years and reported on laboratory diagnosed gonorrhea or chlamydia. Similar to their previous trial, this trial showed a similar magnitude of risk reduction for the standard intervention at 1 year, adjusted OR 0.51 (0.31–0.83), and at 2 years, adjusted OR 0.57, 95 percent CI (0.34–0.96). There was no difference in re-infection rates between the two intervention groups, standard versus enhanced.

Kamb et al. ^14^ conducted Project RESPECT, a multi-center, fair-quality RCT in four urban STI clinics serving predominantly low-income and minority populations. Project RESPECT randomized heterosexual persons age 14 or older (n=5758) into one of two intervention groups or one of two control groups. One intervention group received enhanced HIV counseling and testing based on the theory of reasoned action and social cognitive theory delivered in four individual sessions (total of 200 minutes). The second intervention group was the CDC's client-centered HIV prevention counseling model delivered in two brief individual sessions (total of 40 minutes). The control groups also consisted of two similar individual sessions, only lasting a total of 10 minutes. At baseline, participants had a median age of 25 years, 57 percent were men, 84 percent were nonwhite, and about one-third had a current STI. At 6 months, with about 70 percent followup, the standard intervention group had a reduction in those testing positive for a new STI (including gonorrhea, chlamydia, syphilis, or HIV), compared with those in the primary control group, RR 0.71, 95 percent CI (0.58–0.89). At 12 months, with about 66 percent followup, the RR was 0.81, 95 percent CI (0.67–0.98). There was no significant difference in risk reduction between the two intervention groups, standard versus enhanced.

A trial conducted by Boyer et al. ^12^ in STI clinics focused on heterosexual young adults with either a previous/current STI or a partner diagnosed with an STI. Participants (n=393) were randomized to four sessions of ARRM-based individual counseling, or usual care consisting of a brief 15-minute standard risk-reduction. At baseline, 67 percent were men, 71 percent were nonwhite, and 62 percent had a history of an STI. At 6 months, with about 70 percent followup, there was no difference in newly detected STIs by laboratory testing (gonorrhea, chlamydia, syphilis, trichomonas, or HIV), sequelae of STIs (e.g., PID, cervicitis, urethritis), or chronic/possible STIs (e.g., HSV, HPV, BV).

[underlined: Adults: self-reported STIs.] The only trial in a general primary care setting that examined the impact of behavioral counseling intervention on STI incidence in adults was by Scholes et al. ^15^ This fair-quality RCT focused on nonmonogamous women, aged 18 to 24 years, who received care in an HMO. Women (n=1210) were randomized to receive either tailored self-help intervention materials consisting of a 12-page magazine style booklet aimed at increasing condom use, plus a booster newsletter at 3 months, or to usual care. At baseline, about 31 percent of the women were nonwhite, about 42 percent were employed fulltime, and about 26 percent had a history of an STI. At 6 months, with 85 percent followup, there was no difference in any self-reported STIs over the past 3 months. Overall, there was a low percent of self-reported STIs at the 6-month followup (3.5 percent in the intervention group and 3.6 percent in the usual care group).

A fair-quality RCT by Carey et al. ^13^ was the only study focusing on mentally ill patients meeting our inclusion criteria. This study focused on patients attending an outpatient psychiatric clinic who had comorbid drug or alcohol use. Participants (n=408) were randomized into one of three groups: an intervention group receiving 10 group sessions on HIV risk reduction based on harm reduction and motivational techniques to enhance readiness to change; a control group receiving 10 group sessions on substance use reduction; and a second control group receiving usual care only. At baseline, the median age was 36 years, 46 percent were men, 21 percent were nonwhite, 17 percent were employed, and about 38 percent had a history of an STI. At 6 months, with 89 percent followup, only 2 percent in the intervention group self-reported a newly diagnosed STI, compared to 8 percent in the substance use reduction control group, p<0.013 adjusted for STI at baseline.

[underlined: Adolescents: laboratory diagnosed STIs.] Three trials were exclusively conducted in sexually active adolescents. One good-quality trial by Jemmott et al. ^20^ focused on African American and Hispanic girls in an urban adolescent medicine clinic. Adolescents (n=682) were randomized to receive one of two culturally tailored counseling interventions based on cognitive behavioral theories or a similarly formatted general health promotion intervention. The interventions consisted of either one 250-minute, small-group session on skills based HIV/STI risk reduction or information based risk reduction delivered by a trained African American female facilitator. At baseline, the mean age was about 15 years, about 70 percent were African American, 30 percent were Hispanic, and about 20 percent had a current STI. At 6 months, with about 93 percent followup, there was no significant difference in laboratory diagnosed gonorrhea, chlamydia, or trichomonas. At 12 months, however, with about 89 percent followup, there was a significant reduction in STIs for girls who received the skills-based counseling intervention, adjusted mean 10.5 percent in the skills-based intervention, compared to 18.2 percent in the control group, p=0.05.

Another good-quality trial that focused on a similar population, sexually active African-American adolescents aged 14–18 years, was conducted by DiClemente et al. ^19^ This trial randomized girls (n=552) to either receive either a culturally tailored counseling intervention on sexual risk reduction or nutrition and exercise, based on social cognitive theory and theory of gender and power. This intervention was similar in intensity to the trial by Jemmott et al., but group sessions were divided into four sessions and delivered by a trained African-American female facilitator with two peer facilitators. At baseline, these girls were on average 16 years old and about 20–30 percent had a current bacterial STI. At 12 months, with about 88 percent followup, there was a significant reduction in laboratory diagnosed chlamydia infections, adjusted OR 0.17, 95 percent CI (0.03–0.92). The reductions in gonorrhea and trichomonas infections were not statistically significant. This finding, however, may result from the relatively small number of incident gonorrhea and trichomonas infections, which occurred at about half the rate of chlamydia infections.

Project RESPECT, as discussed in the “Adult” subsection, was a fair-quality, multi-center RCT that evaluated two HIV counseling and testing interventions in STI clinics. ^14,^ ^21^ Bolu et al. ^21^ present a series of subgroup analyses that included a stratification by age groups. They report that the greatest risk reduction for newly diagnosed STIs (gonorrhea, chlamydia, syphilis, and HIV) was in adolescents (age 14 to 20 years), for both the standard and enhanced interventions. The adjusted RR for the standard intervention (CDC's client-centered HIV prevention counseling model, two sessions for a total of 40 minutes) was 0.58, 95 percent CI (0.37, 0.92), compared to control.

[underlined: Adolescents: self-reported STIs.] Boekeloo et al ^18^ conducted the only trial that examined a behavioral counseling intervention's impact on STI incidence in a general population of adolescents, including presexually active adolescents. This fair-quality RCT focused on young adolescents, aged 12 to 15 years, in an urban/suburban HMO. Young adolescents (n=219) were randomized to either a 15-minute audiotape including a risk assessment and a subsequent discussion with pediatrician or usual care with their primary care pediatrician. This counseling intervention, ASSESS (Awareness, Skills, Self-efficacy/-esteem, and Social Support), based on social cognitive theory and the Theory of Reasoned Action, was designed to be incorporated into the general health exam and waiting period. At baseline, about half of the adolescents were aged 12–13 years, about half were male, about 80 percent were nonwhite, and 20 percent were sexually active during the previous 3 months, and about five to seven percent had been treated for an STI during the previous 3 months. At both 3 and 9 months, with about 90 percent followup, there was no statistically significant difference in self-reported incidents of STIs. Rates of self-reported STIs, however, were low (up to 5.8 percent).

## Key Question 2. Do behavioral counseling interventions to prevent STIs in primary care reduce risky sexual behaviors or increase protective sexual behaviors?

We will not discuss studies that provide direct evidence of behavioral counseling interventions on the reduction of STI incidence in the context of their impact on behavioral outcomes. Details of behavioral outcomes for these studies, however, can be found in the evidence table (Appendix B).

### Summary of results

[underlined: Adults.] We identified three additional fair-to-good-quality trials that examined the impact of primary care feasible behavioral counseling interventions on reducing self-reported risky sexual behaviors or increasing protective sexual behaviors in adults, but did not report biological health outcomes (Table 3). ^22^ – ^24^ All of these RCTs were conducted in primary care or primary care equivalent clinic settings (e.g., family planning clinic, university health clinic, family practice setting in Australia). All trials were conducted in urban environments and focused on young adults. Behavioral counseling interventions in these studies ranged from low intensity (e.g., brief single-session counseling) to high intensity (multiple-session counseling up to 18 hours).

Table 3 Behavioral outcomes adults (KQ2)

Study Reference Quality | Setting | Population | Study Intervention | UAI or UVI (without condom unless specified) | Use of condom (male condom unless otherwise specified) | # Of sex partners
Ehrhardt 2002 ^22^ Hoffman 2003 ^61^ Melendez 2003 ^47^ Project FIO Good | Planned Parenthood clinic | N: 360 100% Female African American: 73% Hispanic: 17% with hx STI: 58.3% | Culturally tailored ARRM. IG1: High- 10 hours total; four group sessions plus booster at 9 months; IG2: High- 18 hours total; eight group sessions plus booster at 9 months CG: usual care, assessment only | ‘model predicted’ mean # unprotected acts in past 3 mo text reads IG2 had on average 4 fewer UVI/UAI than control, p=0.00 % maintaining or improving safer sex behavior, OR (adjusted) [underlined: IG1:] 66.4% [underlined: IG2:] 72.7% [underlined: CG:] 61.7% OR (IG2 to CG) 1.65 (0.94, 2.90) | % using condom (male/female) in past 3-mo [underlined: IG1:] NR [underlined: IG2:] 18% increase, p=0.06 [underlined: CG:] NR | NR
Proude 2004 ^23^ Fair | FP practices Australia | N: 312 Male: 29% Race: NR | Physician counseling based on brief risk assessment done by FP during visit; theory not specified. IG: Low- unknown total duration; ‘brief’ individual session CG: usual care, details NR | NR | % Condom use on first sex occasion with new partner [underlined: IG]: 73%(8/11) [underlined: CG]: 77%(10/13) p=0.813 | % New sex partners over past 3 mo (c) [underlined: IG1]: 11/156 [underlined: CG]: 13/156
Wenger 1992 ^24^ Fair | University Health Clinic | N: 370 Male: 28% Caucasian: 61% with hx/dx STI: 23% | ‘Education’; or ‘Education’ plus HIV testing; theory not specified. IG1 & IG2: Moderate- 1 hour total; 1 group session; +/- HIV testing CG: wait list control | % With UVI/UAI with last sex partner 6-mo [underlined: IG1:] 68% [underlined: IG2:] 63% [underlined: CG:] 61% p>0.15 | N | Mean number sex partners in last mo 6-mo [underlined: IG1:] 0.70 [underlined: IG2:] 0.84 [underlined: CG:] 0.72 p>0.15

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

Of the three trials only one showed a reduction in risk sexual behaviors (unprotected sexual intercourse, multiple sex partners) or an increase in consistent condom use. This trial by Ehrhardt et al., ^22^ was conducted in a family planning clinic. The trial showed a decrease at 12 months in self-reported unprotected sexual intercourse and an increase in (male and female) condom use in the extremely intensive counseling intervention arm. The intervention consisted of nine 2-hour group sessions, but not in the less-intensive intervention consisting of five 2-hour group sessions.

Measures of self-reported behavioral outcomes (e.g., unprotected sexual intercourse, condom use, and number of sexual partners) and methods of data collection (e.g., interview or questionnaire) varied amongst trials.

[underlined: Adolescents.] We identified one fair-quality trial that examined the impact of primary care feasible behavioral counseling interventions on reducing self-reported risky sexual behaviors or increasing protective sexual behaviors in adolescents (Table 4). ^25^ This fair-quality RCT was conducted in an HMO, which included both sexually and presexually active adolescents. This RCT did not show an increase in condom use or abstinence at 12 months in male adolescents who received a single 1-hour counseling intervention, compared with those who did not.

Table 4 Behavioral outcomes adolescents (KQ2)

Study Reference Quality | Location Population | Baseline Demographics | Study Intervention/Intensity | UAI or UVI (without condom unless otherwise specified) | Use of condom (male condom unless otherwise specified) | # Of sex partners | Abstinence
Danielson 1990 ^25^ Fair | HMO | N: 1195 Male: 100% African American: <5% Asian pacific islander: <4% | Slide tape program followed by session with health practitioner; theory not specified. IG: Moderate- 1 hour total; 1 individual session CG: wait-list control | % using any contraceptive at most recent intercourse [underlined: IG:] 69.9% [underlined: CG:] 65.8% OR adjusted 1.51, p<0.05 OR adjusted for those who had not been sex active at baseline 2.53, p<0.01 | % using condom at most recent intercourse [underlined: IG:] 33.3% [underlined: CG:] 35.8% | N | Mean % teen male sex active [underlined: IG:] 90% [underlined: CG:] 91% mean % teen male sex active (of those not previously sex active) [underlined: IG:] 30% [underlined: CG:] 34%

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

Pregnant women. We found no studies that met our inclusion criteria that specifically addressed pregnant women. One study by Hobfoll et al. was excluded for poor quality. ^26^

### Study Details

[underlined: Adults.] Three studies meeting our inclusion criteria examined the impact of primary care feasible behavioral counseling interventions on self-reported risky and protective sexual behavior in a nonSTI clinic population. ^22^ – ^24^

Wenger et al. ^24^ conducted a fair-quality RCT at a university health clinic targeting heterosexual university students. Students seeking care at the clinic (n=370) were randomized into one of three arms: one session of small-group education and counseling, counseling plus HIV testing, or usual care plus a list of locations for free anonymous HIV testing. At baseline, participants' average age was 23 years, 28 percent were men, 39 percent were nonwhite, and 23 percent self-reported a history of an STI. With about 90 percent followup in the intervention groups and about 80 percent followup in the control group at 6 months, there was no significant difference between the three groups in the self-report of unprotected sex with previous partner or mean number of sex partners during the previous month.

In our hierarchical approach, we looked in non-US, English-speaking countries when there was not sufficient evidence from US-based studies. We found one article, by Proude et al., ^23^ from Australia that met our inclusion criteria. This fair-quality trial randomized young adults (n=312) in family medicine practices to either receive a brief risk assessment and physician-counseling plus educational pamphlets on sexual risk reduction or tobacco use (active control). At baseline, more than half of patients were aged 22 to 25 years, about 30 percent were men, and 14 percent reported multiple partners during the previous year. At 3 months, with about two-thirds followup, there was no difference in self-reported condom use with new partners (n=24), or in self-reported new sex partners during the previous 3 months.

This third study, Project FIO (The Future is Ours) by Ehrhardt et al., was conducted in an urban family planning clinic. ^22^ Women (n=360) in this good-quality trial were randomized to receive one of two risk reduction behavioral counseling interventions based on the ARRM, or an assessment-only group. The intervention consisted of either four 2-hour group sessions with a booster session at 9 months, or to an eight 2-hour group sessions plus a booster at 9 months. At baseline women were on average 22 years old, 72 percent were African American, 17 percent were Hispanic, and almost 60 percent had a history of an STI. At 12 months, with over 90 percent followup, they found that women in the eight-session intervention group had an average of four fewer unprotected sexual acts during the previous 3 months based on self-report, p=0.00. They also reported an 18 percent increase in self-reported condom (male or female) use in the eight-session intervention group. This result, however, is of borderline statistical significance (p=0.06).

[underlined: Adolescents.] One trial meeting our inclusion criteria examined the impact of primary care feasible behavioral counseling interventions on self-reported risky and protective sexual behavior.

This trial by Danielson et al. examined the impact of a general sexual health intervention that included risk-reduction counseling on high school boys in an urban HMO. ^19^ Adolescents (n=1195) were randomized to either wait-list control or a 1-hour medical appointment with 30 minutes of slide tape program on general sexual health and 30 minutes risk-reduction counseling with health practitioner. Participants at baseline were less than 10 percent nonwhite and 37 percent self-reported being sexually active during the previous year. At 12 months, with about 80 percent followup, there was no difference between the two groups in self-reported condom use or abstinence.

## Key Question 3. Are there other positive outcomes besides sexual behavioral changes and reduced incidence of STI resulting from behavioral counseling interventions to prevent STIs in primary care?

Summary of results. Within the body of literature examined for KQ1 and KQ2, we looked for evidence of other positive outcomes obtained from behavioral counseling interventions. We focused on other positive behavioral or biological outcomes of primary care feasible counseling interventions. We do not discuss outcomes that are primarily psychosocial mediators of behavior (e.g., knowledge, attitude and self-esteem, and ability changes), although these measures were reported in many of our included studies. ^12^ – ^15,^ ^18^ – ^20,^ ^23^ – ^25,^ ^27^

In general, few studies reported on other behavioral or biological outcomes. For adults, we found evidence that behavioral counseling increases compliance with treatment recommendations for women in an STI clinic setting (Table 5). ^16,^ ^17,^ ^22^ For adolescents, we found evidence that behavioral counseling may decrease other risky behavior and pregnancy in sexually active female adolescents, and increase general contraception use in male adolescents (Table 6). ^18^ – ^20,^ ^25^

Table 5 Other positive outcomes adults (KQ3)

Study Reference Quality | Setting | Population | Study Intervention | Other positive Outcomes
Shain 2004 ^17^ Project SAFE 2 Fair | STI clinic | N: 775 (690 in analysis) 100% Female Hispanic: 77% African American: 23% with GC (c):20.6% with chlamydia (c): 77.8% with trichomonas (c): 15.4% with syphilis(c): 4.6% Male: 0% | Culturally tailored ARRM. IG1 & IG2: High- 9 hours total; 3 group sessions +/- optional support group sessions CG: usual care, 15 minute CDC standard counseling | % unprotected sex with untreated or incompletely treated partner at 12 mo [underlined: IG1:] 7.8%, p=0.001 [underlined: IG2:] 10.2%, p=0.01 [underlined: CG:] 18.1%
Shain 1999 ^16^ Project SAFE Good | STI clinic | N: 617 (549 in analysis) 100% Female Hispanic: 69% African American: 31% with GC (c): 22.8% with chlamydia (c): 68.7% with trichomonas (c): 23.7% with syphilis (c): 6.0% | Culturally tailored ARRM. IG: High- 9–12 hours total; 3 group sessions CG: usual care, 15 minute CDC standard counseling | % apply condoms on sex partners (relative % change)
6-mo [underlined: IG:] 2.18 [underlined: CG:] 1.51 45.99% (24.66, 63.86), p<0.001 | 12-mo [underlined: IG:] 1.97 [underlined: CG:] 1.59 28.39% (12.51, 54.7), p=0.003
Ehrhardt 2002 ^22^ Hoffman 2003 ^61^ Melendez 2003 ^47^ Project FIO Good | Planned Parenthood clinic | N: 360 100% Female African American: 73% Hispanic: 17% with hx STI: 58.3% | Culturally tailored ARRM. IG1: High- 10 hours total; four group sessions plus booster at 9 months; IG2: High- 18 hours total; eight group sessions plus booster at 9 months CG: usual care, assessment only | % Alternative risk reduction strategy (# sex occasions; outercourse; refusing sex; leaving relationship; choosing not to get involved with new partner; mutual HIV testing); - text states no difference between groups at 12-mo f/u

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

Table 6 Other positive outcomes adolescents (KQ3)

Study Reference Quality | Setting | Population | Study Intervention/Intensity | Other positive Outcomes
Jemmott 2005 ^20^ Good | Adolescent medicine clinic | N: 682 100% Female African American: 68% Hispanic: 32% with any STI: 21.9 | Culturally tailored skills-based intervention based on cognitive behavioral theories. IG1 & IG2: High- 250 minutes total; one group session; +/- skills training CG: matched general health promotion counseling | mean # of days of sex while intoxicated past 3 mo
3-mo [underlined: IG1:] 0.10, p=0.03 [underlined: IG2:] 0.29, p=0.98 [underlined: CG:] 0.26 | 6-mo [underlined: IG1:] 0.07, p=0.005 [underlined: IG2:] 0.15, p=0.10 [underlined: CG:] 0.31 | 12-mo [underlined: IG1:] 0.42, p=0.37 [underlined: IG2]: 0.53, p=0.65 [underlined: CG:] 0.66
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | % self-reported pregnancy
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | 6-mo [underlined: IG:] 3.6 [underlined: CG:] 7.0 OR 0.38 (0.15–0.96) | 12-mo [underlined: IG:] 6.0 [underlined: CG:] 8.5 OR 0.74 (0.30–1.82)
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% with GC: 5.2% with chlamydia: 17.4% with trichomonas: 13.0% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. IG: High- 4 hours total; 4 group sessions CG: matched nutrition and exercise counseling | % apply condoms on sex partners (relative % change)
6-mo [underlined: IG:] 2.18 [underlined: CG:] 1.51 45.99% (24.66, 63.86), p<0.001 | 12-mo [underlined: IG:] 1.97 [underlined: CG:] 1.59 28.39% (12.51, 54.7), p=0.003
Boekeloo 1999 ^18^ Fair | HMO | N: 219 Male: 50.2% African American: 64% Hispanic: 3% Other race: 14% | Physician counseling based on 15 minute audiotape risk assessment done in waiting period. IG: Low- unknown total duration; ‘brief’ individual session CG: usual care, details NR | % self-reported pregnancy (gotten someone or been pregnant)
baseline, 3-mo [underlined: IG:] 1.0%, 0% [underlined: CG:] 1.8%, 1.9% NS, p>0.05 | baseline, 6-mo [underlined: IG:] 1.0%, 1.1% [underlined: CG:] 1.8%, 5.9% NS, p>0.05
Danielson 1990 ^25^ Fair | HMO | N: 1195 Male: 100% African American: <5% Asian pacific islander: <4% | Slide tape program followed by session with health practitioner; theory not specified. IG: Moderate- 1 hour total; 1 individual session CG: wait-list control | % with partner using pill at most recent sexual intercourse [underlined: IG:] 32.4% [underlined: CG:] 23.9% OR 1.66, p<0.05

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

### Study Details

[underlined: Adults.] In both Project SAFE ^16^ and Project SAFE 2, ^17^ those who received group counseling had increased treatment compliance compared to those who received usual care. In Project SAFE, 15.7 percent of participants in the intervention arm reported unprotected sexual intercourse with untreated or incompletely treated sexual partners, compared with 28.5 percent (p<0.001) in the control arm. Likewise, in Project SAFE 2, 7.8 percent in the intervention arm (p<0.001) reported unprotected sexual intercourse with an untreated/incompletely treated sexual partner, versus 18.1 percent in the control arm.

The trial by Ehrhardt et al. ^22^ targeting women in a family planning clinic reported on other behavioral outcomes as a composite measure of “alternative risk reduction strategy.” These included refusing sex, leaving/ending relationship, and mutual HIV testing. However, there was no significant difference in this composite measure at the 12-month followup.

[underlined: Adolescents.] The trial by Jemmott et al. ^20^ found a significant decrease in self-reported number of days of sex while intoxicated over the past 3 months at their 3-and 6-month followup for those girls in the skills-based counseling intervention arm, compared to those in the health promotion arm. This effect, however, was not statistically significant at the 12-month followup.

The trial by DiClemente et al. ^19^ found a significant decrease in self-reported pregnancy at 6 months for those girls in the intervention group, OR 0.38 (0.15, 0.96). Again, this effect was not significant at the 12 month followup, OR 0.74 (0.30, 1.82).

The trial by Boekeloo et al. ^18^ that targeted young adolescents in an HMO did not find a statistically significant reduction in self-reported pregnancy. This study, however, had a smaller sample size and fewer reported pregnancies.

In the Danielson et al. ^25^ trial, high-school boys in an HMO who received counseling self-reported an increase in any contraception use during their most recent sexual encounter, which appeared to be mediated by partner use of oral contraceptives rather than condom use.

## Key Question 4. What are the adverse effects associated with behavioral counseling interventions to prevent STIs in primary care to reduce risky sexual behaviors and increase protective sexual behaviors?

Summary of results. Within the body of literature examined for KQs 1 and 2, we looked for evidence of harms of primary care feasible behavioral counseling interventions. We found no additional studies meeting our inclusion criteria that assessed behavioral or biological adverse effects of counseling interventions.

[underlined: Adults.] Overall, the nine trials evaluating risk reduction counseling in adult populations showed no evidence of increased incidence of STIs or self-reported risky behaviors, including increased unprotected sex or increased number of sexual partners (Table 7). ^12^ – ^17,^ ^22^ – ^24^ The six trials that reported on biological outcomes showed no evidence of increased incidence of STIs, either by self report or laboratory testing. ^12^ – ^17^ Eight trials showed no evidence of self-reported increased unprotected sex (or decreased use of condoms). ^12^ – ^16,^ ^22^ – ^24^ Six trials showed no evidence of self-reported increase in the number of sexual partners.

Table 7 Adverse effects adults (KQ4)

Study Reference Quality | Setting | Baseline Demographics | Study Intervention | Adverse Outcomes
Carey 2004 ^13^ Fair | Outpatient psychiatric | N: 408 Male: 46% African-American: 21% | HIV harm reduction, motivational techniques to enhance readiness to change. High: unknown total hours; 10 group sessions | No increase in number of sex partners No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self-report)
Shain 2004 ^17^ Project SAFE 2 Fair | STI clinic | N: 690 100% Female Hispanic: 77% African American: 23% | Culturally tailored ARRM. High: 9 hours total; 3 group sessions +/- optional support group sessions | No increase in number of sex partners No increase in STI incidence (by testing)
Scholes 2003 ^15^ Fair | Medical clinic | N: 1210 100% Female African American: 19% Other race: 12% | Individually tailored self-help printed materials based on multiple social science theories. Low: 2 mailings, 12-page booklet and booster newsletter | No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self report)
Ehrhardt 2002 ^22^ Project FIO Good | Planned Parenthood clinic | N: 360 100% Female African American: 73% Hispanic: 17% | Culturally tailored ARRM. High: 18 hours total; eight group sessions plus booster at 9 months | No increase in unprotected sex or decrease in condom use
Shain 1999 ^16^ Project SAFE Good | STI clinic | N: 617 (n=549 in analysis) 100% Female Hispanic: 69% African American: 31% | Culturally tailored ARRM. High: 9–12 hours total; 3 group sessions | No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self report)
Kamb 1998 ^14^ Project RESPECT Fair | STI clinics | N: 5758 Male: 57% African American: 59% Hispanic: 19% Other race: 6% | CDC's client centered HIV prevention counseling model; or enhanced version using theory of reasoned action and social cognitive theory. Moderate: 40 minutes total; 2 individual sessions. High: 200 minutes total; 4 individual sessions | No increase in number of sex partners No increase in unprotected sex or decrease in condom use No increase in STI incidence (by testing)
Boyer 1997 ^12^ Fair | STI clinic | N: 393 Male (c): 67% African American: 46% Hispanic: 15% Other race: 10% | ARRM. High: 4 hours total; 4 individual sessions | No increase in unprotected sex or decrease in condom use. No increase in STI incidence (by self-report) No increase in number of sex partners
Wenger 1992 ^24^ Fair | University Health Clinic | N: 370 Male: 28% White: 61% | ‘Education’; or ‘Education’ plus HIV testing; theory not specified. Moderate: 1 hour total; 1 group session | No increase in number of sex partners No increase in unprotected sex or decrease in condom use
Proude 2004 ^23^ Fair | FP practices Australia | N: 312 Male: 29% Race: NR | Physician counseling based on brief risk assessment done by FP during visit; theory not specified. Low: unknown total duration; ‘brief’ individual session | No increase in number of sex partners No increase in unprotected sex or decrease in condom use

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

[underlined: Adolescents.] Overall, the five trials evaluating risk-reduction counseling in adolescents showed no evidence of increased incidence of STIs or self-reported risk behaviors including increased unprotected sex, increased number of sexual partners, or earlier onset of sexual debut (Table 8). ^18^ – ^20,^ ^25^ No trials evaluating abstinence-only counseling interventions met our inclusion criteria. Therefore, we could not assess potential harms or benefits associated with these types of counseling interventions. The four trials that reported on biological outcomes showed no evidence of increased incidence of STIs, either by self-report or laboratory testing. ^18^ – ^20,^ ^25^ Five trials showed no evidence of an increase in self-reported unprotected sex (or decreased use of condoms). ^18^ – ^20,^ ^25^ Two trials showed no evidence of an increase in the participants' self-reported number of sexual partners. ^14,^ ^20^

Table 8 Adverse effects adolescents (KQ4)

Study Reference Quality | Setting | Baseline Demographics | Study Intervention | Adverse Outcomes
Jemmott 2005 ^20^ Good | Adolescent medicine clinic | N: 682 100% Female African American: 68% Hispanic: 32% | Culturally tailored skills-based intervention based on cognitive behavioral theories. High: 250 minutes total; one group session | No increase in number of sex partners No increase in unprotected sex or decrease in condom use No increase in STI incidence (by testing)
DiClemente 2004 ^19^ Good | Community health agencies | N: 522 100% Female African American: 100% | Culturally tailored social cognitive theory and theory of gender and power; with peer co-facilitators. High:4 hours total; 4 group sessions. | No increase in unprotected sex or decrease in condom use No increase in STI incidence (by testing)
Boekeloo 1999 ^18^ Fair | HMO | N: 219 Male: 50.2% African American: 64% Caucasian: 19% Hispanic: 3% Other race: 14% | Physician counseling based on 15 minute audiotape risk assessment done in waiting period. Low: unknown total duration; ‘brief’ individual session | INCREASE in % having vaginal sex at 3mo but NOT at 9mo (at 6 mo: IG=27%, CG=20%, OR -2.46 (1.04, 5.84)) No increase in overall sex (vaginal, oral, and anal sex) No increase in unprotected sex or decrease in condom use No increase in STI incidence (by self report)
Danielson 1990 ^25^ Fair | HMO | N: 1195 Male: 100% African American: <5% Asian pacific islander: <4% | Slide tape program followed by session with health practitioner; theory not specified. Moderate: 1 hour total; 1 individual session | No increase in unprotected sex or decrease in condom use No earlier sexual debut

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

One trial by Boekeloo et al. ^18^ showed a transient increase in self-reported vaginal sex at 3 months, but not at 9 months, in adolescents aged 12 to 15 years. There was no increase, however, in self-reported overall sexual intercourse (vaginal, oral, or anal sex).

### Study Details

[underlined: Adolescents.] Only one study, by Boekeloo et al., showed possible harms for risk-reduction behavioral counseling in adolescents. ^18^ This fair-quality RCT, in which 12 to 15 year old adolescents (n=219) from an urban HMO were assigned to either usual care or a 15-minute, standardized, self-risk assessment, and physician discussion of risk, reported that adolescents in the intervention group self-reported more vaginal sexual intercourse at 3 months compared with adolescents receiving usual care, adjusted OR 2.46, 95 percent CI (1.04, 5.84). This effect, however, was not observed at the 9-month followup. In addition, no difference was observed in self-report of “any” sexual intercourse (including vaginal, oral or anal sex) at either followup.

Three of the five studies were conducted in sexually active adolescent populations. ^19,^ ^20,^ ^25^ One of the two trials conducted in a general adolescent population reported on sexual debut. ^25^ This fair-quality RCT of 15- to 18-year-old adolescent boys, 37 percent of whom self-reported being sexually active during the previous year, found no evidence that risk reduction counseling increased sexual activity in those previously not sexually active. The proportion of boys not sexually active at baseline, who became sexually active during the following year, was 30 percent in the intervention group, compared with 34 percent in the wait-list control group.

## Key Question 5. Do sexual behavioral changes, including reducing risky sexual behaviors and increasing protective sexual behaviors, lead to a reduced incidence of STIs and/or related morbidity and mortality?

Summary of results. Based on the findings from KQ 2 that behavioral counseling can increase both male and female condom use, we examined the effectiveness of female condoms in reducing the incidence and transmission of STIs. We did not reexamine the effectiveness of male condoms for the prevention of STIs, which has been previously established.

We found four trials examining the effectiveness of female condoms in reducing the incidence of STIs (Table 9). One study by Soper et al. was excluded for poor quality. ^28^ The remaining three studies were RCTs comparing the effectiveness of female plus male condom use compared to male condom use alone. ^29^ – ^31^ Only one study was conducted in the US, the other two were conducted in Kenya and Thailand. All three studies suggest that counseling women to use female condoms and providing female condoms offers similar protection against bacterial STIs as counseling women to use male condoms. Although none of these trials were powered as non-inferiority studies, there were no statistical differences in the incidences of bacterial STIs between the women using female and male condoms versus the women only using male condoms. The percentages of women using female condoms were consistently low in the two trials that report on female condom use

Table 9 Female condom effectiveness (KQ5)

Study Reference Quality | Study Design Location Target population | Population | Study Intervention | Outcomes/Results
French 2003 ^31^ Fair | RCT US; urban STI clinic Adult, female; low-income, minority | N : 1442 % Female: 100% % African American: 86% | IG: small group sessions; 10–20 minutes; given free female condoms during study period. Encouraged to use the female condom during vaginal and anal sex and were instructed to purchase flavored male condoms for oral sex (not advised to stop using other methods). CG: format same as IG, encouraged to use male condoms during all types of sexual intercourse (not encouraged to stop using any other method of protection) | STI diagnosed at follow-up (gonorrhea, chlamydia, early syphilis, trichomonas)
French 2003 ^31^ Fair | RCT US; urban STI clinic Adult, female; low-income, minority | N : 1442 % Female: 100% % African American: 86% | | IG: 12.4%(106/855) | CG: 15.8%( 93/587)
French 2003 ^31^ Fair | RCT US; urban STI clinic Adult, female; low-income, minority | N : 1442 % Female: 100% % African American: 86% | | OR (unadjusted)- 0.75 (0.56–1.01), p=0.06 STI incidence (per 100 women months) at follow-up
French 2003 ^31^ Fair | RCT US; urban STI clinic Adult, female; low-income, minority | N : 1442 % Female: 100% % African American: 86% | | IG: 6.8 | CG: 8.5
OR- 0.79 (0.59–1.06), p=0.11
Fontanet 1998 ^30^ Fair | RCT Thailand; urban Sex establishments Adult; Female; sex workers | N: 504 % Female: 100% Race: NR | IG: male/female condom group; option of using female condom when clients refused or could not use a male condom; given free supply of condoms. CG: male condom group; if clients refused or could not use male condoms, they were instructed not to have sex; given free supply of condoms (same as IG) | STI (gonorrhea, chlamydia, trichomonas, genital ulcer disease) Incidence (per 100 woman weeks)
Fontanet 1998 ^30^ Fair | RCT Thailand; urban Sex establishments Adult; Female; sex workers | N: 504 % Female: 100% Race: NR | | IG: 2.81 | CG: 3.69
Fontanet 1998 ^30^ Fair | RCT Thailand; urban Sex establishments Adult; Female; sex workers | N: 504 % Female: 100% Race: NR | | Incidence rate ratio (95% CI): 0.76 (0.50–1.16) Percent with acts female condom
IG: 12.0% | CG: 0%
Feldblum 2001 ^29^ Feldblum 2000 ^62^ Good | Cluster RCT Kenya; rural Agricultural sites Adult, female; employed as agricultural worker | N: 1929 % Female: 100% Race: NR | IG: Outreach program with individual counseling, given male and female condoms for all adults. CG: Similar prevention program excluding information on female condoms, only given male condoms | Crude prevalence of STI (gonorrhea, chlamydia, or trichomonas)
Feldblum 2001 ^29^ Feldblum 2000 ^62^ Good | Cluster RCT Kenya; rural Agricultural sites Adult, female; employed as agricultural worker | N: 1929 % Female: 100% Race: NR | IG: Outreach program with individual counseling, given male and female condoms for all adults. CG: Similar prevention program excluding information on female condoms, only given male condoms | [underlined: Baseline] IG: 22.1% CG: 25.6% | [underlined: 6-mo] IG: 17.1% CG: 17.6% | [underlined: 12-mo] IG: 18.2% CG: 18.4%
Feldblum 2001 ^29^ Feldblum 2000 ^62^ Good | Cluster RCT Kenya; rural Agricultural sites Adult, female; employed as agricultural worker | N: 1929 % Female: 100% Race: NR | IG: Outreach program with individual counseling, given male and female condoms for all adults. CG: Similar prevention program excluding information on female condoms, only given male condoms | OR (adjusted) IG: OR- 1.1 (0.8, 1.6- 1.0) CG: OR- 1.0 % Consistent female condom use
[underlined: 6-mo] IG=11% CG=NA | [underlined: 12-mo] IG: 7% CG: NA

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

Table 10 Summary of evidence

No. of studies | Design | Limitations | Consistency | Applicability | Overall Quality | Summary of Findings | Comment
KQ1. biological outcomes
Adults
6 ^12^ – ^17^ | RCT | Limited number of trials with significant heterogeneity in populations and interventions. | Inconsistency between STI clinic and non-STI clinic setting and intensity of intervention. | Trials conducted in urban areas; 4 trials in predominantly AA and/or Hispanic adults; 4 trials in STI clinics; 1 trial in a psychiatric clinic | Fair-Good | Three of the six trials (n=7150) showed a moderate reduction in STI incidence at 12 months among adults in STI clinics receiving moderate to high-intensity counseling interventions. One trial (n=393) did not show a reduction in STI incidence at 6 months in adults attending an STI clinic receiving a high-intensity counseling intervention. One trial in a psychiatric clinic (n=408) showed a moderate reduction in self-reported STI incidence using a high-intensity counseling intervention. One trial (n=1210) did not show a reduction in self-reported STIs in adults receiving a low-intensity counseling intervention. | Self-reported measures of STI outcomes should be interpreted cautiously
Adolescents
4 ^14^ – ^18^ – ^21^ | RCT | Limited number of trials with significant heterogeneity in populations and interventions. | Inconsistency between sexually active adolescents and general adolescent population and intensity of intervention. | Trials conducted in urban areas in predominantly AA and/or Hispanic adolescents | Fair-Good | [underlined: Sexually active adolescents]: All three trials (n=1998) showed a modest reduction in laboratory diagnosed STI incidence at 12 months in sexually active adolescents receiving moderate to high-intensity counseling interventions. [underlined: Pre-sexually and sexually active adolescents]: One trial (n=219) did not show a reduction in self-reported STI incidence at 3 or 9 months in young adolescents receiving a low-intensity counseling intervention. | One of the 4 trials is a subgroup analysis by age group of Project RESPECT Self-reported measures of STI outcomes should be interpreted cautiously
KQ2. behavioral outcomes
Adults
3 ^22^ – ^24^ | RCT | Limited number of trials with significant heterogeneity in populations, interventions, and measurement of outcomes. | Inconsistency by intervention intensity and population risk. | Trials conducted in urban areas; 1 trials in predominantly AA and/or Hispanic adults; 1 trial in a university health clinic; 1 trial in Australia | Fair | Two of the three trials did not show a decrease in self-reported risky sexual behavior (i.e. unprotected sexual intercourse or multiple sex partners or increase in self-reported male condom use) in adults receiving low to high-intensity counseling interventions. Only one trial showed a decrease in self-reported unprotected sexual intercourse and increase in self-reported (male and female) condom use at 12 months in women with a high percentage of previous STI, receiving a very high-intensity counseling intervention (18 hours), but not a high-intensity counseling intervention (10 hours).
Adolescents
1 ^19^ | RCT | Only one study. | N/A | High school boys in urban HMO setting | Fair | [underlined: Pre-sexually and sexually active adolescents]: This study did not show an increase in condom use or abstinence at 12 months in male adolescents receiving a moderate-intensity counseling intervention.
KQ3. other positive outcomes
Adults
3 ^16,^ ^17,^ ^22^ | RCT | Limited number of trials with significant heterogeneity in populations and interventions | No inconsistencies | Trials conducted in urban areas in predominantly AA and/or Hispanic adults | Fair | Two trials conducted in STI clinics found that women receiving high-intensity group counseling also had increased STI treatment compliance, as measured by self-reported unprotected intercourse with untreated or incompletely treated sex partner. Another trial did not show an increase in self-reported ‘alternative risk reduction’ strategies with high-intensity group counseling at 12 months.
Adolescents
4 ^18^ – ^20,^ ^25^ | RCT | Limited number of trials with significant heterogeneity in populations and interventions. | No serious inconsistencies | Trials conducted in urban areas; 3 trials in predominantly AA and/or Hispanic adolescents | Fair | [underlined: Sexually active adolescents]: One trial showed a decrease in self-reported sex while intoxicated at 3 and 6 months, but not at 12 months in female adolescents receiving high-intensity group counseling. Another trial showed a decrease in self-reported pregnancy at 6 months, but not at 12 months, in female adolescents receiving high-intensity group counseling. [underlined: Pre-sexually and sexually active adolescents]: One trial did not show a statistically significant decrease in self-reported pregnancy in adolescents receiving a low-intensity counseling intervention, which also had a smaller sample size and fewer reported pregnancies. Another trial showed an increase in general contraception use in male adolescents receiving a moderate-intensity counseling intervention.
KQ4. adverse effects
Adults
9 ^12^ – ^17,^ ^22^ – ^24^ | RCT | Limited number of trials with significant heterogeneity in populations, interventions, and measurement of outcomes. | No inconsistencies | Trials conducted in urban areas; 6 trials in predominantly AA and/or Hispanic adults; 4 trials in STI clinics; 1 trial in a psychiatric clinic, 1 trial in a university health clinic; 1 trial in Australia | Fair-Good | Overall, no increase in number of sexual partners, unprotected sexual intercourse or STI incidence by testing or self-report with low- to high-intensity counseling interventions. | .
Adolescents
4 ^18^ – ^20,^ ^25^ | RCT | Limited number of trials with significant heterogeneity in populations, interventions, and measurement of outcomes. | No serious inconsistencies | Trials conducted in urban areas; 3 trials in predominantly AA and/or Hispanic adolescents | Fair-Good | [underlined: Sexually active adolescents]: Overall, no increase in number of sexual partners, unprotected sexual intercourse, or STI incidence by testing or self-report with high-intensity counseling interventions. Pre-sexually and sexually active adolescents: One study showed a transient increase of vaginal sex in young adolescents receiving a low-intensity counseling intervention at 3 months, OR 2.46, 95%CI (1.04–5.84); but NOT at 9 months, and no increase in overall sexual activity at either followup. Another study in an HMO setting showed no evidence of earlier sexual debut in male adolescents receiving a moderate-intensity counseling intervention. | Risk reduction counseling only.
KQ5. female condoms
3 ^29^ – ^31^ | 1 RCT, 2 cluster RCT | Limited number of trials with significant heterogeneity in populations and interventions. | No inconsistencies | One in US STI clinic; one in Thai sex workers in Thailand; and one in rural Kenya | Fair | All three studies suggest that counseling women to use female condoms and providing female condoms in addition to male condoms offers similar protection against bacterial STIs as counseling women to use male condoms and providing male condoms. | Overall use of female condoms was low- about 7 percent of women in the Kenyan RCT and 12% of sex acts in the Thai RCT.

Abbreviations: GC= Gonorrhea; HSV= Herpes simplex virus; HPV= human papilloma virus; BV= bacterial vaginosis; ARRM= AIDS Risk Reduction Model; dx= diagnosed; RR= Relative Risk; OR= Odds Ratio; IG= Intervention Group; CG= Control Group; hx= history' (c)= calculated; NR= not reported; FP= family practice

Study Details. The RCT by French et al. is the only fair-quality study in the US that directly examined the effectiveness of female condom use in reducing the incidence of STIs. ^31^ Women attending an urban public STI clinic (n=1442) were randomized into one of two interventions, either a 20-minute, small-group, interactive counseling session on using female condoms (in which the women were instructed to use male condoms for oral sex, and not advised to stop using other methods), or a similarly formatted counseling session on using male condoms. All the women were given a free supply of their assigned condoms. Only approximately 50 percent of women returned for additional STI testing (gonorrhea, chlamydia, syphilis, and trichomonas) during the 1-year followup period. Among those who had followup, there was no statistically significant difference in STI incidence between the two groups. The percent of women using female condoms was not reported.

One good-quality study by Feldblum et al., ^29^ conducted in rural Kenya, randomized twelve agricultural sites representing 1929 women to either a multi-faceted program with community level education and individual counseling to promote female and male condom use or a similar program excluding female condom information. All adults were provided with female and male condoms, or only male condoms, respectively. These communities had 82 percent followup at both 6- and 12-month followup assessments. There was no significant difference in STI prevalence (gonorrhea, chlamydia, and trichomonas) between programs at either 6 or 12 months. Only 11 percent of women at 6 months and 7 percent of women at 12 months consistently used female condoms. As female condom use declined at 12 months, however, consistent male condom use increased, from 14 percent to 22 percent in the female condom intervention communities. Overall, there was a low percentage of consistent condom use in all communities.

One fair-quality study by Fontanet et al. conducted in urban Thailand randomized four ^30^ commercial sex establishments, representing 548 female sex workers to either male condoms plus female condoms or only male condoms. In the female condom intervention sites, women were instructed to use female condoms when clients refused or could not use a male condom. In the male condom only sites, women were instructed not to have sex if clients refused or could not use a male condom. Again, women were provided with condoms. At 24 weeks (6 months), 96 percent of women in the female condom group versus 88 percent of women in the male condom only group had followup. There was no statistically significant difference in the STI incidence, OR (95 percent CI), for female plus male condom, versus male condom alone 0.76 (0.50, 1.16). In the female condom intervention sites, female condoms were used in only 12 percent of sex acts, and male condoms were used in about 88 percent of sex acts.