# Methods

## Update Key Questions and Analytic Framework

Using the USPSTF's methods, ^11^ we developed an analytic framework (Figure 1) that included five updated key questions (KQs) to guide our literature search and systematic review. KQ1 examined the direct evidence that primary care feasible behavioral counseling interventions to reduce risky sexual behaviors or increase protective sexual behaviors reduce the incidence of STIs, including HIV, or their related morbidity and mortality. KQ2 examined if these behavioral counseling interventions reduce risky behaviors or increase protective sexual behaviors that impact the transmission of STIs. Trials that met inclusion for KQ1 (i.e., reported on STI incidence as an outcome measure), were not included in KQ2, even if they reported on behavioral outcome measures. KQ3 examined if these behavioral counseling interventions have other positive behavioral or biologic outcomes, other than change in sexual behaviors and STI incidence. KQ4 examined if these behavioral counseling interventions can cause any adverse behavioral or biologic outcomes. For KQ3 and KQ4, we did not consider outcome measures of knowledge, attitudes, self-esteem, ability changes, or self-efficacy. KQ5 examined if any behavioral change outcomes identified in KQ2 were associated with a decrease in STI incidence. Based on our findings in KQ2, we focused KQ5 on the evidence for female condoms use. We did not reconsider the evidence for male condom use or abstinence, both of which the USPSTF previously judged as adequate in 1996.

Figure 1. Analytic framework

In addition to our systematic review of the above key questions, we also address two contextual questions that the USPSTF defined as important to interpreting the evidence. These included: what are possible socio-cultural or health care system factors that mediate the effect of these behavioral counseling interventions, and what is the cost-effectiveness of these behavioral counseling interventions. In contrast to key questions, evidence for contextual questions were not systematically reviewed.

## Literature Search Strategy

We developed literature search strategies and terms for each KQ (Appendix A, Table 1) and conducted two separate literature searches (Search one was for KQ1, KQ2; and Search two was for KQ5). For behavioral counseling interventions that met our inclusion criteria for KQ1 and KQ2, we examined if there were other positive (KQ3) or potentially harmful (KQ4) behavioral or biological outcomes. Because we limited our search for potential adverse effects to behavioral or biological outcomes, which are the paradoxical effects of beneficial outcomes (i.e., increase in risky sexual behavior rather than a decrease in risky sexual behavior), we used the same study design criteria for beneficial (KQ1, 2, 3) and harmful (KQ4) outcomes. Therefore, we were able to use a single, broad search strategy for KQ1, 2, 3, and 4.

For KQs 1 and 2, we searched Medline (ML), Cochrane Central Registry of Controlled Trials (CCRCT), Cochrane Database of Systematic Reviews (CDSR), PsycINFO (PI), and the CDC's Prevention Synthesis Research (PRS) Project's database from 1988 to December 31, 2006. We explicitly chose to examine the literature since 1988 because it marks the initial year for published studies on sexual behavioral counseling in the post-HIV era. Our approach is consistent with both the CDC's Guide to Community Preventive Services and the PRS Project. For KQ5, we searched ML and CCRCT from 1988 to August 2006. KQ5 focused on the effectiveness of female condoms, which were first manufactured in 1988. Literature searches were supplemented with outside source material from experts in the field and from examining the bibliographies of existing systematic reviews on this topic (Appendix A Table 4).

While we did not conduct systematic searches for contextual questions, we searched the National Health Service Economic Evaluation Database (NHSEED) through October 2006 for any articles related to cost-effectiveness.

## Article Review and Data Abstraction

We reviewed all abstracts for potential inclusion for any of the KQs using the inclusion/exclusion criteria described in Appendix A, Table 2. To be included, a study had to evaluate a primary care feasible behavioral counseling intervention addressing sexual behavior change (e.g., sexual risk reduction or sexual risk avoidance) with the primary intention of preventing STI transmission. Consistent with the USPSTF's scope, behavioral counseling interventions needed to be conducted in primary care settings, or judged to be feasible for delivery in primary care based. In general, primary care feasible counseling interventions had to involve individual-level participant identification; a primary care practitioner or related clinical staff; and individual or small-group format, with a limited number of sessions, or at a minimum be viewed as connected to the health care system. Behavioral counseling interventions that included an active component of community outreach, use of community members (e.g., opinion leaders, peer facilitators), use of community programs (e.g., worksite programs, school programs), use of social marketing, or use of public policy changes were not considered primary care feasible. School- and university-based trials were excluded unless conducted in a school- or university-based health clinic. (see Appendix A Table 2 for criteria details).

We also required that studies evaluating primary care feasible behavioral counseling interventions be conducted in populations representative of primary care patients. Therefore, we excluded studies that exclusively enrolled participants from correctional facilities, substance-abuse-treatment facilities, HIV clinics, and inpatient hospital units.

For inclusion, studies had to report either biological (e.g., STI incidence) or behavioral outcomes at 3 months after the counseling intervention or later. We excluded studies only reporting outcomes centered around knowledge, attitudes, self-esteem, and ability changes (skills).

All included studies were limited to those reported in English language. For KQs 1, 2, 3, and 4, studies were also limited to those conducted in English-speaking countries with cultural similarity to the US (e.g., Australia, Canada, New Zealand, and United Kingdom). For KQ5, studies were not limited to English-speaking countries. The study design was limited to randomized controlled trials (RCTs) and controlled clinical trials (CCTs). For KQ5, however, we included comparative observational research designs in addition to RCTs and CCTs. We excluded trials of comparative effectiveness (i.e., trials without a control arm). Trials had to include a control arm with no intervention (e.g., wait-list control, usual care), minimal intervention (e.g., usual care limited to no more than 15 minutes of information), or matched control (e.g., similar format and intensity intervention on a different content area).

Two investigators independently screened all abstracts for potential inclusion. We reviewed a total of 2776 abstracts and 278 complete articles for KQs 1, 2, 3, and 4. We reviewed 190 abstracts and 15 complete articles for KQ5. Two investigators independently rated all articles meeting inclusion criteria for quality assessment (30 articles) using the USPSTF's study-design specific quality criteria (Appendix A Table 3). All poor-quality studies were excluded. Listings of all excluded articles are included in Appendix C. Aside from quality, the most common reasons for articles exclusion included interventions not judged to be primary care feasible or relevant and comparative effectiveness designs. A QUORUM tree of reviewed abstracts and articles is included in Appendix A Figure 1.

This review included 19 articles representing 13 unique trials for KQs 1, 2, and 3, and three articles for KQ 4. One primary reviewer abstracted relevant information into standardized evidence tables for each included article (Appendix B). A second reviewer checked the abstraction process.

## Literature Synthesis

We were unable to conduct quantitative synthesis for any key question due to the heterogeneity of intervention methods, populations addressed, and settings. Instead, we qualitatively synthesized our results within categories focusing first on the population(s) addressed, and second on the setting in which the population was identified and the counseling intervention delivered. The results text and corresponding summary tables reflect these qualitative summaries.

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the scope, analytic framework, and key questions; to resolve issues around the review process; and to finalize the evidence synthesis. The Agency for Healthcare Research and Quality (AHRQ) funded this research under a contract to support the work of the USPSTF. AHRQ staff provided project oversight, reviewed the draft report, and assisted in external review of the draft evidence synthesis.