# Introduction

## Scope and Purpose

This systematic review was undertaken to support the USPSTF in updating its prior recommendation on sexually transmitted infection (STI) counseling. ^1^

We examined the evidence for the benefits and harms of counseling primary care patients to prevent sexually transmitted infections (STIs), including Human Immunodeficiency Virus (HIV). Our review includes studies evaluating behavioral counseling interventions conducted in primary care, or judged to be feasible for delivery in primary care. We defined behavioral counseling interventions as any intervention that included some provision of education, skills training, and support providing guidance to clients/patients on how to change sexual behavior, delivered alone or in combination with other interventions intended to promote sexual risk reduction or risk avoidance. We included studies targeting adults (e.g., general and “at-risk” populations), adolescents (e.g., sexually active and pre-sexual debut), and pregnant women. This review summarizes the current state of the evidence relevant to primary care clinicians and identifies key gaps in this scientific literature.

## Condition Definition

An STI is any bacterial or viral illness that is transmitted through sexual contact, including, but not limited to, anal, vaginal, or oral sex. Common STIs in the US include HIV, Hepatitis B, Hepatitis C, Herpes simplex virus 1 and 2 (HSV 1 and 2), Human papillomavirus (HPV), Chlamydia trachomatis, Neisseria gonorrhea, Treponema pallidum (Syphilis), and Trichomonas vaginalis.

In addition to sexual contact, there are other methods by which the bloodborne STIs (HIV, Hepatitis B and C) can be acquired, including maternal-fetal transmission, transfusions, inadvertent needlesticks, and sharing needles or injection equipment with an infected person. This report does not address these methods of transmission or the counseling measures that could potentially reduce them.

## Burden of Preventable Illness

Despite advances in both prevention and treatment, STIs remain a significant cause of morbidity and mortality in the United States. The Center for Disease Control and Prevention (CDC) estimates that 19 million new infections occur each year, almost half of which occur among people ages 15 to 24 years. ^2^ STI rates in the US exceed those in all other industrialized countries, including countries in western and northern Europe, Canada, Japan, and Australia. The rates also exceed the US benchmarks set by Healthy People 2010 goals. Of the reported bacterial STIs, chlamydia is currently acquired at a rate of 320 new cases per 100,000 persons a year; gonorrhea at 114 new cases per 100,000 persons a year; and, syphilis at 2.8 new cases per 100,000 persons. This is complicated by the fact that these rates are likely an underestimate given underreporting of STIs. Of the reported viral STIs, an estimated forty-five to fifty million Americans have herpes simplex virus (HSV), with about one million new cases occurring each year. High risk human papillomavirus (HPV) infections (e.g., types 16 and 18) currently affect about 22 percent of women, and it is estimated that 50 percent of all sexually active persons will acquire some form of HPV during their lifetime. ^3^ While the annual number of new HIV cases has been relatively stable over the past five years, this number remains high at 40,000 per year. These rates are more troubling when viewed with the fact that an estimated 25 percent of these individuals are unaware of their positive status. ^4^ STIs reap significant economic cost, as the direct medical costs associated with STIs in the United States are estimated at $13 billion annually. ^5^

## Risk Factors

Level of risk and risk factors for STI acquisition can be divided into individual risk factors and population risk factors. Individual risk factors are based on an individual's engagement in risky behaviors (e.g., sex with multiple or new partners, sex with high-risk partners, unprotected sex, sex while intoxicated, sex in exchange for money). These behaviors are theoretically influenced by an individual's preexisting knowledge, attitudes, skills, self-efficacy, and the presence of environmental factors that promote, reinforce, or inhibit change. Therefore, risk factors based on an individual's risky behavior are generally considered modifiable. Population risk factors are based on the higher than average incidence of STIs in a particular epidemiologic group, or the increased morbidity of STIs in a particular group (e.g., pregnant women). Higher-risk population groups for STIs in the US include adolescents and young adults, African Americans, Hispanics, men who have sex with men (MSM), military recruits, inmates and former inmates, intravenous drug users (IVDUs) and former IVDUs, sex workers, mentally ill persons, mentally disabled persons, persons living in low-income urban areas, persons living in the southern United States, persons with a history of an STI, and pregnant women.

## Current Practice

Several national organizations, including the USPSTF and the CDC, recommend periodic sexual risk assessment to determine which patients are most likely to benefit from STI screening or prompt risk-reduction counseling. There remains great variability, however, in taking a sexual history and risk assessment in clinical practice. From individual studies, it appears that the proportion of providers taking sexual histories or documenting sexual histories ranges from less than 50 percent to about 90 percent. Two national population surveys indicated that only 28 percent of adults aged 18–64 years reported being asked about STIs during routine visits, and only 15 percent of women of reproductive age said they discussed STIs at their first obstetric and gynecologic visit. ^6^

In general, sexual-risk-reduction counseling in primary care appears to be low. In one primary care practice, an independent, random sample of charts showed that only 45 percent of all patients under 45 years old had received counseling on condom use. In other studies conducted in the private sector setting, STI counseling was only documented for about one third of all visits in which HIV or other STI testing was performed, although lack of documentation could be a factor in these studies. ^6^ In a random-digit-dialing phone survey of low-income adolescents, only 50 percent reported being counseled on STIs. ^7^ A survey of primary care physicians showed that only 40 percent of physicians reported screening all their adolescent patients for sexual activity, and only 31 percent reported educating their adolescent patients about STI transmission. ^8^ In a survey of colleges and universities, about 60 percent of schools had health centers, most of which provided “some” STI prevention education. ^9^

Perhaps the most pervasive provider-based barriers to sexual risk assessment and sexual-risk-reduction counseling for STIs in primary care include lack of time, lack of support staff, and low confidence in the effectiveness of their STI prevention message. In a survey of primary care providers in the private sector, about one third reported lack of time to elicit sexual histories or address STIs and limited number of staff members to counsel patients. ^6^ In another survey of primary care providers, while 89 percent felt comfortable discussing sex-related issues with patients, 70 percent believed that their counseling was ineffective, 48 percent believed their medical school STI training was inadequate, and 43 percent believed they were not responsible for STI preventive services. ^10^ Other commonly cited barriers include patient concerns and discomfort around discussing sexual issues with health care providers; provider discomfort discussing sexual issues; insufficient or nonconfidential reimbursement methods for risk assessment and counseling; difficulty keeping up with revised recommendations for STI screening and treatment; lack of explicit policies and protocols for STI care in general; lack of provider feedback and reminder systems; legal concerns about reporting sexual activity of minors; and lack of demand for quality improvement of STI care. ^6^

## Previous USPSTF Recommendation

In 1996, the USPSTF presented the following recommendations about counseling for HIV and other STIs:

All adolescent and adult patients should be advised about risk factors for human immunodeficiency virus (HIV) infection and other sexually transmitted diseases (STDs), and counseled appropriately about effective measures to reduce the risk of infection. Counseling should be tailored to the individual risk factors, needs, and abilities of each patient. This recommendation is based on the proven efficacy of risk reduction, although the effectiveness of clinician counseling in the primary care setting is uncertain....

All adolescent and adult patients should be advised about risk factors for STDs and counseled appropriately about effective measures to reduce risk of infection (B recommendation). This recommendation is based on the proven efficacy of risk reduction, although the effectiveness of clinical counseling in the primary care setting has not been evaluated adequately (C recommendation). ^1^

The USPSTF used a different methodology and rating system to evaluate evidence for recommendations in 1996. Using the USPSTF's current methodology, this B/C recommendation might have received an “I” rating for insufficient evidence to recommend for or against routinely providing counseling.