# References

1 National Cancer Institute Surveillance Epidemiology and End Results Program. Cancer Stat Fact Sheets-Cancer of the Prostate. 2006. Accessed at http://seer.cancer.gov/statfacts/html/prost.html on 5 June 2008.
2 Jemal A, Siegel R, Ward E, Murray T, Xu J, Thun MJ. Cancer statistics, 2007. CA Cancer J Clin. 2007;57:43-66. [PMID: 17237035]. [pmid: 17237035].
3 Collin SM, Martin RM, Metcalfe C, Gunnell D, Albertsen PC, Neal D, et al. Prostate-cancer mortality in the USA and UK in 1975-2004: an ecological study. Lancet Oncol. 2008;9:445-52. [PMID: 18424233]. [pmid: 18424233].
4 Farwell WR, Linder JA, Jha AK. Trends in prostate-specific antigen testing from 1995 through 2004. Arch Intern Med. 2007;167:2497-502. [PMID: 18071173]. [pmid: 18071173].
5 Welch HG, Schwartz LM, Woloshin S. Prostate-specific antigen levels in the United States: implications of various definitions for abnormal. J Natl Cancer Inst. 2005;97:1132-7. [PMID: 16077071]. [pmid: 16077071].
6 Aus G, Damber JE, Khatami A, Lilja H, Stranne J, Hugosson J. Individualized screening interval for prostate cancer based on prostate-specific antigen level: results of a prospective, randomized, population-based study. Arch Intern Med. 2005;165:1857-61. [PMID: 16157829]. [pmid: 16157829].
7 Catalona WJ, Partin AW, Slawin KM, Brawer MK, Flanigan RC, Patel A, et al. Use of the percentage of free prostate-specific antigen to enhance differentiation of prostate cancer from benign prostatic disease: a prospective multicenter clinical trial. JAMA. 1998;279:1542-7. [PMID: 9605898]. [pmid: 9605898].
8 Catalona WJ, Richie JP, deKernion JB, Ahmann FR, Ratliff TL, Dalkin BL, et al. Comparison of prostate specific antigen concentration versus prostate specific antigen density in the early detection of prostate cancer: receiver operating characteristic curves. J Urol. 1994;152:2031-6. [PMID: 7525994]. [pmid: 7525994].
9 Fang J, Metter EJ, Landis P, Carter HB. PSA velocity for assessing prostate cancer risk in men with PSA levels between 2.0 and 4.0 ng/ml. Urology. 2002;59:889-93. discussion 893–4. [PMID: 12031375]. [pmid: 12031375].
10 Thompson I, Thrasher JB, Aus G, Burnett AL, Canby-Haglino ED, Cookson MS, et al. AUA Prostate Cancer Clinical Guideline Update Panel. Guideline for the management of clinically localized prostate cancer: 2007 update. J Urol. 2007;177:2106-31. [PMID: 17509297]. [pmid: 17509297].
11 Wilt TJ, MacDonald R, Rutks I, Shamliyan TA, Taylor BC, Kane RL. Systematic review: comparative effectiveness and harms of treatments for clinically localized prostate cancer. Ann Intern Med. 2008;148:435-48. [PMID: 18252677]. [pmid: 18252677].
12 Harris R, Lohr KN. Screening for prostate cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:917-29. [PMID: 12458993]. [pmid: 12458993].
13 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Methods Work Group, Third US Preventive Services Task Force. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [PMID: 11306229]. [pmid: 11306229].
14 Labrie F, Candas B, Dupont A, Cusan L, Gomez JL, Suburu RE, et al. Screening decreases prostate cancer death: first analysis of the 1988 Quebec prospective randomized controlled trial. Prostate. 1999;38:83-91. [PMID: 9973093]. [pmid: 9973093].
15 Labrie F, Candas B, Cusan L, Gomez JL, Bélanger A, Brousseau G, et al. Screening decreases prostate cancer mortality: 11-year follow-up of the 1988 Quebec prospective randomized controlled trial. Prostate. 2004;59:311-8. [PMID: 15042607]. [pmid: 15042607].
16 Sandblom G, Varenhorst E, Löfman O, Rosell J, Carlsson P. Clinical consequences of screening for prostate cancer: 15 years follow-up of a randomised controlled trial in Sweden. Eur Urol. 2004;46:717-23. discussion 724. [PMID: 15548438]. [pmid: 15548438].
17 Ilic D, O'Connor D, Green S, Wilt T. Screening for prostate cancer. Cochrane Database Syst Rev. 2006;3:CD004720. [PMID: 16856057]
18 Essink-Bot ML, de Koning HJ, Nijs HG, Kirkels WJ, van der Maas PJ, Schröder FH. Short-term effects of population-based screening for prostate cancer on health-related quality of life. J Natl Cancer Inst. 1998;90:925-31. [PMID: 9637143]. [pmid: 9637143].
19 Brindle LA, Oliver SE, Dedman D, Donovan JL, Neal DE, Hamdy FC, et al. Measuring the psychosocial impact of population-based prostate-specific antigen testing for prostate cancer in the UK. BJU Int. 2006;98:777-82. [PMID: 16978272]. [pmid: 16978272].
20 Katz DA, Jarrard DF, McHorney CA, Hillis SL, Wiebe DA, Fryback DG. Health perceptions in patients who undergo screening and workup for prostate cancer. Urology. 2007;69:215-20. [PMID: 17320653]. [pmid: 17320653].
21 McNaughton-Collins M, Fowler FJ Jr, Caubet JF, Bates DW, Lee JM, Hauser A, et al. Psychological effects of a suspicious prostate cancer screening test followed by a benign biopsy result. Am J Med. 2004;117:719-25. [PMID: 15541320]. [pmid: 15541320].
22 Fowler FJ Jr, Barry MJ, Walker-Corkery B, Caubet JF, Bates DW, Lee JM, et al. The impact of a suspicious prostate biopsy on patients' psychological, socio-behavioral, and medical care outcomes. J Gen Intern Med. 2006;21:715-21. [PMID: 16808772]. [pmid: 16808772].
23 Hardie C, Parker C, Norman A, Eeles R, Horwich A, Huddart R, et al. Early outcomes of active surveillance for localized prostate cancer. BJU Int. 2005;95:956-60. [PMID: 15839912]. [pmid: 15839912].
24 Roemeling S, Roobol MJ, Postma R, Gosselaar C, van der Kwast TH, Bangma CH, et al. Management and survival of screen-detected prostate cancer patients who might have been suitable for active surveillance. Eur Urol. 2006;50:475-82. [PMID: 16713065]. [pmid: 16713065].
25 Roemeling S, Roobol MJ, de Vries SH, Wolters T, Gosselaar C, van Leenders GJ, et al. Active surveillance for prostate cancers detected in three subsequent rounds of a screening trial: characteristics, PSA doubling times, and outcome. Eur Urol. 2007;51:1244-50. discussion 1251. [PMID: 17161520]. [pmid: 17161520].
26 Weinmann S, Richert-Boe K, Glass AG, Weiss NS. Prostate cancer screening and mortality: a case-control study (United States). Cancer Causes Control. 2004;15:133-8. [PMID: 15017125]. [pmid: 15017125].
27 Weinmann S, Richert-Boe KE, Van Den Eeden SK, Enger SM, Rybicki BA, Shapiro JA, et al. Screening by prostate-specific antigen and digital rectal examination in relation to prostate cancer mortality: a case-control study. Epidemiology. 2005;16:367-76. [PMID: 15824554]. [pmid: 15824554].
28 Kopec JA, Goel V, Bunting PS, Neuman J, Sayre EC, Warde P, et al. Screening with prostate specific antigen and metastatic prostate cancer risk: a population based case-control study. J Urol. 2005;174:495-9. discussion 499. [PMID: 16006879]. [pmid: 16006879].
29 Concato J, Wells CK, Horwitz RI, Penson D, Fincke G, Berlowitz DR, et al. The effectiveness of screening for prostate cancer: a nested case-control study. Arch Intern Med. 2006;166:38-43. [PMID: 16401808]. [pmid: 16401808].
30 Agalliu I, Weiss NS, Lin DW, Stanford JL. Prostate cancer mortality in relation to screening by prostate-specific antigen testing and digital rectal examination: a population-based study in middle-aged men. Cancer Causes Control. 2007;18:931-37. [pmid: 17641982].
31 Marcella SW, Rhoads GG, Carson JL, Merlino F, Wilcox H. Prostate-specific antigen screening and mortality from prostate cancer. J Gen Intern Med. 2008;23:248-53. [pmid: 18172740].
32 Aus G, Bergdahl S, Lodding P, Lilja H, Hugosson J. Prostate cancer screening decreases the absolute risk of being diagnosed with advanced prostate cancer—-results from a prospective, population-based randomized controlled trial. Eur Urol. 2007;51:659-64. [PMID: 16934392]. [pmid: 16934392].
33 Johansson JE, Andrén O, Andersson SO, Dickman PW, Holmberg L, Magnuson A, et al. Natural history of early, localized prostate cancer. JAMA. 2004;291:2713-9. [PMID: 15187052]. [pmid: 15187052].
34 Albertsen PC, Hanley JA, Fine J. 20-year outcomes following conservative management of clinically localized prostate cancer. JAMA. 2005;293:2095-101. [PMID: 15870412]. [pmid: 15870412].
35 Bill-Axelson A, Holmberg L, Ruutu M, Häggman M, Andersson SO, Bratell S, et al. Scandinavian Prostate Cancer Group Study No. 4. Radical prostatectomy versus watchful waiting in early prostate cancer. N Engl J Med. 2005;352:1977-84. [PMID: 15888698]. [pmid: 15888698].
36 Schröder FH, Kranse R, Rietbergen J, Hoedemaeke R, Kirkels W. The European Randomized Study of Screening for Prostate Cancer (ERSPC): an update. Members of the ERSPC, Section Rotterdam. Eur Urol. 1999;35:539-43. [PMID: 10408951]. [pmid: 10408951].
37 Gohagan JK, Prorok PC, Hayes RB, Kramer BS. Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial Project Team. The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial of the National Cancer Institute: history, organization, and status. Control Clin Trials. 2000;21:251S-272S. [PMID: 11189683]. [pmid: 11189683].