# Discussion

We found inconclusive evidence from RCTs about the health benefits of screening for prostate cancer with PSA. Although we excluded nonrandomized studies of PSA screening, several case-control studies have been published since the 2002 USPSTF review. These studies, conducted in a variety of settings and populations, have yielded conflicting results about the relationship between PSA screening and prostate cancer-related morbidity and mortality (26–31).

In 2007, Aus and colleagues (32) reported interim results from the ERSPC (European Randomized Study of Screening for Prostate Cancer), an ongoing trial that is designed to detect a mortality difference in men randomly assigned to biennial PSA screening or usual care. In the 19945 men in this subsection of the study, the authors observed a 49% reduction in the risk for metastatic prostate cancer in the screening group (24 cases compared with 47 cases in the control group) after 10 years of follow-up (32).

We determined that this study did not meet inclusion criteria but brought it to the attention of the USPSTF. The primary outcome, metastatic prostate cancer, is an uncertain surrogate for mortality because of high initial response rates to androgen deprivation therapy and competing causes of death. Also, the criterion used for testing to ascertain this outcome may have resulted in unequal attention to the 2 groups, thereby biasing the results. In the absence of symptoms, bone scans were obtained only in men with a PSA level greater than 20 μg/L. Because patients in the control group with prostate cancer had a higher mean PSA level (90.4 μg/L) than do patients in the screening group (19.8 μg/L), the reported difference in metastatic disease may have been exaggerated in favor of the screening group.

Although we found some evidence that false-positive PSA test results are associated with adverse psychological effects, we cannot determine from the existing studies the precise magnitude of psychological harms of prostate cancer screening. Because the populations studied have almost exclusively consisted of college-educated white men, these results may not be generalizable to men with less formal education, or to ethnic or racial minorities. No studies of the effects of false-positive PSA test results have included many black men, who have a higher risk for diagnosis with and dying of prostate cancer. Studies excluded during our review that were performed in black patient populations involved strategies for increasing rates of prostate cancer screening in these patients, with the benefit of such screening being assumed.

Short-term monitoring studies of highly selected older men with PSA-detected, nonpalpable, localized prostate cancer do not suggest that delayed or no treatment leads to poor health outcomes. Larger, longer-term studies are urgently needed. A recent report of a population-based cohort of men with untreated, early-stage prostate cancer found a sharp decline in prostate cancer-specific survival after 15 years of follow-up (33). None of the participants in this study received their diagnosis through screening, and most cancer cases were detected when clinically palpable. However, these results, in addition to those from a retrospective cohort study that did not find an increase in prostate cancer mortality rates over a similar period (34), suggest that decades of follow-up may be required to determine the safety and effectiveness of current monitoring protocols.

Although we did not examine new evidence on the harms of treatment in this focused update, the 2002 USPSTF review found that prostate cancer treatments cause clinically significant harms, including erectile dysfunction and urinary incontinence, in many patients (12). Still, many physicians continue to believe that the benefits of immediately treating PSA-detected prostate cancer outweigh the risks of delayed or no treatment. In this context, a study that was excluded from this review merits mention.

In 2005, Bill-Axelson and colleagues (35) reported the results of a trial of 695 men with localized prostate cancer who were randomly assigned to receive radical prostatectomy or watchful waiting. The study did not meet inclusion criteria because only 5.2% of the population had prostate cancer diagnosed through screening and 77.8% of the treatment group had stage T2 (palpable) cancer. After a median of 8.2 years, 14.4% of men in the control group and 8.6% of men in the treatment group had died of prostate cancer. An analysis of prostate cancer-specific mortality stratified by age and intervention suggested that the men younger than 65 years were much more likely to benefit from radical prostatectomy than men 65 years of age or older. In the latter subgroup, the cumulative incidence of death from prostate cancer after 10 years was comparable in the watchful waiting and prostatectomy groups.

Two large RCTs of PSA screening are currently under way. The ERSPC randomly assigned 190000 men between ages 50 and 75 years to screening with PSA, digital rectal examination, and transrectal ultrasonography or usual care; the intervention was later changed to PSA screening alone (36). Biopsies were performed in patients with PSA levels greater than 3.0 μg/L, and positive biopsy results led to treatment outlined by a standardized protocol. The prostate component of the U.S. National Cancer Institute's Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial is evaluating the effect of annual screening with PSA and digital rectal examination on prostate cancer-specific mortality in 76,705 men (37). Abnormal results were provided to the patient's primary care physician of record, and further diagnostic work-up and treatment were based on individual patient and physician preferences.

These trials may provide valuable and complementary information about the health outcomes associated with PSA screening in the general primary care population. Even if 1 or both ultimately demonstrates a population-level mortality benefit, however, individual screening decisions will still need to be made by weighing the benefits and harms of prostate cancer screening and treatment summarized in the previous USPSTF review (12) and this focused evidence update.