# Results

We identified 390 potentially relevant articles on health outcomes associated with PSA screening, 421 potentially relevant articles on harms of prostate cancer screening, and 91 potentially relevant articles on the natural history of PSA-detected prostate cancer. Appendix Figure 1, Appendix Figure 2, and Appendix Figure 3 contain details of the stages of review and reasons for study exclusion. We obtained 68 articles for full-text review; 10 articles met inclusion criteria for this evidence update.

## Key Question 1

Does screening for prostate cancer with PSA, as a single-threshold test or as a function of multiple tests over time, decrease morbidity or mortality?

No good- or fair-quality RCTs addressed this question. Two poor-quality RCTs with important flaws in design and analysis (Table 1) do not show a mortality benefit from PSA screening independently or in a meta-analysis. We identified no RCTs that measured health outcomes from PSA screening by means other than single-threshold tests.

Table 1 Evidence for Key Question 1: Effect of Prostate Cancer Screening on Morbidity and Mortality

Author, Year (Reference) | Participants | Monitoring Protocol | Results | Comments | Quality Rating
Labrie et al., 2004 (15) | Men registered on the Québec City area electoral rolls in 1985; 46 486 men age 45–80 y; 23% of invited men actually screened; 7.3% of control participants received screening. | Annual screening by PSA and DRE, 1988-1999; PSA cut-point >3.0 μg/L; positive screening result led to TRUS and biopsy. | Primary outcome was death from prostate cancer; 10 deaths in 7348 men who received screening; 74 deaths in 14 231 unscreened men; 62% reduction in prostate cancer mortality in screened group. | No sociodemographic comparison of the 2 groups; no intention-to-screen analysis; no information on death rates from other causes. | Poor
Sandblom et al., 2004 (16) | All male residents of Norrkoping, Sweden, 1987-1996; men age 50–69 y; 1494 men (every 6th man) invited for screening; 70%–78% received screening; 7532 control participants received usual care; an unknown number received screening. | DRE only in 1987 and 1990; DRE and PSA test in 1993 and 1996; PSA cut-point >4.0 μg/L; positive screening result led to biopsy; confirmed prostate cancer treated by urologist with “standardized management program.” | Total and prostate cancer-specific survival did not differ between invited and noninvited groups. | No sociodemographic comparison of the 2 groups; no information on crossovers from control group; study was inadequately powered to detect differences in outcomes of interest. | Poor

DRE = digital rectal examination; PSA = prostate-specific antigen; TRUS = transrectal ultrasonography.

In 2002, the USPSTF identified 1 poor-quality RCT of prostate cancer screening by Labrie and colleagues (14) that did not show a mortality benefit from screening when data were re-analyzed by using an intention-to-screen analysis. A 2004 publication described 3 additional years of follow-up of this study (15). By the end of 1999, 23.6% of the screening-invited group and 7.3% of the control group had actually received screening. Comparing all men who were screened with all men who were not, the authors calculated a relative risk (RR) for death from prostate cancer of 0.385 (95% CI, 0.207 to 0.714) in those who were screened. However, when they compared screening-invited men with noninvited men, they found no mortality difference between the 2 groups (RR, 1.085 [CI, 0.822 to 1.433]).

Labrie and colleagues did not report information on the adequacy of randomization, the demographic composition of the 2 groups, or the characteristics of participants who crossed over from screening to no screening or vice versa. Moreover, they did not indicate whether the assessment of outcomes was blinded. And finally, the inappropriate analysis comparing screened with unscreened cohorts did not adjust for potential confounders.

A poor-quality quasi-RCT by Sandblom and colleagues (16) compared total mortality and prostate-cancer-specific mortality in 1494 men who received digital rectal examination and PSA screening with those in 7,532 control participants. An intention-to-screen analysis found no statistical difference in total mortality or prostate-cancer-specific mortality between the 2 groups. Sandblom and colleagues did not report information on the comparability of the groups, crossovers from the control group, or how the cause of death was assigned. Also, the study was not adequately powered to detect a statistically significant difference in the outcomes of interest.

A Cochrane meta-analysis (17) combined these 2 studies by using an intention-to-screen analysis and found no difference in prostate cancer mortality between men invited to prostate cancer screening and control groups (RR, 1.01 [CI, 0.80 to 1.29]). The authors assessed both studies as having a high risk for bias because of the methodological problems discussed previously.

## Key Question 2

What are the magnitude and nature of harms associated with prostate cancer screening other than overtreatment?

One cross-sectional and 2 prospective cohort studies of fair-to-good quality reported short- and long-term psychological harms from prostate cancer screening (Table 2). Although abnormal screening results did not affect summary measures of anxiety or health-related quality of life, men with false-positive PSA screening test results were more likely to worry specifically about prostate cancer, have a higher perceived risk for prostate cancer, and report problems with sexual function compared with control participants for up to 1 year after the test. In 1 study, 26% of men with false-positive screening results reported moderate-to-severe pain during the prostate biopsy; men with false-positive results were also more likely to undergo repeated PSA testing and additional biopsies.

Table 2 Evidence for Key Question 2: Harms of PSA Screening

Author, Year (Reference) | Study Type | Participants | Measurements | Results | Comments | Quality Rating
Brindle et al., 2006 (19) | Prospective cohort | Men age 50–69 y in general practices in the United Kingdom | Before-and-after abnormal PSA results: HADS and SF-12 | HADS or SF-12 scores did not differ. | Did not specifically assess effect of false-positive screening results; complete data on 78% of participants. | Fair
Katz et al., 2007 (20) | Cross-sectional | Men at university-affiliated primary care practices in Wisconsin, Iowa, and Indiana; 97% white; mostly college-educated | 2 mo after testing: Medical Outcomes Study SF-36, SAI-6, questions about prostate cancer-related worry (using 5-point scale), perception of cancer risk, and sexual function | SF-36 or SAI-6 scores did not differ; men with false-positive screening results had increased prostate cancer-related worry and problems with sexual function. | 84% of biopsy group and 73% of control group returned surveys; findings persisted after multivariate regression analysis; limited external validity because of demographic characteristics of participants | Fair
McNaughton-Collins et al., 2004 (21); Fowler et al., 2006 (22) | Prospective cohort | Men age ≥40 y at primary care practices of 3 Boston teaching hospitals; 88% white; mostly college-educated | 6 wk, 6 mo, and 1 y after testing: survey developed in focus groups with questions about prostate cancer worry, prostate cancer knowledge, self-perceived cancer risk, and biopsy experiences | Biopsy group reported more thinking and worrying about prostate cancer than control participants; biopsy group was more likely than control participants to have had another PSA test or biopsy. | More than 85% of men in both groups returned 1-y surveys. Limited external validity because of demographic characteristics of participants | Good

HADS = Hospital Anxiety and Depression Scale; PSA = prostate-specific antigen; SAI-6 = State Anxiety Index, Short-Form; SF-12 = Short Form-12 Health Survey; SF-36 = Short Form 36-item Health Survey.

In 2002, the USPSTF found little evidence on harms associated with prostate cancer screening. Digital rectal examination and prostate biopsy cause discomfort or pain in most men. However, in the initial screening round of an RCT, health-related quality-of-life measures were not negatively affected by false-positive screening test results (18).

Brindle and colleagues (19) administered standardized assessments of anxiety, depression, and mental health to 7,344 men who received PSA testing. Of the 855 men with a PSA level greater than an age-specific or numerical threshold, 770 returned for a biopsy and then took the questionnaires again before receiving their biopsy results. Assessment scores did not change in patients with an elevated PSA level. Because some elevated PSA levels were true positives, this study was not able to specifically assess the psychological effect of a false-positive PSA result. It was not clear whether the measures used were sensitive enough to detect changes in mental health related to anxiety specific to prostate cancer. Finally, this study was limited by 2 potential sources of selection bias: Recruited patients were already enrolled in a randomized trial of PSA screening, and more than 20% of participants with abnormal PSA levels were not re-evaluated.

Other studies have used prostate-specific measures of harms in addition to generic mental health or quality-of-life scores. Katz and colleagues (20) did a telephone survey of 2 groups of men approximately 2 months after PSA screening. After adjustment for baseline characteristics, men with false-positive screening results were statistically more likely than control participants to worry about getting prostate cancer, have a higher perceived 5-year risk for prostate cancer, and report at least moderate problems with sexual function. This study was limited by the potential of confounding through other sources of psychological differences between the 2 groups (for example, referral vs. primary care patient population) and a lower survey response rate in the control group.

McNaughton-Collins and colleagues (21) compared 167 men who had an abnormal screening result but a benign biopsy specimen with 233 men who had a normal PSA level (defined as <2.5 μg/L). After 6 weeks, 49% of men in the biopsy group reported thinking about prostate cancer “a lot” or “some of the time,” compared with 18% of the control group. In addition, 40% of the biopsy group worried “a lot” or “some of the time” about developing prostate cancer compared with 8% of the control group. A total of 26% of men experienced moderate-to-severe pain from the biopsy. For 25% of men, the most recent benign biopsy was their third biopsy or more. Statistically significant differences between the biopsy and control groups in anxiety related to prostate cancer and perceived prostate cancer risk persisted 6 months and 1 year later (22). After 1 year, more men in the biopsy group than in the control group had at least 1 additional PSA test (73% vs. 42%) and another biopsy (15% vs. 1%).

## Key Question 3

What is the natural history of PSA-detected, nonpalpable, localized prostate cancer?

Three fair-quality cohort studies with small-to-medium sample sizes, highly self-selected elderly patients, and high drop-out rates show that some men with PSA-detected, nonpalpable, localized (stage T1c) prostate cancer have good health outcomes up to 10 years after diagnosis (Table 3). We did not identify any population-based studies in which patients with stage T1c prostate cancer were followed longitudinally with no intervention in order to determine health outcomes resulting from the natural progression of disease.

Table 3 Evidence for Key Question 3: Natural History of PSA-Detected, Localized Prostate Cancer

Author, Year (Reference) | Study Type | Participants | Monitoring Protocol | Results | Comments | Quality Rating
Hardie et al., 2005 (23) | Prospective cohort | 80 men referred to tertiary care center in United Kingdom, 1993-2002, with stage T1–T2 disease, PSA level ≤20 μg/L, Gleason score ≤7, and fitness for radical prostatectomy or radiotherapy; median age, 70.5 y | PSA and DRE every 3–6 mo for first 2 y, then every 6 mo after; no routine repeated biopsy; delayed treatment decision based on rate of PSA level increase; no established triggers for treatment; decisions “made according to the judgment of each patient and clinician.” | Median follow-up, 42 mo; 64 patients remained on surveillance; 5 died of causes other than prostate cancer; 11 received or would receive radical treatment; no evidence of disease recurrence in 7 patients who received treatment. | Self-selected population; only 10% of patients with localized prostate cancer entered protocol; short follow-up. | Fair
Roemeling et al., 2006 (24) | Prospective cohort | 64 men with stage T1c or T2 prostate cancer, in the first screening round of the Rotterdam section of ERSPC, who chose watchful waiting; 50 had stage T1c prostate cancer; Gleason score ≤6, PSA level <15 μg/L, and PSA density <0.2 μg/L; mean age, 68.4 y | PSA and DRE every 3 mo for first year, then every 6 mo; “major reason for deferred treatment was an increasing PSA level” but no established triggers. | Mean follow-up, 82.4 mo; 37 patients remained on watchful waiting; 19 patients chose deferred treatment; no deaths from prostate cancer; 8 patients died of other causes. | Characteristics of patients who chose watchful waiting were not separately described | Fair
Roemeling et al., 2007 (25) | Retrospective cohort | 278 men with T1c or T2 prostate cancer in 1 of the 3 screening rounds of the Rotterdam section of ERSPC; median age, 69.8 y; median PSA level, 3.6 μg/L; PSA level <15 μg/L; Gleason score <8 | Not standardized, but consisted of periodic PSA testing; no uniform indications for treatment. | Median follow-up, 3.4 y; 196 patients remained on surveillance; 89% overall survival; 100% prostate cancer-specific survival. | End points (prostate cancer-specific and total mortality) determined by blinded independent committee; short follow-up. | Fair

DRE = digital rectal exam; ERSPC = European Randomized Study of Screening for Prostate Cancer; PSA = prostate-specific antigen.

The USPSTF did not directly examine this question in 2002. Recent studies have used PSA testing and biopsy-based monitoring protocols to identify groups of men with “favorable-risk” prostate cancer who were candidates for delayed treatment if subsequent testing showed biochemical or histologic evidence of disease progression. Triggers for treatment varied by study, and many men in the monitoring groups eventually opted for treatment without any objective signs of disease progression.

Hardie and colleagues (23) tested the feasibility of a surveillance protocol in 80 men (median age, 70.5 years) with localized prostate cancer (stage T1 to T2) who were referred to a single tertiary care center in the United Kingdom from 1993 to 2002. Delayed treatment was recommended on the basis of serial PSA level testing and life expectancy assessments. After a median of 42 months of follow-up, 64 men remained on surveillance, 11 had received delayed treatment, and 5 had died of causes other than prostate cancer. This study was limited by the self-selected nature of participants (representing only 10% of eligible patients during the study enrollment period) and the absence of a standardized PSA-based threshold (absolute value or rate of increase) for initiating treatment.

Roemeling and colleagues (24) studied 64 men (mean age, 68.4 years) who chose watchful waiting and were part of a larger cohort of 293 men with stage T1c or T2 prostate cancer who met favorable risk criteria. After a mean follow-up of 82.4 months (range, 23.8 to 119.9 months), 37 men were living and untreated, 19 had chosen treatment, and 8 had died from causes other than prostate cancer. The same authors examined health outcomes in 278 men (median age, 69.8 years) who chose an active surveillance protocol (25). After a median follow-up of 3.4 years (range, 1.2 to 6 years), 170 men remained on surveillance, 26 had died of causes other than prostate cancer, and 82 had chosen treatment. Both studies by Roemeling and colleagues were limited by having highly self-selected patient populations and high drop-out rates.