# Methods

After consultation with USPSTF liaisons and content experts, we chose a broad definition of PSA screening that included evolving prognostic measures, such as PSA velocity and doubling time. However, a comparison of the performance characteristics of such measures with traditional single-threshold PSA testing is outside the scope of this review.

## Data Sources

For evidence on health outcomes associated with PSA screening, we searched PubMed for English-language articles indexed between 1 January 2002 and 12 July 2007 by using combinations of the Medical Subject Heading (MeSH) terms and keywords prostate neoplasms, screening, prostate-specific antigen, early diagnosis, PSA velocity, PSA doubling time, and prostate specific antigen doubling.

For evidence on the harms of screening for prostate cancer, we searched PubMed for English-language articles indexed between 1 January 2002, and 12 July 2007 by using combinations of the MeSH terms and keywords prostate neoplasms; screening; false positive reactions; adverse effects; mass screening/adverse effects; mass screening/psychology; anxiety,; quality of life; and health knowledge, attitudes, practice.

For evidence on the natural history of PSA-detected, nonpalpable, localized prostate cancer, we searched PubMed for English-language articles indexed between 1 January 2002 and 23 August 2007 by using combinations of the MeSH terms and keywords prostatic neoplasms, natural history, epidemiology, disease progression, survival analysis, watchful waiting, active surveillance, population surveillance, expectant management, and conservative management.

We identified additional articles through a search of the Cochrane Library, recommendations of experts, and a hand search of reference lists from major review articles and studies.

## Study Selection

Two reviewers independently reviewed the title lists, abstracts, and full articles by using predetermined inclusion and exclusion criteria. Articles selected by at least 1 reviewer advanced to the next stage of review.

For key question 1, eligible studies were randomized, controlled trials (RCTs), meta-analyses, and systematic reviews that compared screening with no screening (or usual care) in general primary care populations and reported morbidity or mortality outcomes. Although the 2002 USPSTF review (12) considered case-control studies and ecological data related to this key question, we excluded these study types from this part of the evidence update to avoid potential sources of confounding that are inherent in nonrandomized studies.

For key question 2, eligible studies were randomized or nonrandomized comparative studies that reported quantitative health or quality-of-life outcomes related to a false-positive screening result. We excluded studies that reported only harms resulting from prostate cancer treatment.

For key question 3, eligible studies were RCTs and cohort studies that reported health outcomes of patients with stage T1c (nonpalpable, localized, PSA-detected) prostate cancer who did not receive active treatment (including patients assigned to watchful waiting or active surveillance protocols). To ensure that we retrieved the most applicable information on natural history, we excluded studies that predominantly involved patients with non-PSA-detected cancer (defined as comprising ≥80% of the study population), were too small to draw reliable conclusions about health outcomes (defined as <50 patients in the watchful waiting or surveillance group), or did not provide separate data on patients with stage T1c prostate cancer.

## Data Extraction and Quality Assessment

For all citations that met the initial eligibility criteria, 2 reviewers reviewed the full articles and independently rated their quality by using previously published USPSTF criteria (13). Disagreements between reviewers regarding article inclusion and quality rating were resolved through a consensus process. We assessed the quality of RCTs and cohort studies on the following items: initial assembly and maintenance of comparable groups; absence of important differential loss to follow-up or overall high loss to follow-up; use of equal, valid, and reliable outcome measurements; clear definition of interventions; and appropriateness of outcomes. We evaluated systematic reviews and meta-analyses on the following items: comprehensiveness of sources considered, appropriateness of search strategy, standard appraisal of included studies, validity of conclusions, recency, and relevance. The Appendix Table describes more thoroughly the criteria and definitions for USPSTF quality ratings.

## Data Synthesis and Analysis

We synthesized the data qualitatively by key question in tabular and narrative formats. Data from the 2002 USPSTF review (12) relevant to key questions 1 and 2 are included to facilitate an overall assessment of the body of evidence. We did not perform quantitative synthesis because of the paucity and heterogeneity of included studies.

## Role of the Funding Source

The general work of the USPSTF is supported by the Agency for Healthcare Research and Quality. This review did not receive specific funding.