# Acknowledgement

The authors thank Caryn McManus at the Agency for Healthcare Research and Quality for her assistance with the literature searches.