# Appendix D Expert Reviewers of the Draft Report

- Amy M. Donahue, PhD
- National Institute on Deafness and Other Communication Disorders
- National Institutes of Health

- Subash Duggirala, MD, MPH, FAAFP
- Center for Medicaid and Medicare Services
- Department of Health and Human Services

- Charles Homer, MD, MPH
- National Initiative for Children's Healthcare Quality (NICHQ) CEO
- Harvard School of Public Health - Associate Professor, Department of Society, Human Development, and Health

- Colin Kennedy, MD
- University of Southampton, Department of Child Health, UK

- Tracy Lieu, MD, MPH
- Harvard School of Public Health - Associate Professor in the Department of Health Policy and Management

- Eric A. Mann, MD, PhD
- CAPT, U.S. Public Health Service
- Branch Chief, ENTB/DOED
- Food and Drug Administration

- Mary Dianne Murphy, MD
- Director, Office of Pediatric Therapeutics
- Food and Drug Administration
- Department of Health and Human Services

- William Rodriguez, MD, PhD
- Food and Drug Administration
- Department of Health and Human Services

- Christine Yoshinaga-Itano, Ph.D.
- Department of Speech, Language, and Hearing Sciences
- University of Colorado-Boulder, Boulder, Colorado
- Northwestern University