# Appendix C Evidence Table of Key Screening Studies

Evidence Table of Key Screening Studies

Study, Year, Location | Study Design and Quality Score | Population | Inclusion & Exclusion Criteria | Referral criteria | Confounders | Outcomes measured | Results | Comments
Kennedy, 2005 ^17^ UK | Nonrandomized controlled trial, Good | 8-year follow-up of all infants born in 4 participating hospitals in southern England from 1993-1996 in the Wessex Trial including 25,609 who had UNHS and 28,172 not screened. | All children enrolled in the Wessex Trial were included and those with abnormal tests at birth or subsequently were followed by audiology services. Information about their diagnoses and management was obtained from multiple sources (records, therapists, etc.). Children with postnatal causes of hearing impairment were excluded. | See Wessex, 1998. All children were also subjected to screening using the Health Visitor Distraction Test at age 7–8 months as usual care in the UK. Some children were referred due to parent or clinician concern. | Severity of hearing impairment. | Proportion of hearing impaired children referred before age 6 months, proportion referred before age 3 years, age at referral, sensitivity, specificity, positive likelihood ratio, and negative likelihood ratio of screening, magnitude of effect. | Proportion referred before age 6 months: 11/35 (31%) with true hearing impairment born during periods without UNHS, 23/31 (74%) born during periods with UNHS (difference 43%, CI 19–60%, P=0.001). Adjustment for effect of severity of hearing impairment on age of referral: increased the odds ratio between UNHS and early referral from 6.3 to 6.9 (CI 2.2–22.0, P=0.001). Referral before age 3 years: the percentage of all true cases referred was greater at any given age during the first 3 years for children screened vs. not; percentages were similar after age 3. Age at referral: lower with UNHS than not (0 mo vs. 8 mo, P<0.001). Test sensitivity and specificity: 22/24 (0.92) and 20,960/21,279 (0.98). Positive and negative likelihood ratios: 61 and 0.08. Magnitude of effect: one additional case of bilateral hearing impairment was referred before age 6 months for every 1969 (CI 1011–12,896) infants in the UNHS population. | The numbers of cases offered screening but refused (n=7) will likely decrease as screening becomes an established clinical service. Although referral was early, management was often initiated later (48% after 18 mos), reflecting the evolving management system of the 1990s. 23% of all cases (screened and not) had progressive impairment that could be missed at birth.
Kennedy, 2006 ^33^ UK | Retrospective cohort, Good | 120 children with bilateral permanent hearing impairment identified from a large birth cohort in southern England assessed at a mean of 7.9 years of age (range 5.4 to 11.7). Children were either part of the Wessex Trial or from districts in Greater London providing UNHS or not at the time of birth. 63 age-matched children with normal hearing were used to derive z scores for outcome measures. | All children with bilateral permanent childhood hearing impairment of at least 40 dB hearing level identified from a cohort of 157,000 children born in 8 districts of southern England between 1992-1997. Children with known postnatal causes were excluded. | UNHS was performed in some district hospitals. Protocols for identification and confirmation of hearing impairment were similar at all sites (see Wessex, 1998). All children were also subjected to screening using the Health Visitor Distraction Test at age 7–8 months as usual care in the UK. Therapy was provided to all children as a public health service and included audiology services. | Baseline characteristics were similar between comparison groups (gender, English as first language, nonverbal ability using Raven's Progressive Matrices score, age at assessment, degree of hearing loss (moderate [40–69 dB HL], severe [70–94 dB HL], profound [more than 95 dB HL]), other disabilities, mother's education, and occupation of head of household). Outcome measures were adjusted for severity, maternal education, and age-adjusted total Raven's Progressive Matrices scores. | Receptive language: Test for Reception of Grammar, British Picture Vocabulary Scale, aggregate scores. Expressive language: Renfrew Bus Story Test (sentence information and 5 longest sentences), aggregate scores. Speech: Children's Communication Checklist (speech scale). | Age at confirmation of hearing impairment: children confirmed early (age 9 months or younger) had better scores than those confirmed later on the Test for Reception of Grammar (adjusted mean difference 0.90, P=0.003), British Picture Vocabularly Scale (0.64, P=0.02), Renfrew Bus Story Test, sentence information (0.54, P=0.03); but not on the Renfrew Bus Story, longest sentences component, or Children's Communication Checklist, speech scale. All aggregate scores for receptive and expressive language were significantly better for the early confirmation group. Universal newborn hearing screening: children who underwent UNHS had better scores than those who did not not on the Test for Reception of Grammar (0.27, P=0.05), British Picture Vocabularly Scale (0.47, P=0.08), but not the Renfrew Bus Story test or Children's Communication Checklist, speech scale. Aggregate scores for receptive language were better for the UNHS group. | Difference in higher scores for early vs. late confirmation are equivalent to an increase of 10 to 12 points in the verbal compared with nonverbal intelligence quotient. Estimated size of benefit is likely underestimated because the system of screening and follow-up has improved since the first cohort underwent this process. Not clear if children not screened as newborns had onset of hearing impairment after birth or not, a sensitivity analysis indicated that benefit for the screened group would have been higher if all were truly congenital. Speech was assessed on the basis of parental or professional report, rather than by direct measurement, and may lack sensitivity as an outcome measure.
Wake, 2005 ^35^ Australia | Retrospective cohort, Fair | 88 children age 7 to 8 years born in Victoria, Australia who were fitted with hearing aids by age 4.5 years for congenital hearing impairment. Children were identified from a large birth cohort and services were provided by the government for all eligible children. | All hearing impaired children from the birth cohort. Children with intellectual disability and non-English speakers were excluded from the study. | Hearing screening included audiology referral for infants with risk factors and a universally available behavioral hearing screen at age 8 to 10 months. | Outcome measures were adjusted for confounders using multiple regression for non-verbal IQ, maternal education, paternal occupational prestige, and family functioning. Evaluators were blinded to the children's history and hearing status. | Receptive and expressive language (Clinical Evaluation of Language Fundamentals), receptive vocabulary (Peabody Picture Vocabulary Test), cognition (Perceptual Organization Index of the Wechsler Intelligence Scale for Children), articulation (Goldman-Fristoe Test of Articulation), reading comprehension (Reading Progress Test 1), intelligibility (teacher questionnaire), and family functioning (McMaster Family Assessment Device). | Age at diagnosis did not contribute significantly to variance on language, speech, or reading measures except receptive vocabulary; severity of impairment contributed to variance on all measures except reading comprehension. Language outcomes were more than 25 points lower than expected from IQ scores and were related to the severity of impairment, but not age at diagnosis. Age at diagnosis was negatively correlated with severity at diagnosis. | Few children were diagnosed younger than age 6 months (n=11) or 12 months (n=28); comparisons between early vs. late diagnosed children were not reported.
Wessex Universal Neonatal Hearing Screening Trial Group, 1998 ^18^ UK | Nonrandomized controlled trial, Good | All infants born in 4 participating hospitals in southern England from 1993-1996 including 25,609 who had UNHS and 28,172 not screened. | All children born in the participating hospitals. Two teams of testers (trained nursery nurses) and equipment moved between 2 pairs of hospitals to achieve 4 periods of 4–6 months duration with UNHS and 4 without. Infants in special care units and NICUs were screened at the end of their hospital stays. | Newborns with abnormal tests (40 dB hearing level or more using OAE and ABR in those who failed the first test) were referred to local audiological services for assessment and management. These are public health services available to all children. All children were also subjected to screening using the Health Visitor Distraction Test at age 7–8 months as usual care in the UK. | Severity of hearing impairment. | Proportion screened, proportion with risk factors, test performance, yield of screening, yield of screening vs. usual care, proportion with early referral, odds of early confirmation of impairment, odds of early management. | Proportion of newborns screened at birth: 87%. Risk factors: proportion screened with known risk factors=8.1%; proportion with impairment who had risk factors=64% (CI 50–77%). Test performance: false positive rate=1.5%, false negative rate=4% (distraction test=27%). Yield of screening: 90 cases per 100,000 target poulation confirmed after referral from UNHS (equivalent to 80% of expected prevalence). Screening vs. distraction test (usual care): relative risk=2.3 (CI 1.1–4.7) for detection through UNHS vs. distraction test. Proportion with early referral: 71 more infants per 100,000 were referred before age 6 months during periods with UNHS vs. during periods without; proportion is equivalent to 19 times higher than non screened infants. Early confirmation of hearing impairment: odds of confirmation before age 10 months adjusted for severity=5.0 (1.0–23.0) times greater for screened vs. non screened infants. Early management: odds ratio of management before age 10 months=8.0 (1.2–51.0) times higher for screened vs. non screened infants. | 87% of all births could be covered by screeners in medium to large maternity units with high rates of discharge within 2 days of birth. Higher coverage was attained after the addition of recall clinics for infants discharged from the hospital without screening and increasing personnel on peak services. Average non-pass rate was 1.6%, equivalent to 2 infants requiring follow-up assessment every 3 weeks in an annual birth cohort of 5,000. Proportion with risk factors consistent with other studies (50%) supporting need for universal vs. risk factor based screening. Special-care and NICU infants accounted for 36% of hearing impaired infants. Benefit of screening was underestimated due to use of a run-in period when coverage was lower (67%), difficulty obtaining timely parental consent, cases of profound impairment were more prevalent in the non screened group, and short duration of trial follow-up. Families undergoing UNHS were less anxious than those not screened.