# Appendix B

## Appendix B1. Search Strategies

Overall Searches:

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 (universal$ and (newborn$ or infant$) and hearing and screen$).mp.
2 ((deaf$ or hearing) adj5 (infant$ or infancy or neonat$ or newborn$)).mp.
3 1 or 2

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 (universal$ and (newborn$ or infant$) and hearing and screen$).mp.
2 ((deaf$ or hearing) adj5 (infant$ or infancy or neonat$ or newborn$)).mp.
3 1 or 2

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

1 (universal$ and (newborn$ or infant$) and hearing and screen$).mp.
2 ((deaf$ or hearing) adj5 (infant$ or infancy or neonat$ or newborn$)).mp.
3 1 or 2

Key Question 1 & 2 Specific Search:

Database: Ovid MEDLINE

1 exp hearing disorders/
2 exp hearing impaired persons/
3 1 or 2
4 infant/ or infant, newborn/
5 (universal$ and (newborn$ or infant$) and hearing and screen$).mp.
6 3 and 4
7 5 or 6
8 limit 7 to humans
9 limit 8 to english language
10 8 not 9
11 limit 10 to abstracts
12 9 or 11
13 exp Mass Screening/
14 screen$.mp.
15 exp Hearing Tests/
16 exp Otoacoustic Emissions, Spontaneous/
17 (otoacoustic$ adj2 emission$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
18 (teoae or dpoae).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
19 exp Evoked Potentials, Auditory, Brain Stem/
20 (auditory$ adj2 brainstem$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
21 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20
22 12 and 21
23 exp Cochlear Implants/
24 exp Hearing Aids/
25 exp manual communication/
26 exp rehabilitation of hearing impaired/
27 exp hearing disorders/dt, rh, su, th
28 23 or 24 or 25 or 26 or 27
29 12 and 28
30 22 or 29
31 exp epidemiologic studies/
32 meta analysis/
33 exp clinical trials/
34 (longitudinal$ or prospective$ or retrospective$ or follow up or cross sectional or cohort).mp.
35 exp comparative study/
36 31 or 32 or 33 or 34 or 35
37 exp “Outcome and Process Assessment (Health Care)”/
38 “Sensitivity and Specificity”/
39 exp diagnostic errors/
40 exp time factors/
41 exp age factors/
42 40 or 41
43 30 and 36
44 limit 43 to yr=“2000 - 2007”
45 30 and 37
46 limit 45 to yr=“2000 - 2007”
47 30 and 38
48 limit 47 to yr=“2000 - 2007”
49 30 and 39
50 limit 49 to yr=“2000 - 2007”
51 30 and 42
52 limit 51 to yr=“2000 - 2007”
53 44 or 46 or 48 or 50 or 52
54 limit 30 to (controlled clinical trial or guideline or meta analysis or randomized controlled trial)
55 limit 54 to yr=“2000 - 2007”
56 53 or 55
57 3 and 21
58 3 and 28
59 57 or 58
60 limit 59 to humans
61 limit 60 to english language
62 limit 60 to abstracts
63 61 or 62
64 limit 63 to yr=“2000 - 2007”
65 (infant$ or infancy or newborn$ or neonat$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
66 64 and 65
67 36 and 66
68 38 and 66
69 37 and 66
70 67 or 68 or 69
71 limit 66 to (controlled clinical trial or guideline or meta analysis or randomized controlled trial)
72 70 or 71
73 56 or 72

Key Question 3 Specific Search:

Database: Ovid MEDLINE

1 exp hearing disorders/
2 infant/ or infant, newborn/
3 (universal$ and (newborn$ or infant$) and hearing and screen$).mp.
4 1 and 2
5 3 or 4
6 limit 5 to humans
7 limit 6 to english language
8 6 not 7
9 limit 8 to abstracts
10 7 or 9
11 (adverse effect$ or harm$ or stigma$).mp. or exp stress, psychological/et or exp life change events/ or exp prejudice/ or exp stereotyping/ or exp self concept/
12 10 and 11
13 exp Diagnostic Errors/
14 10 and 13
15 12 or 14

## Appendix B2. Inclusion and Exclusion Criteria

Reasons for Inclusion in Results

- Provides data that address key questions
- Study designs: systematic review, randomized controlled trial, controlled trial without randomization, observational cohort or case-control study, descriptive study that provides unique data (e.g. survey of parental anxiety about screening)
- Hearing impairment identified prior to 6 months of age
- Primary care feasible or referable (see definitions below)
- Applicable years: 2000 to present

Reasons for Inclusion in Other Sections

- Provides context or background, or addresses methodology, epidemiology, or cost

Reasons for Exclusion

- Not relevant to key questions
- Study designs: Editorials, letters, non-systematic reviews, non-comparative studies, case studies, chapter, comment/opinion, etc
- Study not conducted in a country generalizable to the US population
- Non-English
- Non-humans
- No data provided

Criteria for judging if an intervention is primary care feasible:

- [underlined: Whom Targeted]: Somehow involves individual-level identification of being a patient in need of an intervention.
- [underlined: Who Delivered]: Usually involves primary care clinicians (physicians in family practice, internal medicine, obstetrics-gynecology, pediatrics, general practice), other physicians, nurses, nurse practitioners, physician assistants, or related clinical staff (dietitians, health educators, other counselors) in some direct or indirect way—or, at least, the intervention would be seen as connected to the health care system by the participant.
- [underlined: How Delivered]: To individuals or small groups (15 or less). Does not involve only or primarily group-level interventions outside the primary care setting to achieve behavioral change. Generally involves no more than a total of 8 group sessions and an intervention time period no longer than 12 months.
- [underlined: Where Delivered]: Could be delivered anywhere (including via the web, interactive technologies, in the home) if linked to primary care as above.

Definition of primary care referable:

In order for an intervention to be feasible for primary care referral, it would need to be conducted in a healthcare setting or else be widely available in the community at a national level (such as a car seat fitting station within a hospital).

## Appendix B3. Studies Excluded from Results of Review

### Outside Scope of Report

Abdullah A, Hazim MY, Almyzan A, et al. Newborn hearing screening: experience in a Malaysian hospital. Singapore Med J. 2006;47(1):60-64. [pmid: 16397723].
Abdullah A, Long CW, Saim L, et al. Sensitivity and specificity of portable transient otoacoustic emission (TEOAE) in newborn hearing screening. Med J Malaysia. 2005;60(1):21-27. [pmid: 16250276].
American College of Medical Genetics (ACMG). Genetics evaluation guidelines for the etiologic diagnosis of congenital hearing loss. ACMG statement. Genet Med. 2002;4(3):162-171. [pmid: 12180152].
Aidan D, Avan P, Bonfils P. Auditory screening in neonates by means of transient evoked otoacoustic emissions: a report of 2,842 recordings. Ann Otol Rhinol Laryngol. 1999;108(6):525-531. [pmid: 10378518].
Albuquerque W, Kemp DT. The feasibility of hospital-based universal newborn hearing screening in the United Kingdom. Scand Audiol Suppl. 2001;(Suppl 53):22–28.
Angeli S. Value of vestibular testing in young children with sensorineural hearing loss. Arch Otolaryngol Head Neck Surg. 2003;129(4):478-482. [pmid: 12707199].
Barker SE, Lesperance MM, Kileny PR. Outcome of newborn hearing screening by ABR compared with four different DPOAE pass criteria. Am J Audiol. 2000;9(2):142-148. [pmid: 11200191].
Baumgartner WD, Pok SM, Egelierler B, et al. The role of age in pediatric cochlear implantation. Int J Pediatr Otorhinolaryngol. 2002;62(3):223-228. [pmid: 11852125].
Bhatt KA, Liberman MC, Nadol JB Jr. Morphometric analysis of age-related changes in the human basilar membrane. Ann Otol Rhinol Laryngol. 2001;110(12):1147-1153. [pmid: 11768706].
Bishop DV. Development of the Children's Communication Checklist (CCO): a method for assessing qualitative aspects of communicative impairment in children. J Child Psychol Psychiatry. 1998;39:879-891. [pmid: 9758196].
Boshuizen HC, van der Lem GJ, Kauffman-de Boer MA, et al. Costs of different strategies for neonatal hearing screening: a modeling approach. Arch Dis Child Fetal Neonatal Ed. 2001;85(3):F177-181. [pmid: 11668159].
Chadha S, Bais AS. Auditory brainstem responses in high risk and normal newborns. Indian J Pediatr. 1997;64(6):777-784. [pmid: 10771920].
Chapchap MJ, Segre CM. Universal newborn hearing screening and transient evoked otoacoustic emission: new concepts in Brazil. Scand Audiol Suppl. 2001;Suppl 53:33–36.
Ching TY, Dillon H, Byrne D. Children's amplification needs—same or different from adults? Scand Audiol Suppl. 2001;Supplementum.(53):54–60.
Chiong CM, Dv Llanes EG, Tirona-Remulla AN, et al. Neonatal hearing screening in a neonatal intensive care unit using distortion-product otoacoustic emissions. Acta Otolaryngol (Stockh). 2003;123(2):215-218. [pmid: 12701743].
Clarke P, Iqbal M, Mitchell S. A comparison of transient-evoked otoacoustic emissions and automated auditory brainstem responses for pre-discharge neonatal hearing screening. Int J Audiol. 2003;42(8):443-447. [pmid: 14658852].
Clemens CJ, Davis SA. Minimizing false-positives in universal newborn hearing screening: a simple solution. Pediatrics. 2001;107(3):E29. [pmid: 11230610].
Cone-Wesson B, Vohr BR, Sininger YS, et al. Identification of neonatal hearing impairment: infants with hearing loss. Ear Hear. 2000;21(5):488-507. [pmid: 11059706].
Cox LC, Toro MR. Evolution of a universal infant hearing screening program in an inner city hospital. Int J Pediatr Otorhinolaryngol. 2001;59(2):99-104. [pmid: 11378184].
Crockett R, Baker H, Uus K, et al. Maternal anxiety and satisfaction following infant hearing screening: a comparison of the health visitor distraction test and newborn hearing screening. J Med Screen. 2005;12(2):78-82. [pmid: 15949118].
Cundall J. Universal newborn hearing in the volunteer state. Tenn Med. 2004;97(4):169-171. [pmid: 15103976].
Davis J, Elfenbein JL, Schum R, et al. Effects of mild and moderate hearing impairment on language, educational and psychosocial behavior of children. J Speech Hear Disord. 1986;51:53-62. [pmid: 3945060].
De Ceulaer G, Daemers K, Van Driessche K, et al. Neonatal hearing screening with transient evoked otoacoustic emissions—retrospective analysis on performance parameters. Scand Audiol Suppl. 2001;Supplementum.(52):109–111.
Dent K, Kenneson A, Palumbos J, et al. Methodology of a multistate study of congenital hearing loss: preliminary data from Utah newborn screening. Am J Med Genet C Semin Med Genet. 2004;125(1):28-34. [pmid: 14755431].
DesGeorges J. Family perceptions of early hearing, detection, and intervention systems: listening to and learning from families. Ment Retard Dev Disabil Res Rev. 2003;9(2):89-93. [pmid: 12784226].
Fitzgerald T, Duva S, Ostrer H, et al. The frequency of GJB2 and GJB6 mutations in the New York State newborn population: feasibility of genetic screening for hearing defects. Clin Genet. 2004;65(4):338-342. [pmid: 15025729].
Folsom RC, Widen JE, Vohr BR, et al. Identification of neonatal hearing impairment: recruitment and follow-up. Ear hear. 2000;21(5):462-470. [pmid: 11059704].
Gilley P, Sharma A, Dorman M, et al. Developmental changes in regractoriness of the cortical auditory evoked potential. Clin Neurophysiol. 2005;116(3):648-657. [pmid: 15721079].
Gorga MP, Norton SJ, Sininger YS, et al. Identification of neonatal hearing impairment: distortion product otoacoustic emissions during the perinatal period. Ear Hear. 2000;21(5):400-424. [pmid: 11059701].
Harrison WA, Dunnell JJ, Mascher K, et al. Identification of neonatal hearing impairment: experimental protocol and database management. Ear Hear. 2000;21(5):357-372. [pmid: 11059698].
Hyde M, Power D. Informed parental consent for cochlear implantation of young deaf children: social and other considerations in the use of the ‘bionic ear’. Aust J Soc Issues. 2000;35(2):117-127. [pmid: 14627014].
Isaacson G. Universal newborn hearing screening in an inner-city, managed care environment. Laryngoscope. 2000;110(6):881-894. [pmid: 10852501].
Jacobson CA, Jacobson JT. Follow-up services in newborn hearing screening programs. J Am Acad Audiol. 1990;1(4):181-186. [pmid: 2132602].
Johnson JL, White KR, Widen JE, et al. A multicenter evaluation of how many infants with permanent hearing loss pass a two-stage otoacoustic emissions/automated auditory brainstem response newborn hearing screening protocol. Pediatrics. 2005;116(3):663-672. [pmid: 16140706].
Keefe DH, Folsom RC, Gorga MP, et al. Identification of neonatal hearing impairment: ear-canal measurements of acoustic admittance and reflectance in neonates. Ear Hear. 2000;21(5):443-461. [pmid: 11059703].
Khairi MD, Din S, Shahid H, et al. Hearing screening of infants in Neonatal Unit, Hospital Universiti Sains Malaysia using transient evoked otoacoustic emissions. J Laryngol Otol. 2005;119(9):678-683. [pmid: 16156907].
Knutson JF, Wald RL, Ehlers SL, et al. Psychological consequences of pediatric cochlear implant use. Ann Otol Rhinol Laryngol Suppl. 2000;185:109-111. [pmid: 11140977].
Korres SG, Balatsouras DG, Gkoritsa E, et al. Success rate of newborn and follow-up screening of hearing using otoacoustic emissions. Int J Pediatr Otorhinolaryngol. 2006;70(6):1039-1043. [pmid: 16318876].
Kountakis SE, Skoulas I, Phillips D, et al. Risk factors for hearing loss in neonates: a prospective study. Am J Otolaryngol. 2002;23(3):133-137. [pmid: 12019480].
Kudo T, Oshima T, Kure S, et al. Mutation detection of GJB2 using IsoCode and real-time quantitative polymerase chain reaction with SYBR green I dye for newborn hearing screening. Laryngoscope. 2004;114(7):1299-1304. [pmid: 15235365].
Kuhl P. A new view of language acquisition. Proc Natl Acad Sci U S A. 2000;97(22):11850-11857. [pmid: 11050219].
Li R, Greinwald JH Jr, Yang L, et al. Molecular analysis of the mitochondrial 12S rRNA and tRNASer(UCN) genes in paediatric subjects with non-syndromic hearing loss. J Med Genet. 2004;41(8):615-620. [pmid: 15286157].
Lieu JE, Champion G. Prediction of auditory brainstem reflex screening referrals in high-risk infants. Laryngoscope. 2006;116(2):261-267. [pmid: 16467716].
Lim G, Fortaleza K. Overcoming challenges in newborn hearing screening. J Perinatol. 2000;20(8 Pt 2):S138-142. [pmid: 11190695].
Lin CY, Huang CY. Community-based newborn hearing screening program in Taiwan. Int J Pediatr Otorhinolaryngol. 2004;68(2):185-189. [pmid: 14725985].
Luterman DK, Kurtzer-White E. Identifying hearing loss: parents' needs. Am J Audiol. 1999;8(1):13-18. [pmid: 10499113].
Magnuson M, Hergils L. The parents' view on hearing screening in newborns. Scand Audiol Suppl. 1999;28(1):47-56.
Magnuson M, Hergils L. Late diagnosis of congenital hearing impairment in children: the parents' experiences and opinions. Patient Educ Couns. 2000;41(3):285-294. [pmid: 11042431].
Messner AH, Price M, Kwast K, et al. Volunteer-based universal newborn hearing screening program. Int J Pediatr Otorhinolaryngol. 2001;60(2):123-130. [pmid: 11518589].
Moeller MP, White KR, Shisler L. Primary care physicians' knowledge, attitudes, and practices related to newborn hearing screening. Pediatrics. 2006;118(4):1357-1370. [pmid: 17015524].
Mutton PE, Beckenham EJ, Gibson WP, et al. When the diagnosis of deafness is wrong. Med J Aust. 1992;157(7):483-484. [pmid: 1383677].
Norton SJ, Gorga MP, Widen JE, et al. Identification of neonatal hearing impairment: a multicenter investigation. Ear Hear. 2000;21(5):348-356. [pmid: 11059697].
Norton SJ, Gorga MP, Widen JE, et al. Identification of neonatal hearing impairment: summary and recommendations. Ear Hear. 2000;21(5):529-535. [pmid: 11059708].
Norton SJ, Gorga MP, Widen JE, et al. Identification of neonatal hearing impairment: evaluation of transient evoked otoacoustic emission, distortion product otoacoustic emission, and auditory brain stem response test performance. Ear Hear. 2000;21(5):508-528. [pmid: 11059707].
Norton SJ, Gorga MP, Widen JE, et al. Identification of neonatal hearing impairment: transient evoked otoacoustic emissions during the perinatal period. Ear Hear. 2000;21(5):425-442. [pmid: 11059702].
Okubo S, Takahashi M, Saito T, et al. Evaluation of universal newborn hearing screening in Japan: an analysis of the literature. Nippon Koshu Eisei Zasshi. 2005;52(11):928-933. [pmid: 16408477].
O'Neill C, Lutman ME, Archbold SM, et al. Parents and their cochlear implanted child: questionnaire development to assess parental views and experiences. Int J Pediatr Otorhinolaryngol. 2004;68(2):149-160. [pmid: 14725981].
Ozcebe E, Sevinc S, Belgin E. The ages of suspicion, identification, amplification and intervention in children with hearing loss. Int J Pediatr Otorhinolaryngol. 2005;69(8):1081-1087. [pmid: 16005351].
Park AH, Warner J, Sturgill N, et al. A survey of parental views regarding their child's hearing loss: a pilot study. Otolaryngol Head Neck Surg. 2006;134(5):794-800. [pmid: 16647537].
Pressman L, Pipp-Siegel S, Yoshinaga-Itano C, et al. Maternal sensitivity predicts language gain in preschool children who are deaf and hard of hearing. J Deaf Stud Deaf Educ. 1999;4(4):294-304. [pmid: 15579896].
Pressman LJ. A comparison of the links between emotional availability and language gain in young children with and without hearing loss. Volta Rev. 1998;100(5):251-278.
Quittner AL. Coping with a hearing-impaired child: a model of adjustment to chronic stress. In: Johnson JH, Johnson SB, eds. Advances in child health psychology. Gainesville, FL: University of Florida Press; 1991:206–223.
Quittner AL, Glueckauf RL, Jackson DN. Chronic parenting stress: moderating versus mediating effects of social support. J Pers Soc Psychol. 1990;59:1266-1278. [pmid: 2283593].
Sach TH, Whynes DK. Paediatric cochlear implantation: the views of parents. Int J Audiol. 2005;44(7):400-407. [pmid: 16136790].
Sharma A, Dorman M. Neurophysiologic correlates of cross-language phonetic perception. J Acoust Soc Am. 2000;107(5):2697-2703. [pmid: 10830391].
Sharma A, Dorman M. Exploration of the perceptual magnet effect using the mismatch negativity event-related potential. J Acoust Soc Am. 1998;104:511-517. [pmid: 9670542].
Sharma A, Dorman M. Cortical auditory evoked potential correlates of categorical perception of voice-onset time. J Acoust Soc Am. 1999;106(2):1078-1083. [pmid: 10462812].
Sharma A, Dorman M, Spahr A. Rapid development of cortical auditory evoked potentials after early cochlear implantation. Neuroreport. 2002;13(10):1365-1368. [pmid: 12151804].
Sharma A, Dorman MF, Kral A. The influence of a sensitive period on central auditory development in children with unilateral and bilateral cochlear implants. Hear Res. 2005;203(12):134-143. [pmid: 15855038].
Sharma A, Kraus N, McGee T, et al. Developmental changes in P1 & N1 auditory responses elicited by consonant vowel-syllables. Electroencephalogr Clin Neurophysiol. 1997;104:540-545. [pmid: 9402896].
Sharma A, Marsh C, Dorman M. Relationship between N1 evoked potential morphology and perception of voice-onset-time. J Acoust Soc Am. 2000;108(6):3030-3035. [pmid: 11144595].
Sharma A, Tobey E, Dorman M, et al. Central auditory maturation and babbling development in infants with cochlear implants. Arch Otolaryngol Head Neck Surg. 2004;130(5):511-516. [pmid: 15148169].
Shoup A, Owen K, Jackson G, et al. The Parkland Memorial Hospital experience in ensuring compliance with Universal Newborn Hearing Screening follow-up. J Pediatr. 2005;146(1):66-72. [pmid: 15644825].
Sininger Y, Cone-Wesson B, Folsom R, et al. Identification of neonatal hearing impairment: auditory brain stem responses in the perinatal period. Ear Hear. 2000;21(5):383-399. [pmid: 11059700].
Stewart DL, Mehl A, Hall JW 3rd, et al. Universal newborn hearing screening with automated auditory brainstem response: a multisite investigation. J Perinatol. 2000;20(8 Pt 2):S128-131. [pmid: 11190693].
van Straaten HL, Hille ET, Kok JH, et al. Implementation of a nation-wide automated auditory brainstem response hearing screening programme in neonatal intensive care units. Acta Paediatr. 2003;92(3):332-338. [pmid: 12725549].
Vohr BR, Moore PE, Tucker RJ. Impact of family health insurance and other environmental factors on universal hearing screen program effectiveness. J Perinatol. 2002;22(5):380-385. [pmid: 12082473].
Vohr BR, Widen JE, Cone-Wesson B, et al. Identification of neonatal hearing impairment: characteristics of infants in the neonatal intensive care unit and well-baby nursery. Ear Hear. 2000;21(5):373-382. [pmid: 11059699].
Waltzman SB, Cohen NL, Green J, et al. Long-term effects of cochlear implants in children. Otolaryngol Head Neck Surg. 2002;126(5):505-511. [pmid: 12075224].
Watkin P. Neonatal otoacoustic emission screening and the identification of deafness. Arch Dis Child Fetal Neonatal Ed. 1996;74(1):F16-25. [pmid: 8653430].
Watkin PM, Beckman A, Baldwin M. The views of parents of hearing impaired children on the need for neonatal hearing screening. Br J Audiol. 1995;29(5):259-262. [pmid: 8838547].
Widen JE, Folsom RC, Cone-Wesson B, et al. Identification of neonatal hearing impairment: hearing status at 8 to 12 months corrected age using a visual reinforcement audiometry protocol. Ear Hear. 2000;21(5):471-487. [pmid: 11059705].
Yoshinaga-Itano C, Gravel JS. The evidence for universal newborn hearing screening. Am J Audiol. 2001;10(2):62-64. [pmid: 11808721].

### Reviewed for Contextual Information

FDA-approved cochlear implants. Available at: www.fda.gov/cdrh/cochlear/approved.html. Accessed October 20, 2006.
American Academy of Pediatrics. Early Hearing Detection & Intervention (EHDI) Programs by State. Available at: http://www.medicalhomeinfo.org/screening/EHDIstateinfo.html. Accessed October 23, 2006.
American Academy of Pediatrics (AAP). Newborn Hearing Screening Test. http://www.aap.org/healthtopics/stages.cfm#inf. Accessed March 26, 2007.
American Speech-Language Hearing Association (ASHA). http://www.asha.org/public/hearing/testing#newborns_and_infants. Accessed September 22, 2006.
Anderson I, Weichbold V, D'Haese PS, et al. Cochlear implantation in children under the age of two—what do the outcomes show us?. Int J Pediatr Otorhinolaryngol. 2004;68(4):425-431. [pmid: 15013608].
Apuzzo M, Yoshinaga-Itano C. Early identification of infants with significant hearing loss and the Minnesota child development inventory. Semin Hear. 1995;16:124-139.
Bamford J, Uus K, Davis A. Screening for hearing loss in childhood: issues, evidence and current approaches in the UK. J Med Screen. 2005;12(3):119-124. [pmid: 16156941].
Baroch KA. Universal newborn hearing screening: fine-tuning the process. Curr Opin Otolaryngol Head Neck Surg. 2003;11(6):424-427. [pmid: 14631173].
Barsky-Firkser L, Sun S. Universal newborn hearing screenings: a 3-year experience. Pediatrics. 1997;99(6):E4. [pmid: 9164800].
Bishop DVM. Test for reception of grammar. Manchester, United Kingdom: Age and Cognitive Performance Research Centre, University of Manchester; 1983.
Burger T, Spahn C, Richter B, et al. Psychic stress and quality of life in parents during decisive phases in the therapy of their hearing-impaired children. Ear Hear. 2006;27(4):313-320. [pmid: 16825882].
Calderon R, Naidu S. Further support of the benefits of early identification and intervention with children with hearing loss. Volta Rev. 2000;100:53-84.
Canale A, Favero E, Lacilla M, et al. Age at diagnosis of deaf babies: a retrospective analysis highlighting the advantage of newborn hearing screening. Int J Pediatr Otorhinolaryngol. 2006;70(7):1283-1289. [pmid: 16488484].
Centers for Disease Control (CDC). Infants tested for hearing loss — United States. MMWR. 2003;52(41):981-984. [pmid: 14561955].
Centers for Disease Control (CDC). Early Hearing Detection and Intervention (EHDI) Program — 2006. http://www.cdc.gov/ncbddd/ehdi/default.htm. Accessed March 26, 2007.
Clemens CJ, Davis SA, Bailey AR. The false-positive in universal newborn hearing screening. Pediatrics. 2000;106(1):E7. [pmid: 10878176].
Colletti V, Carner M, Miorelli V, et al. Cochlear implant failure: is an auditory brainstem implant the answer?. Acta Otolaryngol (Stockh). 2004;124(4):353-357. [pmid: 15224852].
Connolly JL, Carron JD, Roark SD. Universal newborn hearing screening: are we achieving the Joint Committee on Infant Hearing (JCIH) objectives?. Laryngoscope. 2005;115(2):232-236. [pmid: 15689741].
Davis A, Bamford J, Wilson I, et al. A critical review of the role of neonatal hearing screening in the detection of congenital hearing impairment. Database of Abstracts of Reviews of Effects. 2006(4).
Davis A, Hind S. The impact of hearing impairment: a global health problem. Int J Pediatr Otorhinolaryngol. 1999;49(Supple 1):S51-S54. [pmid: 10577775].
Delb W, Merkel D, Pilorget K, et al. Effectiveness of a TEOAE-based screening program. Can a patient-tracking system effectively be organized using modern information technology and central data management?. Eur Arch Otorhinolaryngol. 2004;261(4):191-196. [pmid: 15103471].
Dettman SJ, Pinder D, Briggs RJ, et al. Communication development in children who receive the cochlear implant younger than 12 months: risks versus benefits. Ear Hear. 2007;28(2 Suppl):11S-18S. [pmid: 17496638].
Dodson KM, Maiberger PG, Sismanis A. Intracranial complications of cochlear implantation. Otol Neurotol. 2007;28(4):459-462. [pmid: 17414094].
Dunn LM, Whetton C, Burley J. British Picture Vocabulary Scale. 2nd Edition. Windsor, United Kingdom: NFER-Nelson; 1997.
El-Hakim H, Abdolell M, Mount RJ, et al. Influence of age at implantation and of residual hearing on speech outcome measures after cochlear implantation: binary partitioning analysis. Ann Otol Rhinol Laryngol Suppl. 2002;189:102-108. [pmid: 12018334].
El-Hakim H, Papsin B, Mount RJ, et al. Vocabulary acquisition rate after pediatric cochlear implantation and the impact of age at implantation. Int J Pediatr Otorhinolaryngol. 2001;59(3):187-194. [pmid: 11397500].
ElReda DK, Grigorescu V, Jarrett A, et al. Impact of the Early Hearing Detection and Intervention program on the detection of hearing loss at birth-Michigan, 1998-2002. J Educ Audiol. 2005;12:1-6.
Finitzo T, Albright K, O'Neal J. The Newborn with Hearing Loss: Detection in the Nursery. Pediatrics. 1998;102(6):1452-1460. [pmid: 9832584].
Fink NE, Wang NY, Visaya J, et al. Childhood Development after Cochlear Implantation (CDaCI) study: design and baseline characteristics. Cochlear Implants Int. 2007;8(2):92-116. [pmid: 17549807].
Fortnum HM, Davis A. Epidemiology of permanent childhood hearing impairment in Trent Region. Br J Audiol. 1997;31:409-446. [pmid: 9478287].
Goldberg DM, Flexer C. Auditory-verbal graduates: outcome survey of clinical efficacy. J Am Acad Audiol. 2001;12(8):406-414. [pmid: 11599875].
Gorga MP, Neely ST. Cost-effectiveness and test-performance factors in relation to universal newborn hearing screening. Ment Retard Dev Disabil Res Rev. 2003;9(2):103-108. [pmid: 12784228].
Gorga MP, Preissler K, Simmons J, et al. Some issues relevant to establishing a universal newborn hearing screening program. J Am Acad Audiol. 2001;12(2):101-112. [pmid: 11261458].
Govaerts PJ, De Beukelaer C, Daemers K, et al. Outcome of cochlear implantation at different ages from 0 to 6 years. Otol Neurotol. 2002;23(6):885-890. [pmid: 12438851].
Grill E, Hessel F, Siebert U, et al. Comparing the clinical effectiveness of different new-born hearing screening strategies. A decision analysis. BMC Public Health. 2005;5:12. [pmid: 15679901].
Grill E, Uus K, Hessel F, et al. Neonatal hearing screening: modeling cost and effectiveness of hospital- and community-based screening. BMC Health Serv Res. 2006;6:14. [pmid: 16504089].
Grosse SD, Ross DS. Cost savings from universal newborn hearing screening. Pediatrics. 2006;118(2):844-845. author reply 845–846. [pmid: 16882853].
Hammes DM, Novak MA, Rotz LA, et al. Early identification and cochlear implantation: critical factors for spoken language development. Ann Otol Rhinol Laryngol Suppl. 2002;189:74-78. [pmid: 12018355].
Harrison M, Roush J. Age of suspicion, identification, and intervention for infants and young children with hearing loss: a national study. Ear Hear. 1996;17(1):55-62. [pmid: 8741968].
Harrison M, Roush J, Wallace J. Trends in age of identification and intervention in infants with hearing loss. Ear Hear. 2003;24(1):89-95. [pmid: 12598815].
Hassanzadeh S, Farhadi M, Daneshi A, et al. The effects of age on auditory speech perception development in cochlear-implanted prelingually deaf children. Otolaryngol Head Neck Surg. 2002;126(5):524-527. [pmid: 12075227].
Houston DM, Pisoni DB, Kirk KI, et al. Speech perception skills of deaf infants following cochlear implantation: a first report. Int J Pediatr Otorhinolaryngol. 2003;67(5):479-495. [pmid: 12697350].
Hyde ML. Newborn hearing screening programs: overview. J Otolaryngol. 2005;34(Suppl 2):S70-78. [pmid: 16076420].
Kemper AR, Downs SM. A cost-effectiveness analysis of newborn hearing screening strategies. Arch Pediatr Adolesc Med. 2000;154(5):484-488. [pmid: 10807300].
Kennedy C, Kimm L, Thornton R, et al. False positives in universal neonatal screening for permanent childhood hearing impairment. Lancet. 2000;356(9245):1903-1904. [pmid: 11130392].
Kennedy C, McCann D. Universal neonatal hearing screening moving from evidence to practice. Arch Dis Child Fetal Neonatal Ed. 2004;89(5):F378-383. [pmid: 15321952].
Kennedy CR. Controlled trial of universal neonatal screening for early identification of permanent childhood hearing impairment: coverage, positive predictive value, effect on mothers and incremental yield. Wessex Universal Neonatal Screening Trial Group. Acta Paediatr. 1992;88(432):73-75.
Keren R, Helfand M, Homer C, et al. Projected cost-effectiveness of statewide universal newborn hearing screening. Pediatrics. 2002;110(5):855-864. [pmid: 12415021].
Kezirian EJ, White KR, Yueh B, et al. Cost and cost-effectiveness of universal screening for hearing loss in newborns. Otolaryngol Head Neck Surg. 2001;124(4):359-367. [pmid: 11283492].
Kirk KI, Miyamoto RT, Lento CL, et al. Effects of age at implantation in young children. Ann Otol Rhinol Laryngol Suppl. 2002;189:69-73. [pmid: 12018353].
Kishon-Rabin L, Taitelbaum-Swead R, Ezrati-Vinacour R, et al. Prelexical vocalization in normal hearing and hearing-impaired infants before and after cochlear implantation and its relation to early auditory skills. Ear Hear. 2005;26(4 Suppl):17S-29S. [pmid: 16082264].
Kolski C, Le Driant B, Lorenzo P, et al. Early hearing screening: what is the best strategy?. Int J Pediatr Otorhinolaryngol. 2007;71(7):1055-1060. [pmid: 17482286].
Lang DV. Neonatal otoacoustic emission screening (OAE) for deafness: psychological costs. Arch Dis Child Fetal Neonatal Ed. 1996;75(2):F143. [pmid: 8949703].
Leveque M, Schmidt P, Leroux B, et al. Universal newborn hearing screening: a 27-month experience in the French region of Champagne-Ardenne. Acta Paediatr. 2007;96(8):1150-1154. [pmid: 17578491].
Lin H, Shu M, Chang K, et al. A universal newborn hearing screening program in Taiwan. Int J Pediatr Otorhinolaryngol. 2002;63(3):209-218. [pmid: 11997156].
Lutman ME, Grandori F. Screening for neonatal hearing defects European consensus statement. Eur J Pediatr. 1999;158:95-96. [pmid: 10048602].
Manrique M, Cervera-Paz FJ, Huarte A, et al. Advantages of cochlear implantation in prelingual deaf children before 2 years of age when compared with later implantation. Laryngoscope. 2004;114(8):1462-1469. [pmid: 15280727].
Manrique M, Cervera-Paz FJ, Huarte A, et al. Prospective long-term auditory results of cochlear implantation in prelinguistically deafened children: the importance of early implantation. Acta Otolaryngol Suppl (Stockh). 2004(552):55–63.
March of Dimes. Recommended Newborn Screening Tests: 29 Disorders. Available at: http://www.marchofdimes.com/professionals/14332_15455.asp. Accessed October 20, 2006.
Mason J, Herrmann K. Universal infant hearing screening by automated auditory brainstem response measurement. Pediatrics. 1998;101(2):221-228. [pmid: 9445495].
Mayne AM, Yoshinaga-Itano C, Sedey A, et al. Expressive vocabulary development of infants and toddlers who are deaf or hard of hearing. Volta Rev. 2000;100:1-28.
Mehl AL, Thomson V. Newborn hearing screening: the great omission. Pediatrics. 1998;101(1):E4. [pmid: 9417168].
Meyer C, Witte J, Hildmann A, et al. Neonatal screening for hearing disorders in infants at risk: incidence, risk factors, and follow-up. Pediatrics. 1999;104(4 Pt 1):900-904. [pmid: 10506232].
Moeller MP. Early intervention and language development in children who are deaf and hard of hearing. Pediatrics. 2000;106:E43. [pmid: 10969127].
Moyer VA. Controlled trial of universal neonate screening for early identification of permanent childhood hearing impairment. J Pediatr. 1999;135(1):129-130. [pmid: 10428653].
National Deaf Children's Society (NDCS). Early Years. http://www.ndcs.org.uk/about_us/campaigns_policies/campaigns/early_years.html. Accessed March 26, 2007.
National Information Center for Children and Youth with Disabilities. Deafness and hearing loss (Pub. No. FS3). Washington, DC 2004.
National Institutes of Health (NIH). Has Your Baby's Hearing Been Screened? National Institute on Deafness and Other Communication Disorders (NIDCD) - One of the National Institutes of Health [http://www.nidcd.nih.gov/health/hearing/screened.asp. Accessed March 26, 2007.
Nekahm D, Weichbold V, Welzl-Mueller K, et al. Improvement in early detection of congenital hearing impairment due to universal newborn hearing screening. Int J Pediatr Otorhinolaryngol. 2001;59(1):23-28. [pmid: 11376815].
Nicholas JG, Geers AE. Will they catch up? The role of age at cochlear implantation in the spoken language development of children with severe to profound hearing loss. J Speech Lang Hear Res. 2007;50(4):1048-1062. [pmid: 17675604].
Nicholas JG, Geers AE. Effects of early auditory experience on the spoken language of deaf children at 3 years of age. Ear Hear. 2006;27(3):286-298. [pmid: 16672797].
Preisler G, Tvingstedt AL, Ahlstrom M. A psychosocial follow-up study of deaf preschool children using cochlear implants. Child Care Health Dev. 2002;28(5):403-418. [pmid: 12296875].
Prendergast SG, Lartz MN, Fiedler BC. Ages of diagnosis, amplification, and early intervention of infants and young children with hearing loss: findings from parent interviews. Am Ann Deaf. 2002;147(1):24-30. [pmid: 12061188].
Prieve B, Dalzell L, Berg A, et al. The New York State universal newborn hearing screening demonstration project: outpatient outcome measures. Ear Hear. 2000;21(2):104-117. [pmid: 10777018].
Prieve BA, Stevens F. The New York State universal newborn hearing screening demonstration project: introduction and overview. Ear Hear. 2000;21(2):85-91. [pmid: 10777016].
Prince CB, Miyashiro L, Weirather Y, et al. Epidemiology of early hearing loss detection in Hawaii. Pediatrics. 2003;111(5 Part 2):1202-1206. [pmid: 12728139].
Puig T, Municio A, Meda C. Universal neonatal hearing screening versus selective screening as part of the management of childhood deafness. Cochrane Database Syst Rev. 2006(3).
Raven C, Raven JC, Court JH. Manual for Raven's Progressive Matrices and Vocabulary Scales. Oxford, England: Oxford Psychology Press; 1998.
Renfrew C. Renfrew Bus Story Manual: a test of narrative speech. 3rd Edition. Oxford, England: Renfrew/Winslow; 1995.
Russ SA, Poulakis Z, Wake M, et al. The distraction test: the last word?. J Paediatr Child Health. 2005;41(4):197-200. [pmid: 15813874].
Russ SA, Rickards F, Poulakis Z, et al. Six year effectiveness of a population based two tier infant hearing screening programme. Arch Dis Child. 2002;86(4):245-250. [pmid: 11919095].
Sadri M, Thornton AR, Kennedy CR. Effects of maturation on parameters used for pass/fail criteria in neonatal hearing screening programmes using evoked otoacoustic emissions. Audiol Neurootol. 2007;12(4):226-233. [pmid: 17389789].
Schauwers K, Gillis S, Daemers K, et al. Cochlear implantation between 5 and 20 months of age: the onset of babbling and the audiologic outcome. Otol Neurotol. 2004;25(3):263-270. [pmid: 15129103].
Schimmenti L, Martinez A, Fox M, et al. Genetic testing as part of the early hearing detection and intervention (EHDI) process. Genet Med. 2004;6(6):521-525. [pmid: 15545749].
Schroeder L, Petrou S, Kennedy C, et al. The economic costs of congenital bilateral permanent childhood hearing impairment. Pediatrics. 2006;117(4):1101-1112. [pmid: 16585304].
Schultz D. FDA public health notification: continued risk of bacterial meningitis in children with cochlear implants with a positioner beyond twenty-four months post-implantation. Available at: www.fda.gov/chrh/safety/020606-cochlear.html. Accessed October 20, 2006.
Schulze-Gattermann H, Illg A, Schoenermark M, et al. Cost-benefit analysis of pediatric cochlear implantation: German experience. Otol Neurotol. 2002;23(5):674-681. [pmid: 12218619].
Sharma A, Dorman M, Spahr A. A sensitive period for the development of the central auditory system in children with cochlear implants: implications for age of implantation. Ear Hear. 2002;23(6):532-539. [pmid: 12476090].
Sharma A, Dorman M, Spahr A, et al. Early cochlear implantation allows for normal development of cortical auditory pathways. Ann Otol Rhinol Laryngol. 2002;111(5 Part 2 Suppl 189):38-41.
Sharma A, Martin J, Roland P, et al. P1 latency as a biomarker for central auditory development in children with hearing impairment. J Am Acad Audiol. 2005;16:564-573. [pmid: 16295243].
Spivak L, Dalzell L, Berg A, et al. New York State universal newborn hearing screening demonstration project: inpatient outcome measures. Ear Hear. 2000;21(2):92-103. [pmid: 10777017].
Svirsky MA, Teoh SW, Neuburger H. Development of language and speech perception in congenitally, profoundly deaf children as a function of age at cochlear implantation. Audiol Neurootol. 2004;9(4):224-233. [pmid: 15205550].
Tait ME, Nikolopoulos TP, Lutman ME. Age at implantation and development of vocal and auditory preverbal skills in implanted deaf children. Int J Pediatr Otorhinolaryngol. 2007;71(4):603-610. [pmid: 17239961].
Todd NW. Universal newborn hearing screening follow-up in two Georgia populations: newborn, mother and system correlates. Int J Pediatr Otorhinolaryngol. 2006;70(5):807-815. [pmid: 16246432].
U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. 2nd ed. Washington, DC: U.S. Government Printing Office, November 2000. 2nd ed. Washington, DC.
Uus K, Bamford J, Taylor R. An analysis of the costs of implementing the National Newborn Hearing Screening Programme in England. J Med Screen. 2006;13(1):14-19. [pmid: 16569300].
Uus K, Bamford J, Young A, et al. Readiness of paediatric audiology services for newborn hearing screening: findings and implications from the programme in England. Int J Audiol. 2005;44(12):712-720. [pmid: 16450923].
Uziel AS, Sillon M, Vieu A, et al. Ten-year follow-up of a consecutive series of children with multichannel cochlear implants. Otol Neurotol. 2007;28(5):615-628. [pmid: 17667770].
van Eldik TT. Behavior problems with deaf Dutch boys. Am Ann Deaf. 1994;139:394-399. [pmid: 7810455].
Vartianen E, Kemppinen P, Karjalainen S. Prevalence and etiology of bilateral sensorineural hearing impairment in a Finnish Childhood population. Int J Pediatr Otorhinolaryngol. 1997;41(2):175-185. [pmid: 9306174].
Vohr B, Carty L, Moore P, et al. The Rhode Island Hearing Assessment Program: experience with statewide hearing screening (1993-1996). J Pediatr. 1998;133(3):353-357. [pmid: 9738715].
Vohr BR, Oh W, Stewart EJ, et al. Comparison of costs and referral rates of three universal newborn hearing screening protocols. J Pediatr. 2001;139(2):238-244. [pmid: 11487750].
Vostanis P, Hayes M, Feu MD, et al. Detection of behavioural and emotional problems in deaf children and adolescents: comparison of two rating scales. Child Care Health Dev. 1997;23:233-246. [pmid: 9158912].
Wake M, Hughes E, Poulakis Z, et al. Outcomes of children with mild-profound congenital hearing loss at 7 to 8 years: a population study. Ear Hear. 2004;25(1):1-8. [pmid: 14770013].
Watkin PM. Neonatal hearing screening: have we taken the right road? Results from a 10-year targeted screen longitudinally followed up in a single district. J Audiol Med. 2005;3:175-184.
Watkin PM, Baldwin M, Dixon R, et al. Maternal anxiety and attitudes to universal neonatal hearing screening. Br J Audiol. 1998;32(1):27-37. [pmid: 9643305].
Watkin PM, Baldwin M, Dixon R, et al. Assessing the downside of universal neonatal hearing screening. Child Care Health Dev. 1998;24(6):501-503.
Weichbold V, Nekahm-Heis D, Welzl-Mueller K. Ten-year outcome of newborn hearing screening in Austria. Int J Pediatr Otorhinolaryngol. 2006;70(2):235-240. [pmid: 16085322].
Weichbold V, Nekahm-Heis D, Welzl-Mueller K. Universal newborn hearing screening and postnatal hearing loss. Pediatrics. 2006;117(4):e631-636. [pmid: 16585279].
White K. Early hearing detection and intervention programs: opportunities for genetic services. Am J Med Genet. 2004;130(1):29-36. [pmid: 15368492].
White KR, Vohr BR, Meyer S, et al. A multisite study to examine the efficacy of the otoacoustic emission/automated auditory brainstem response newborn hearing screening protocol: research design and results of the study. Am J Audiol. 2005;14(2):S186-199. [pmid: 16489863].
Windmill S, Windmill IM. The status of diagnostic testing following referral from universal newborn hearing screening. J Am Acad Audiol. 2006;17(5):367-378. quiz 379–380. [pmid: 16796302].
Yoshinaga-Itano C. Levels of evidence: universal newborn hearing screening (UNHS) and early hearing detection and intervention systems (EHDI). J Commun Disord. 2004;37(5):451-465. [pmid: 15231425].
Yoshinaga-Itano C, Apuzzo M. Identification of hearing loss after age 18 months is not early enough. Am Ann Deaf. 1998;143(5):380-387. [pmid: 9893323].
Yoshinaga-Itano C, Apuzzo M. The development of deaf and hard of hearing children identified early through the high-risk registry. Am Ann Deaf. 1998;143(5):416-424. [pmid: 9893327].
Yoshinaga-Itano C, Coulter D, Thomson V. The Colorado Newborn Hearing Screening Project: effects on speech and language development for children with hearing loss. J Perinatol. 2000;20(8 Pt 2):S132-137. [pmid: 11190694].
Yoshinaga-Itano C, Coulter D, Thomson V. Developmental outcomes of children with hearing loss born in Colorado hospitals with and without universal newborn hearing screening programs. Semin Neonatol. 2001;6(6):521-529. [pmid: 12014893].
Yoshinaga-Itano C, Sedey A, Coulter DK, et al. Language of early- and later-identified children with hearing loss. Pediatrics. 1998;102:1161-1171. [pmid: 9794949].
Yoshinaga-Itano C. Early intervention after universal neonatal hearing screening: impact on outcomes. Ment Retard Dev Disabil Res Rev. 2003;9(4):252-266. [pmid: 14648818].
Zwolan TA, Ashbaugh CM, Alarfaj A, et al. Pediatric cochlear implant patient performance as a function of age at implantation. Otol Neurotol. 2004;25(2):112-120. [pmid: 15021769].

### Study Design Limitations

Advice for patients with cochlear implants: new information on meningitis risk. Available at: www.fda.gov/cdrh/medicaldevicesafety/atp/020606-cochlear.html. Accessed October 20, 2006.
Bhatia K, Gibbin KP, Nikolopoulos TP, et al. Surgical complications and their management in a series of 300 consecutive pediatric cochlear implantations. Otol Neurotol. 2004;25(5):730-739. [pmid: 15354004].
Centre for Reviews and Dissemination. Newborn hearing screening (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2006;1:1.
Centre for Reviews and Dissemination. A critical review of the role of neonatal hearing screening in the detection of congenital hearing impairment (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2006;1:1.
Danhauer JL, Johnson CE. Parents' perceptions of an emerging community-based newborn hearing screening program: A case study. J Am Acad Audiol. 2006;17(3):202-220. [pmid: 16646280].
Hehar SS, Nikolopoulos TP, Gibbin KP, et al. Surgery and functional outcomes in deaf children receiving cochlear implants before age 2 years. Arch Otolaryngol Head Neck Surg. 2002;128(1):11-14. [pmid: 11784247].
Miyamoto RT, Houston DM, Bergeson T. Cochlear implantation in deaf infants. Laryngoscope. 2005;115(8):1376-1380. [pmid: 16094108].
Miyamoto RT, Houston DM, Kirk KI, et al. Language development in deaf infants following cochlear implantation. Acta Otolaryngol (Stockh). 2003;123(2):241-244. [pmid: 12701749].
Pipp-Siegel S, Sedey A, Yoshinaga-Itano C. Predictors of patental stress in mothers of young children with hearing loss. J Deaf Stud Deaf Educ. 2002;7(1):1-17. [pmid: 15451883].
Pipp-Siegel S, Sedey AL, VanLeeuwen A, et al. Mastery motivation predicts expressive language in children with hearing loss. J Deaf Stud Deaf Educ. 2003;8(2):133-145. [pmid: 15448063].
Spivak L, Sokol H. Beyond newborn screening: early diagnosis and management of hearing loss in infants. Adv Neonat Care. 2005;5(2):104-112.
Stuart A, Moretz M, Yang EY. An investigation of maternal stress after neonatal hearing screening. Am J Audiol. 2000;9:135-141. [pmid: 11200190].
Therrell BL Jr. Ethical, legal and social issues in newborn screening in the United States. Southeast Asian J Trop Med Public Health. 2003;34(Suppl 3):52-58. [pmid: 15906695].
Waltzman SB, Roland JT Jr. Cochlear implantation in children younger than 12 months. Pediatrics. 2005;116(4):e487-493. [pmid: 16199675].
Yoshinaga-Itano C. The social-emotional ramifications of universal newborn hearing screening, early identification and intervention of children who are deaf and hard of hearing. 2001; Chapter 19:221–231.
Young A, Tattersall H. Universal newborn hearing screening and early identification of deafness: parents' responses to knowing early and their expectations of child communication development. J Deaf Stud Deaf Educ. 2007;12(2):209-220. [pmid: 17277310].
Young A, Tattersall H. Parents' of deaf children evaluative accounts of the process and practice of universal newborn hearing screening. J Deaf Stud Deaf Educ. 2005;10(2):134-145. [pmid: 15778210].

### Not Available in English

Diez-Delgado Rubio J, Espin Galvez J, Lendinez Molinos F, et al. Hearing screening with evoked otoacoustic emission in the neonatal period are logistically and economically feasible. An Esp Pediatr. 2002;57(2):157-162. [pmid: 12139872].
Lesinski-Schiedat A, Illg A, Warnecke A, et al. Paediatric cochlear implantation in the first year of life: preliminary results. HNO. 2006;54(7):565-572. [pmid: 15841407].

## Appendix B4. U.S. Preventive Services Task Force Quality Rating Criteria^*^ ^*^Created using information from Harris RP, Helfand M, Woolf SH, et al. Current Methods of the USPSTF: A Review of the Process. Am J Prev Med 2001:20(3S);21–35.

### Randomized Controlled Trials (RCTs) and Cohort Studies

#### Criteria

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, and contamination).
- Important differential loss to follow-up or overall high loss to follow-up.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions.
- Important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intension-to-treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.

Poor: Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Case Control Studies

#### Criteria

- Accurate ascertainment of cases.
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both.
- Response rate.
- Diagnostic testing procedures applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Appropriate attention to potential confounding variable.

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.