# Appendix A Abbreviations

AAP | American Academy of Pediatrics
ABR | Auditory brainstem response
AHRQ | Agency for Healthcare Research and Quality
ANCOVA | Analysis of covariance
ANOVA | Analysis of variance
ASHA | American Speech-Language-Hearing Association
CDC | Center for Disease Control
CHIP | Children's Health Insurance Program
CI | Confidence interval
CQ | Cognitive quotient
dB | Decibels
DQ | Developmental quotient
ECHI | Early child hearing intervention
EHDI | Early hearing detection and intervention
EPC | Oregon Evidence-based Practice Center
FDA | Food and Drug Administration
HRSA | U.S. Health Resources and Services
Hz | Hertz
IDEA | Individuals with Disabilities Education Act
JCIH | Joint Committee on Infant Hearing
LQ | Language quotient
MCDI | Minnesota Child Development Inventory
NICU | Neonatal intensive care unit
NIDCD | National Institute on Deafness and Other Communication Disorders
NIH | National Institute of Health
NNS | Number needed to screen
OAE | Otoacoustic emissions
PCHL | Permanent congenital hearing loss
RCT | Randomized controlled trial
SE | Standard error
SES | Socioeconomic status
UNHS | Universal newborn hearing screening
USPSTF | U.S. Preventive Services Task Force