# References

1 U.S. Preventive Services Task Force. Newborn hearing screening: Recommendations and rationale. Am Fam Physician. 2001;64(12):1995-1999. [pmid: 11775766].
2 U.S. Preventive Services Task Force. Screening for newborn hearing: Recommendations and rationale. Available at: http://www.ahrq.gov/clinic/3rduspstf/newbornscreen/newhearrr.htm. Accessed September 22, 2006.
3 Thompson DC, McPhillips H, Davis RL, et al. Universal newborn hearing screening: Summary of evidence. JAMA. 2001;286(16):2000-2010. [pmid: 11667937].
4 Helfand M, Thompson DC, Davis RL, et al. Newborn hearing screening: Systematic evidence review. Available at: http://www.ncbi.nlm.nih.gov/books/NBK42616/. Accessed September 22, 2006.
5 Joint Committee on Infant Hearing. Year 2000 position statement: Principles and guidelines for early hearing detection and intervention programs. American Academy of Audiology, American Academy of Pediatrics, American Speech-Language-Hearing Association, and Directors of Speech and Hearing Programs in State Health and Welfare Agencies. Pediatrics. 2000;106(4):798-817. [pmid: 11015525].
6 Joint Committee on Infant Hearing. Year 2007 Position Statement: Principles and guidelines for early hearing detection and intervention programs. American Academy of Audiology, American Academy of Pediatrics, American Speech-Language-Hearing Association, and Directors of Speech and Hearing Programs in State Health and Welfare Agencies. Pediatrics. 2007;120(4):898-921. [pmid: 17908777].
7 U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. 2nd ed. Washington, DC: U.S. Government Printing Office, November 2000. Available at: http://www.healthypeople.gov/document/tableofcontents.htm. Accessed December 15, 2007.
8 Vartianen E, Kemppinen P, Karjalainen S. Prevalence and etiology of bilateral sensorineural hearing impairment in a Finnish Childhood population. Int J Pediatr Otorhinolaryngol. 1997;41(2):175-185. [pmid: 9306174].
9 Barsky-Firkser L, Sun S. Universal newborn hearing screenings: A 3-year experience. Pediatrics. 1997;99(6):E4. [pmid: 9164800].
10 Mehl AL, Thomson V. The Colorado newborn hearing screening project, 1992-1999: On the threshold of effective population-based universal newborn hearing screening. Pediatrics. 2002;109(1):E7. [pmid: 11773575].
11 March of Dimes. Recommended Newborn Screening Tests: 29 Disorders. Available at: http://www.marchofdimes.com/professionals/14332_15455.asp. Accessed October 20, 2006.
12 National Information Center for Children and Youth with Disabilities. Deafness and hearing loss (Pub. No. FS3). Washington, DC 2004.
13 Davis A, Hind S. The impact of hearing impairment: a global health problem. Int J Pediatr Otorhinolaryngol. 1999;49(Supple 1):S51-S54. [pmid: 10577775].
14 van Eldik TT. Behavior problems with deaf Dutch boys. Am Ann Deaf. 1994;139:394-399. [pmid: 7810455].
15 Vostanis P, Hayes M, Feu MD, et al. Detection of behavioural and emotional problems in deaf children and adolescents: Comparison of two rating scales. Child Care Health Dev. 1997;23:233-246. [pmid: 9158912].
16 Fortnum HM, Davis A. Epidemiology of permanent childhood hearing impairment in Trent Region. Br J Audiol. 1997;31:409-446. [pmid: 9478287].
17 Kennedy C, McCann D, Campbell MJ, et al. Universal newborn screening for permanent childhood hearing impairment: An 8-year follow-up of a controlled trial. Lancet. 2005;366:660-662. [pmid: 16112302].
18 Wessex Universal Neonatal Screening Trial Group. Controlled trial of universal neonatal screening for early identification of permanent childhood hearing impairment. Lancet. 1998;352:1957-1964. [pmid: 9872244].
19 Uus K, Bamford J. Effectiveness of population-based newborn hearing screening in England: Ages of interventions and profile of cases. Pediatrics. 2006;117(5):e887-893. [pmid: 16651292].
20 Dalzell L, Orlando M, MacDonald M, et al. The New York State universal newborn hearing screening demonstration project: Ages of hearing loss identification, hearing aid fitting, and enrollment in early intervention. Ear Hear. 2000;21(2):118-130. [pmid: 10777019].
21 American Speech-Language Hearing Association (ASHA). Available at: http://www.asha.org/public/hearing/testing#newborns_and_infants. Accessed September 22, 2006.
22 American Academy of Pediatrics. Early Hearing Detection & Intervention (EHDI) Programs by State. Available at: http://www.medicalhomeinfo.org/screening/EHDIstateinfo.html. Accessed October 23, 2006.
23 Vohr BR, Oh W, Stewart EJ, et al. Comparison of costs and referral rates of 3 universal newborn hearing screening protocols. J Pediatr. 2001;139(2):238-244. [pmid: 11487750].
24 Sperry C. Personal Communication from audiologist to Heidi Nelson; October 2006.
25 Govaerts PJ, De Beukelaer C, Daemers K, et al. Outcome of cochlear implantation at different ages from 0 to 6 years. Otol Neurotol. 2002;23(6):885-890. [pmid: 12438851].
26 Hammes DM, Novak MA, Rotz LA, et al. Early identification and cochlear implantation: Critical factors for spoken language development. Ann Otol Rhinol Laryngol Suppl. 2002;189:74-78. [pmid: 12018355].
27 Manrique M, Cervera-Paz FJ, Huarte A, et al. Advantages of cochlear implantation in prelingual deaf children before 2 years of age when compared with later implantation. Laryngoscope. 2004;114(8):1462-1469. [pmid: 15280727].
28 Schauwers K, Gillis S, Daemers K, et al. Cochlear implantation between 5 and 20 months of age: The onset of babbling and the audiologic outcome. Otol Neurotol. 2004;25(3):263-270. [pmid: 15129103].
29 Sharma A, Martin J, Roland P, et al. P1 latency as a biomarker for central auditory development in children with hearing impairment. J Am Acad Audiol. 2005;16:564-573. [pmid: 16295243].
30 Sharma A, Dorman M, Spahr A, et al. Early cochlear implantation allows for normal development of cortical auditory pathways. Ann Otol Rhinol Laryngol. 2002;111(5 Part 2 Supplement 189):38-41.
31 Sharma A, Dorman M, Spahr A. A sensitive period for the development of the central auditory system in children with cochlear implants: Implications for age of implantation. Ear Hear. 2002;23(6):532-539. [pmid: 12476090].
32 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
33 Kennedy CR, McCann DC, Campbell MJ, et al. Language ability after early detection of permanent childhood hearing impairment. N Engl J Med. 2006;354(20):2131-2141. [pmid: 16707750].
34 Puig T, Municio A, Meda C. Universal neonatal hearing screening versus selective screening as part of the management of childhood deafness. Cochrane Database Syst Rev. 2006(3).
35 Wake M, Poulakis Z, Hughes EK, et al. Hearing impairment: A population study of age at diagnosis, severity, and language outcomes at 7–8 years. Arch Dis Child. 2005;90:238-244. [pmid: 15723906].
36 Moeller MP. Early intervention and language development in children who are deaf and hard of hearing. Pediatrics. 2000;106(E43).
37 Calderon R, Naidu S. Further support of the benefits of early identification and intervention with children with hearing loss. Volta Rev. 2000;100:53-84.
38 Yoshinaga-Itano C, Coulter D, Thomson V, et al. Developmental outcomes of children with hearing loss born in Colorado hospitals with and without universal newborn hearing screening programs. Semin Neonatol. 2001;6(6):521-529. [pmid: 12014893].
39 Yoshinaga-Itano C, Coulter D, Thomson V. The Colorado Newborn Hearing Screening Project: Effects on speech and language development for children with hearing loss. J Perinatol. 2000;20(8 Pt 2):S132-137. [pmid: 11190694].
40 Yoshinaga-Itano C, Apuzzo M. The development of deaf and hard of hearing children identified early through the high-risk registry. Am Ann Deaf. 1998;143(5):416-424. [pmid: 9893327].
41 Yoshinaga-Itano C, Apuzzo M. Identification of hearing loss after age 18 months is not early enough. Am Ann Deaf. 1998;143(5):380-387. [pmid: 9893323].
42 Yoshinaga-Itano C, Sedey A, Coulter DK, et al. Language of early- and later-identified children with hearing loss. Pediatrics. 1998;102:1161-1171. [pmid: 9794949].
43 Mayne AM, Yoshinaga-Itano C, Sedey A, et al. Expressive vocabulary development of infants and toddlers who are deaf or hard of hearing. Volta Rev. 2000;100:1-28.
44 Apuzzo M, Yoshinaga-Itano C. Early identification of infants with significant hearing loss and the Minnesota Child Development Inventory. Semin Hear. 1995;16:124-139.
45 Joseph R, Tan HK, Low KT, et al. Mass newborn screening for hearing impairment. Southeast Asian J Trop Med Public Health. 2003;34(Suppl 3):229-230. [pmid: 15906742].
46 Bailey HD, Bower C, Krishnaswamy J, et al. Newborn hearing screening in Western Australia. Med J Aust. 2002;177(4):180-185. [pmid: 12175320].
47 Harrison M, Roush J, Wallace J, et al. Trends in age of identification and intervention in infants with hearing loss. Ear Hear. 2003;24(1):89-95. [pmid: 12598815].
48 Prendergast SG, Lartz MN, Fiedler BC, et al. Ages of diagnosis, amplification, and early intervention of infants and young children with hearing loss: Findings from parent interviews. Am Ann Deaf. 2002;147(1):24-30. [pmid: 12061188].
49 Kennedy CR, on behalf of the Wessex Universal Neonatal Screening Trial Group. Controlled trial of universal neonatal screening for early identification of permanent childhood hearing impairment: Coverage, positive predictive value, effect on mothers and incremental yield. Acta Paediatr. 1999;Suppl 432:73–75.
50 Weichbold V, Welzl-Mueller K. Maternal concern about positive test results in universal newborn hearing screening. Pediatrics. 2001;108(5):1111-1116. [pmid: 11694689].
51 Poulakis Z, Barker M, Wake M, et al. Six month impact of false positives in an Australian infant hearing screening programme. Arch Dis Child. 2003;88(1):20-24. [pmid: 12495952].
52 Crockett R, Wright AJ, Uus K, et al. Maternal anxiety following newborn hearing screening: The moderating role of parents' knowledge. J Med Screen. 2006;13(1):20-25. [pmid: 16569301].
53 de Uzcategui CA, Yoshinaga-Itano C. Parents' reactions to newborn hearing screening. Audiology Today. 1997;9(1):24-25.
54 Vohr BR, Letourneau KS, McDermott C, et al. Maternal worry about neonatal hearing screening. J Perinatol. 2001;21(1):15-20. [pmid: 11268862].
55 Hergils L, Hergils A. Universal neonatal hearing screening - parental attitudes and concern. Br J Audiol. 2000;34(6):321-327. [pmid: 11201318].
56 Russ SA, Kuo AA, Poulakis Z, et al. Qualitative analysis of parents experience with early detection of hearing loss. Arch Dis Child. 2004;89:353-358. [pmid: 15033847].
57 Bhatia K, Gibbin KP, Nikolopoulos TP, et al. Surgical complications and their management in a series of 300 consecutive pediatric cochlear implantations. Otol Neurotol. 2004;25(5):730-739. [pmid: 15354004].
58 Waltzman SB, Roland JT Jr. Cochlear implantation in children younger than 12 months. Pediatrics. 2005;116(4):e487-493. [pmid: 16199675].
59 Miyamoto RT, Houston DM, Bergeson T, et al. Cochlear implantation in deaf infants. Laryngoscope. 2005;115(8):1376-1380. [pmid: 16094108].
60 Hehar SS, Nikolopoulos TP, Gibbin KP, et al. Surgery and functional outcomes in deaf children receiving cochlear implants before age 2 years. Arch Otolaryngol Head Neck Surg. 2002;128(1):11-14. [pmid: 11784247].
61 Schultz D. FDA public health notification: Continued risk of bacterial meningitis in children with cochlear implants with a positioner beyond twenty-four months post-implantation. Available at: www.fda.gov/chrh/safety/020606-cochlear.html. Accessed October 20, 2006.
62 Reefhuis J, Hoein MA, Whitney CG, et al. Risk of bacterial meningitis in children with cochlear implants. N Eng J Med. 2003;349(5):435-445.
63 Biernath KR, Reefhuis J, Whitney CG, et al. Bacterial meningitis among children with cochlear implants beyond 24 months after implantation. Pediatrics. 2006;117(2):284-289. [pmid: 16390918].
64 Incesulu A, Vural M, Erkam U, et al. Children with cochlear implants: Parental perspective. Otol Neurotol. 2003;24(4):605-611. [pmid: 12851553].
65 Watkin PM. Neonatal hearing screening: Have we taken the right road? Results from a 10-year targeted screen longitudinally followed up in a single district. J Audiological Med. 2005;3:175-184.
66 Harrison M, Roush J. Age of suspicion, identification, and intervention for infants and young children with hearing loss: A national study. Ear Hear. 1996;17(1):55-62. [pmid: 8741968].
67 Vohr B, Carty L, Moore P, et al. The Rhode Island Hearing Assessment Program: Experience with statewide hearing screening (1993-1996). J Pediatr. 1998;133(3):353-357. [pmid: 9738715].
68 Wake M, Hughes E, Poulakis Z, et al. Outcomes of children with mild-profound congenital hearing loss at 7 to 8 years: A population study. Ear Hear. 2004;25(1):1-8. [pmid: 14770013].
69 Schroeder L, Petrou S, Kennedy C, et al. The economic costs of congenital bilateral permanent childhood hearing impairment. Pediatrics. 2006;117(4):1101-1112. [pmid: 16585304].
70 Centers for Disease Control and Prevention Early Hearing Detection and Intervention (EHDI) Program. Available at: www.cdc.gov/ncbddd/ehdi/default.htm. Accessed on March 26, 2007.
71 National Institutes of Health, National Institute on Deafness and Other Communication Disorders (NIH NIDCD). Available at: www.nidcd.nih.gov/health/hearing/screened.asp. Accessed on March 26, 2007.
72 Lutman ME, Grandori F. Screening for neonatal hearing defects European Consensus Statement. Eur J Pediatr. 1999;158(2):95-96. [pmid: 10048602].
73 National Deaf Children's Society. Available at: /www.ndcs.org.uk (http://www.ndcs.org.uk). Accessed on March 26, 2007.