# Results

## Key Question 1. Among infants identified by UNHS who would not be identified by targeted screening, does initiating treatment prior to age 6 months improve language and communication outcomes?

### Summary

No randomized controlled trials address this question. In a community-based cohort of both high and average risk children with PCHL, those who had their hearing impairment confirmed by age 9 months or younger had better scores at age 8 years on measures of receptive and expressive language, but not speech, than those confirmed later. ^33^ Children with PCHL who underwent UNHS had better scores than those who did not on measures of receptive language, but not expressive language and speech. More children undergoing UNHS had confirmation of impairment by age 9 months than those not screened as newborns (67% versus 27%; CI 24–56%; p<0.001).

### Evidence

A Cochrane review comparing the long-term effectiveness of UNHS and early treatment with high risk or opportunistic screening was conducted and updated in February 2005. ^34^ No randomized controlled trials were identified that fulfilled inclusion criteria. No additional trials were identified by our updated searches.

A good-quality retrospective cohort study evaluated the effect of UNHS on speech and language outcomes of children with PCHL (Table 2). ^33^ This study did not evaluate the effects of universal versus targeted newborn screening. It did not report the proportions of hearing impaired children that would have been considered high versus average risk for hearing impairment at birth. However, the proportion of children with other disabilities (13% to 26%), a possible surrogate for risk at birth, was similar between those who had UNHS versus not, and between those confirmed early versus late. The outcome measures are reported as differences between group means preventing calculation of absolute risk reduction or other estimates of magnitude of effect.

Table 2 Cohort Studies Reporting Language Outcomes

Study, Year (Quality) | Selection of Subjects | Comparability and Maintenance of Early vs. Late Groups | Adjustment for Confounders | Results
Kennedy et al, 2006 ^33^ (Good) | 120 children with bilateral permanent hearing impairment identified from a large birth cohort of 157,000 children in southern England assessed at a mean of 7.9 years of age (range 5.4 to 11.7). Children were either part of the Wessex Trial or from districts in Greater London providing UNHS or not at the time of birth. 63 age-matched children with normal hearing were used to derive z scores for outcome measures. Children with known postnatal causes were excluded. | Baseline characteristics were similar between comparison groups (sex, English as first language, nonverbal ability, age at assessment, degree of hearing loss, other disabilities, mother's education, and occupation of head of household). Follow-up and attrition likely similar between groups because all were provided assessment, therapy, and follow-up as a public health service. | Outcome measures were adjusted for confounders using multiple linear regression for degree of hearing loss, maternal education, and age-adjusted nonverbal ability. | Children with hearing impairment confirmed by age 9 months or younger had significantly better age-adjusted scores than those confirmed later on 2 tests of receptive language and 1 of 2 tests of expressive language, but not on a speech scale. All aggregate scores for receptive and expressive language were significantly better for the early confirmation group. Children who underwent UNHS had better scores than those who did not on 2 tests of receptive language, but not on 2 tests of expressive language or speech. Aggregate scores for receptive language were better for the UNHS group.
Wake et al, 2005 ^35^ (Fair) | 88 children age 7 to 8 years born in Victoria, Australia who were fitted with hearing aids by age 4.5 years for congenital hearing impairment. Services were provided by the government for all eligible children and data were collected. Hearing screening included audiology referral for infants with risk factors and a universally available behavioral hearing screen at age 8 to 10 months. Children with intellectual disability and non-English speakers were excluded from the study. | Few children were diagnosed younger than age 6 months (n=11) or 12 months (n=28); comparisons between early vs. late diagnosed children were not reported. | Outcome measures were adjusted for confounders using multiple regression for non-verbal IQ, maternal education, paternal occupational prestige, and family functioning. | Age at diagnosis did not contribute significantly to variance on language, speech, or reading measures except receptive vocabulary; severity of impairment contributed to variance on all measures except reading comprehension. Language outcomes were more than 25 points lower than expected from IQ scores and were related to the severity of impairment, but not age at diagnosis. Age at diagnosis was negatively correlated with severity at diagnosis.
Reviewed for prior report:
Apuzzo and Yoshinaga-Itano, 1995 ^44^ (Fair) | Convenience sample of 69 high-risk infants diagnosed between ages 2 and 25 months. Children with severe cognitive delay were excluded. | Late-identified group was more likely to have severe to profound hearing loss (65% vs. 50%). No report of attrition or follow-up rates. | One-way ANOVA did not adjust for SES, family involvement, or other potential confounders. | At age 40 months, infants identified before age 2 months had higher mean Minnesota Child Development Inventory (MCDI) scores for expressive language (p<0.01).
Calderon and Naidu, 2000 ^37^ (Fair) | Cohort of 80 children with profound hearing loss enrolled in Early Child Hearing Intervention (ECHI) in Seattle Washington. Children with developmental delay were excluded. Cohort grouped by 3 levels by age of entry into program: <1 year (n=9), 12–24 months (n=39), >24 months (n=32). The method of sampling is not described, but the design excluded patients who entered the program but did not graduate. | Not reported. Late diagnosed group had less severe to profound loss (36% vs. 66%). Overall loss to follow-up not reported. Because the early-diagnosed group was in the program longer, they had more opportunity to drop out, so a differential loss to follow-up is likely. | Controlled for degree of hearing loss, degree of outcome impairment that was present upon entry into program (baseline test levels). | At age 3 years, age at entry to program explained 43.5% of the variance in receptive language and 49% of the variance in expressive language. Children treated before age 2 years had better outcomes than those treated after age 2 years. Only 3 children entered the program prior to age 6 months.
Mayne et al, 2000 ^43^ (Poor) | Convenience sample of 113 children ages 24 to 73 months, divided into those diagnosed before and after age 6 months. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Overlap of sample with previous CHIP studies was not reported. | Demographic comparisons of the groups were not reported. No report of attrition of follow-up rates. | Regression analysis adjusted for degree of hearing loss, mode of communication, other disabilities, parents' hearing, CQ, mother's education, ethnicity, SES. | At ages 24 to 36 months, age at diagnosis explained 23% of the variance in expressive language scores.
Reviewed for prior report:
Moeller, 2000 ^36^ (Fair) | Convenience sample of 112 5-year-olds who completed the Diagnostic Early Intervention Program in Lincoln, Nebraska. Children with non-verbal IQ <70 and those who did not participate in program through age 5 were excluded. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Outcome assessments were made pre- and post-intervention. | Not reported. No report of attrition or follow-up rates. Early identified children may have more opportunity to drop out, although differential drop out may be less of a problem at 5 years than in studies assessing closer to enrollment. | Multiple regression analysis adjusted for family involvement, degree of hearing loss and non-verbal IQ. | At age 5 years, family involvement accounted for 57% of variance in vocabulary and age of enrollment accounted for 11.5%. Adjusted mean vocabulary and reasoning scores were within normal range among children enrolled prior to age 11 months but were lower for later-identified children (11 to 23 months 0.69 SD lower, 24 to 35 months 0.99 SD lower).
Yoshinaga-Itano and Apuzzo, 1998 ^40^ (Poor) | Convenience sample of 40 high-risk infants, divided into those identified and treated before age 6 months (n=15) and those treated after age 18 months (n=25). Children with severe cognitive delay were excluded (DQ<60). | Late-identified group was more likely to have severe to profound hearing loss (52% vs. 47%). No report of attrition or follow-up rates. | Sex, severity of hearing loss, cognitive function, and other disabilities were examined in 2-way ANCOVAs, not multiple regression (no simultaneous adjustment for multiple confounders). | At age 40 months, infants identified before age 6 months had better adjusted mean MCDI scores for expressive language (81.1 vs. 64.3, p<0.05 ) and receptive language (84.4 vs. 70.1, p<0.05).
Yoshinaga-Itano and Apuzzo, 1998 ^41^ (Poor) | Convenience sample of 82 infants, ages 19 to 36 months, with mild to profound hearing loss, divided into those identified before age 6 months (n=34) and between ages 7 and 18 months of age (n=48). Early group identified by high-risk registry; late group by usual care. Children with severe cognitive delay were excluded (DQ<60). | Late-identified group was more likely to have severe to profound hearing loss (77% vs. 42%). No report of attrition or follow-up rates. | Sex, severity of hearing loss, cognitive function, and other disabilities were examined in 2-way ANCOVAs, not multiple regression (no simultaneous adjustment for multiple confounders). | At age 26 months, infants identified before age 6 months had better adjusted mean MCDI scores for expressive language (76.2 vs. 56.6, p=0.001), receptive language (82.1 vs. 58.3, p=0.002), MacArthur CDI adjusted mean receptive vocabulary (200 vs. 86.4, p<0.001), and expressive vocabulary (117 vs. 54, p<0.03).
Reviewed for prior report:
Yoshinaga-Itano et al, 1998 ^42^ (Poor) | Convenience sample of 150 children ages 13 to 36 months with mild to profound hearing loss, divided into those identified before (n=72) or after (n=78) age 6 months. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Selection bias is likely because the design probably excluded infants who were diagnosed to have hearing loss but did not enter the program, or who entered, but were lost to follow-up. | At baseline, compared groups differed in some demographic characteristics and in the proportion of subjects with cognitive impairment and severe to profound hearing loss (CQ <80, 29% early group vs. 56% late group; severe to profound hearing loss 34% early group vs. 46% late group). No report of attrition or follow-up rates. | There was stratification by CQ (<80 vs. >80). Other covariates (sex, minority status, maternal education level, Medicaid status, severity, mode of communication, other disabilities) were examined singly in 2-way ANCOVAs. | At ages 13 to 36 months, adjusted mean MCDI receptive language LQ was higher for those identified before age 6 months (79.6 vs. 64.6, p<0.001). Mean MCDI expressive LQ was higher (78.3 vs. 63.1, p<0.001) and total language (79 vs. 64, p<0.001) was higher in early-identified group. No differences in LQ among 4 age of identification levels in late-identified group.
Yoshinaga-Itano et al, 2000 ^39^ and 2001 ^38^ (Poor) | Children born in a hospital with a UNHS program in effect at time of birth (n=25) were compared to children born in a hospital without a UNHS program (n=25). All subjects had been enrolled in CHIP program. Eligibility for the screened group was determined by the availability of an assessment of language outcomes. The creation of the study groups and description of the patients limited the conclusions that could be drawn. | The exposure was birth at a hospital with a UNHS program, not age of identification. Because the groups were drawn from different hospitals and time periods, factors other than exposure to UNHS might have influenced outcomes. Selection of subjects and assessment of outcome were unblinded, and neither the number of excluded subjects, nor the reasons for exclusion, are reported. | Pairs matched on age of testing (9–61 months), degree of hearing loss (mild, moderate, moderately severe, profound), and CQ. | Mean scores (SE) for expressive, receptive, and total language were within normal range for the screened group and 18 to 21 points higher (p<0.001) than the unscreened group (expressive language 82.9 [3.7] vs. 62.1 [4.3]; receptive language 81.5 [3.7] vs. 66.8 [4.0]; total language 82.2 [3.3] vs. 64.4 [3.9]). Language development was within normal range for 56% of the screened group compared to 24% of the unscreened group.

Abbreviations: ANCOVA, analysis of covariance; ANOVA, analysis of variance; CHIP, Children's Health Insurance Program; CQ, cognitive quotient; DQ, developmental quotient; ECHI, Early Child Hearing Intervention; LQ, language quotient; MCDI, Minnesota Child Development Inventory; SE, standard error; SES, socioeconomic status; UNHS, universal newborn hearing screening.

A total of 120 children with PCHL were identified from a cohort of 157,000 children born in 8 districts of southern England between 1992 to1997, and underwent speech and language assessment at school age (mean 7.9 years; range 5.4–11.7). Included children were either part of the Wessex Trial, ^18^ constituting 34% of the birth cohort in this study, or from districts in Greater London providing UNHS or not at the time of birth. Estimates of the completeness of ascertainment of eligible children in the cohort exceeded 95%. Study participants with PCHL represented 71% of eligible children in the cohort and were similar to nonparticipants in age, sex, and severity of hearing loss. It was not reported if there was differential loss to follow up between screened/unscreened or early/late diagnosed groups.

Protocols for screening and confirmation of hearing impairment were similar at all sites, and all children had bilateral impairment of at least 40 dB hearing level. ^18^ All children were also screened using the Health Visitor Distraction Test at age 7 to 8 months as usual care in the U.K. Therapy was provided for all children as a public health service and included education and audiology services with access to hearing aids. Sixty-three age-matched children with normal hearing underwent testing to derive z scores for outcome measures. The z scores represent the number of standard deviations of the distribution of scores in children with normal hearing by which age-adjusted scores of children with hearing impairment differ from the mean scores of children with normal hearing.

Baseline characteristics were similar between comparison groups (sex, English as first language, nonverbal ability using Raven's Progressive Matrices score, age at assessment, degree of hearing loss [moderate 40–69 dB hearing level, severe 70–94 dB hearing level, profound ≥ 95 dB hearing level], presence of other disabilities, mother's education, and occupation of head of household). Outcome measures were adjusted for degree of hearing loss, maternal education, and age-adjusted total Raven's Progressive Matrices scores. Receptive language was evaluated by the Test for Reception of Grammar, British Picture Vocabulary Scale, and aggregate scores. Expressive language was evaluated by the Renfrew Bus Story Test sentence information and 5 longest sentences, and aggregate scores. Speech was evaluated by the Children's Communication Checklist speech scale. Evaluators were blinded to the children's history.

Children who had their hearing impairment confirmed by age 9 months or younger had better adjusted mean scores at school age than those confirmed later on the Test for Reception of Grammar (adjusted mean difference 0.90; p=0.003), British Picture Vocabulary Scale (adjusted mean difference 0.64; p=0.02), and Renfrew Bus Story Test sentence information (adjusted mean difference 0.54; p=0.03); but not on the Renfrew Bus Story longest sentences component, or Children's Communication Checklist speech scale. Differences in higher scores for early versus late confirmation are equivalent to an increase of 10 to 12 points in the verbal compared with nonverbal intelligence quotient.

Children who underwent UNHS had better adjusted mean scores than those who did not on the Test for Reception of Grammar (adjusted mean difference 0.59, p=0.05) and British Picture Vocabulary Scale (adjusted mean difference 0.47, p=0.08), but not the Renfrew Bus Story test or Children's Communication Checklist speech scale. More children undergoing newborn screening had confirmation of impairment by age 9 months than those not screened as newborns (67% versus 27%; CI 24–56%; p<0.001). Associations between early confirmation or exposure to UNHS and outcomes were similar in the Wessex and Greater London subgroups.

Limitations of the study include potential for underestimation of the size of benefit because the system of screening and follow-up has improved since the study birth cohort underwent these processes. Also, it is not clear if children not undergoing UNHS had the onset of hearing impairment after birth or not. A sensitivity analysis indicated that benefit for the UNHS group would have been higher if all cases in the study were truly congenital. Speech was assessed on the basis of parental or professional report which may lack sensitivity as an outcome measure, rather than by direct measurement.

A fair-quality retrospective cohort study conducted in Australia provides speech and language outcomes for a birth cohort exposed to risk based newborn hearing screening. ^35^ This study examined the relationship of age at diagnosis of PCHL and severity of impairment on several language, speech, and reading measures in children age 7 to 8 years who were fitted with hearing aids by age 4.5 years (Table 2). All children born in the state of Victoria who were identified with PCHL through risk based screening of infants, universally available behavioral hearing screening at age 8 to 10 months, and other referral mechanisms were included. The government provided services for all eligible children and data obtained at the time of services were used in the study. Children with intellectual disability and non-English speakers were excluded from the study.

Several outcome measures were examined using validated methods including receptive and expressive language (Clinical Evaluation of Language Fundamentals), receptive vocabulary (Peabody Picture Vocabulary Test), cognition (Perceptual Organization Index of the Wechsler Intelligence Scale for Children), articulation (Goldman-Fristoe Test of Articulation), reading comprehension (Reading Progress Test 1), intelligibility (teacher questionnaire), and family functioning (McMaster Family Assessment Device). Evaluators were blinded to the children's history and hearing status. Regression models were constructed that controlled for confounders including nonverbal intelligence quotient, maternal education, paternal occupational prestige, and family functioning.

Few children in the cohort were diagnosed with PCHL younger than age 6 months (n=11) or 12 months (n=28). The mean age of diagnosis was 21.6 months and mean age of hearing aid fitting was 23.2 months. Comparisons of characteristics between early versus late diagnosed children were not reported except that the age at diagnosis was negatively correlated with severity at diagnosis. Age at diagnosis did not contribute significantly to the variance on any measures except receptive vocabulary. The severity of impairment contributed significantly to the variance on all measures except reading comprehension. Language outcomes were more than 25 points lower than expected from intelligence quotient scores.

Both the Australian and U.K. ^33^ studies use similar methodologies utilizing population-based birth cohorts, assessment and intervention using government-supported services, and evaluation of speech and language outcomes at ages 7 to 8 years. However, the small number of children diagnosed by age 6 months in the Australian study may provide inadequate power to evaluate the effect of age of diagnosis on outcomes. Other differences include types of services provided, educational systems, and use of different outcome measures.

Several other observational studies report the effects of early intervention programs. ^36^ – ^44^ These studies were reviewed for the previous USPSTF recommendation and are briefly summarized for this update in Table 2. All of these studies have important methodologic limitations including use of convenience samples, nonblinded assessments, and lack of information on attrition and follow-up, among others. ^3,^ ^4^ All of these studies report better outcomes for children with hearing impairment identified and/or treated early versus late. One study specifically examined the effect of UNHS on expressive, receptive, and total language outcomes. ^39^ Children who were screened had better outcomes than those not screened, however, potential selection bias and noncomparability of groups limit the conclusions of this study.

## Key Question 2. Compared with targeted screening, does UNHS increase the chance that treatment will be initiated by age 6 months for average risk infants? For high risk infants?

### Summary

No trials compare targeted screening with UNHS and report data about initiation of early treatment for average or high risk infants. Data from a large nonrandomized trial and descriptive studies indicate that average and high risk infants with PCHL born in hospitals with UNHS have earlier referral and initiation of treatment than those born in hospitals without UNHS. In the nonrandomized trial, one additional case of PCHL was referred before the age of 6 months for every 1,969 (1,011–12,896) infants in the UNHS population.

### Evidence

Wessex Universal Neonatal Hearing Screening Trial. The Wessex Universal Neonatal Hearing Screening Trial is a good-quality nonrandomized controlled trial investigating whether the addition of UNHS to usual care screening at age 7 to 8 months versus usual care screening alone increases detection and improves early management of infants with PCHL in the U.K. ^18^ The trial does not measure other benefits to the infants, compare targeted versus universal screening, or compare average versus high risk newborns, but reports characteristics of the cohort.

The trial included all infants born in 4 participating hospitals from 1993 to 1996 including 25,609 born during periods of UNHS and 28,172 not screened as newborns. Two teams of testers (trained nursery nurses) and equipment moved between 2 pairs of hospitals to achieve 4 periods of 4 to 6 months duration with UNHS and 4 without. Most infants were screened within 48 hours of birth. Infants in special-care baby units and neonatal intensive care units (NICU) were screened at the end of their hospital stays. Newborns who screened positive using OAE followed by ABR in those who failed the first test were referred for audiological assessment to determine their hearing level. These are public health services available to all children. All infants were also subjected to screening using the Health Visitor Distraction Test at age 7 to 8 months as usual care.

Results indicate that 87% of all eligible newborns were screened at birth and 8.1% of screened newborns had known risk factors. These include family history of hearing impairment, perinatal infection, birthweight <1.5 kg, anatomical deformity, birth asphyxia, chromosomal abnormality, and exchange transfusion. Sixty-four percent of newborns with PCHL had one or more of these risk factors (95% CI, 50–77%). Special-care and NICU patients accounted for 36% of infants with PCHL.

The screening protocol had a false positive rate of 1.5% and a false negative rate of 4%. The yield of screening was estimated at 90 cases of PCHL of 40 dB hearing level or more per 100,000 target population (equivalent to 80% of expected prevalence in the population).

Several comparisons between infants undergoing UNHS and those who did not indicated:

- 71 more infants per 100,000 were referred before age 6 months during periods with UNHS versus during periods without. This proportion is equivalent to 19 times higher than nonscreened newborns.
- The odds of confirmation before age 10 months adjusted for severity was 5.0 (1.0–23.0) times greater for screened versus nonscreened newborns.
- The odds of initiating management before age 10 months was 8.0 (1.2–51.0) times higher for screened versus nonscreened newborns.
- Improvement in the ages of confirmation and management were significant specifically for infants with moderate or severe PCHL, but not those with profound impairment.
- The relative risk was 2.3 (1.1–4.7) for detection through newborn screening versus the Health Visitor Distraction Test.

All newborns enrolled in the Wessex Trial were included in an 8-year follow-up study. ^17^ Long-term follow-up of all screened and nonscreened newborns in the trial allowed more precise calculations of screening performance and effectiveness. Children with abnormal newborn screening tests, abnormal Health Visitor Distraction Tests, or concern for impairment were referred to audiology services. Information about diagnoses and management was obtained from multiple sources (records, therapists, etc.). Children with postnatal causes of hearing impairment were excluded from the study.

In this analysis, one additional case of PCHL was referred before the age of 6 months for every 1,969 (1,011–12,896) infants in the UNHS population. More children with true PCHL were referred to audiology services prior to age 6 months if they were born during periods with UNHS than during periods without (74% versus 31%; difference 43%; 95% CI 19–60%; p=0.001). Adjustment for the effect of severity of hearing impairment on age of referral increased the odds ratio between newborn screening and early referral from 6.3 to 6.9 (2.2–22.0; p=0.001). The percentage of all true cases referred was greater at any given age during the first 3 years for children screened as newborns versus not; percentages were similar after age 3 years. The age at referral was lower for children undergoing UNHS versus not (0 months versus 8 months; p<0.001). It was noted that 8 children with hearing impairment had screened negative in infancy and 7 had documented progression in severity after detection in infancy. The sum of these 2 figures represents 23% of all cases that might have had progressive losses if the 8 negative screens in infancy had been an accurate reflection of the hearing status of the child at that time.

Results may have been limited by the effects of initiating a new clinical service as part of the trial. Parents of 7 children with subsequently diagnosed hearing impairment initially refused newborn screening. Also, although referrals were early, management was often initiated later than desired (48% after 18 months).

Descriptive Studies of UNHS Follow-up. Several descriptive studies report relevant follow-up data from UNHS programs (Table 3). ^10,^ ^18^ – ^20,^ ^45,^ ^46^ The largest and most recent study describes follow-up of hearing impaired infants who were identified during the first phase of a national UNHS program in the U.K. ^19^ Referred infants with PCHL of 40 dB hearing level or more who were not admitted to the NICU had their first follow-up visits at a median age of 4 weeks, were diagnosed at 10 weeks, enrolled in education services at 10 weeks, and were fitted with hearing aids at 14 weeks. Infants from the NICU utilized these services at slightly older ages: first follow-up at 9 weeks, diagnosed at 13 weeks, and received hearing aids at 24 weeks. Two studies from the U.S. report partial follow-up information. Hearing impaired infants who underwent UNHS in the Colorado Newborn Hearing Screening Project were referred at a median age of 2.1 months. ^10^ Infants referred after UNHS in New York State were diagnosed at a median age of 3 months, enrolled in programs at 3 months, and had hearing aids fitted at 7.4 months. ^20^

Table 3 Descriptive Studies of Universal Newborn Hearing Screening Follow-up

Author, Year, Location | Program Description | Age Screened | Number of Cases | Proportion High Risk | Age Referred | Age at First Follow-up | Age Diagnosed | Age Enrolled in Programs | Age of Hearing Aid Fitting
Uus and Bamford, 2006 ^19^ UK | 169,487 infants at 23 sites in the first phase of a national UNHS program in 2001-2003. Well newborns had OAE, then ABR if needed; NICU newborns had both tests. Referred ≥40 dB hearing level. | Before hospital discharge | 169 | 54% with risk factors^*^ | At screening | Well infants: median age 4 weeks; NICU: 9 weeks | Well infants: median age 10 weeks; NICU: 13 weeks | Median age 10 weeks for education services | Well infants: median age 14 weeks; NICU: 24 weeks
Joseph, 2003 ^45^ Singapore | UNHS of 4,387 newborns in 1999-2001 at 1 hospital using OAE. Positives were rescreened at ~2 weeks, and again at 6 weeks if needed. Referred if specific criteria not met. | Most within 24 hours | 8 | 38% high risk | Those that tested positive at 6 weeks were referred for formal evaluation | NR | 7 of 8 by 7 months | Interventions in place by age 9 months for 4 | NR
Bailey, 2002 ^46^ Australia | UNHS of 12,708 newborns in 5 hospitals in 2000-2001 using OAE and ABR if needed. Referred ≥35 dB hearing level. | Before hospital discharge | 9 | 5 NICU; 8 with risk factors | NR | NR | NR | NR | 6 had hearing aids by 6 months; 1 at 19 months
Mehl, 2002 ^10^ Colorado | Colorado Newborn Hearing Screening Project screened 148,240 newborns in 1992-1999. ABR in 52 hospitals; OAE in 3 hospitals; 2-stage screening in 2 hospitals. Referred >35 dB hearing level in 1 or both ears. | Before hospital discharge | 291 (71% bilateral) | 47% with risk factors | Median age 2.1 months | NR | NR | NR | NR
Dalzell, 2000 ^20^ New York | UNHS of 43,311 newborns in 8 hospitals in New York state in 1995-1996 with OAE and ABR if needed. Referred >20 dB hearing level. | Before hospital discharge | 85 | 61% NICU; 67% with risk factors | NR | NR | Median age 3 months: younger for well babies and for severe or profound impairment | Median age 3 months | Median age 7.5 months
Wessex UNHS Trial Group, 1998 ^18^ UK | UNHS arm of the Wessex Trial including 25,609 newborns screened in 1993-1996 with OAE and ABR if needed. Referred ≥40 dB hearing level. | 3 | 23 | 41% special care units; 74% had risk factors | All by age 6 months | NR | 67% by age 10 months | 63% by age 10 months | NR

* Includes NICU for > 48 hours, family history of hearing impairment, craniofacial anomaly.

Abbreviations: ABR, auditory brainstem response; dB, decibels; NICU, neonatal intensive care unit; OAE, otoacoustic emissions test; UNHS, universal newborn hearing screening.

These results contrast with follow-up data for children who did not undergo UNHS. In addition to results of the Wessex Trial described above, ^17,^ ^18^ descriptive data from parent surveys indicate later ages of diagnosis and initiation of therapy in children not undergoing UNHS. In a national survey of 151 parents with children under age 6 years with hearing impairment in the U.S., children screened as newborns were diagnosed and received hearing aids at younger ages than those not screened. ^47^ For children with unknown causes for hearing impairment, the median ages of confirmation for screened versus nonscreened children were 4 versus 25 months for mild/moderate impairment, and 2 versus 15 months for severe/profound impairment. The median ages for hearing aid fitting for screened versus nonscreened children were 6 versus 30.5 months for mild/moderate impairment and 4 versus 16 months for severe/profound impairment. A survey of parents of 77 nonscreened children with severe to profound hearing impairment attending specialized educational programs in Illinois indicated the median age of suspicion of hearing loss was 8 months, diagnosis 12 months, and hearing aid fitting 15.5 months. ^48^

## Key Question 3. What are the adverse effects of UNHS and early treatment?

### Adverse Effects of Screening

Two fair-quality cohort studies, ^49,^ ^50^ one poor-quality case-control study, ^51^ and 5 survey studies with >40% response rates ^51^ – ^55^ provided relevant information on adverse effects of newborn hearing screening (Table 4).

Table 4 Studies of Potential Adverse Effects of Screening

Study, Year (Quality) | Study Design | Subjects | Screening | Setting | Results
Kennedy, 1999 ^49^ (Fair) | Retrospective cohort | Parents of average-risk newborns: 100 passed UNHS and 100 did not pass; subset of Wessex Trial. | 1 OAE; 2 ABR | UK; 2–12 months after UNHS | No differences in scores on the Spielberger State-Trait Anxiety Inventory & Attitudes Toward the Baby Scale between parents of newborns who passed UNHS versus not passed.
Weichbold, 2001 ^50^ (Fair) | Prospective cohort | 85 mothers whose newborns failed first and/or second screening tests. | OAE; 2 times | Innsbruck, Austria | 59% of mothers whose newborns failed the first screen were not concerned, 27% were slightly concerned, and 14% were highly concerned. In an additional sample of 43 mothers whose newborns failed the 2nd screening, 42% were not concerned, 37% were slightly concerned, and 21% were highly concerned. Differences in proportions between groups were not statistically significant.
Poulakis, 2003 ^51^ (Poor) | Case control | Parents of infants:; 1 108 at risk for hearing impairment;; 2 64 controls for Group 1;; 3 103 failed distraction test;; 4 53 controls for Group 3. | Distraction test | Australia | Parent concerns about language development, general development, and perceived vulnerablity to ill health did not differ among the 4 groups. Approximately 18% of parents continued to feel worried 6 months after the definitive hearing testing. 6% rated the test procedures as somewhat difficult/unpleasant. Parents of children who failed the distraction test reported more negative emotions (anger, sadness, upset, worry, and confusion) after their child's definitive hearing test than parents of children considered at risk (p<0.05).
Crockett, 2006 ^52^ | Survey (questionnaire) | Parents of 722 screened newborns (53% response rate); 1 103 with 1or 2 negative tests;; 2 81 with 3rd negative test;; 3 105 with 3rd test positive in 1 ear;; 4 55 with 3rd test positive in both ears. | OAE; ABR final test | UK; 3 weeks & 6 months post screening | Significant trends for increased anxiety (p<0.05), increased worry (p<0.001), and decreased certainty (p<0.001) as number of tests increased. Parents in Group 4 who understood test implications had lower anxiety (p=0.01) and lower worry (p<0.01) versus those who did not.
de Uzcategui, 1997 ^53^ | Survey (questionnaire) | Parents of 201 screened newborns who were referred for further testing (51% response rate). | Not reported | Colorado, USA; 2 university hospitals | 78% of parents were not angry, 81% felt informed, 38% did not feel comforted by hospital staff. 14% had negative emotions, half had a child with a confirmed hearing loss. Parents of children with confirmed hearing losses had a higher level of frustration, anger, depression, and confusion versus other parents. 25% of the sample did not return for follow-up testing after a referral was indicated.
Hergils, 2000 ^55^ | Survey (questionnaire) | Parents of 83 screened newborns (95% response rate). | OAE | Linkoping, Sweden;well baby visit, 5–6 months old | 76 were satisfied with screening, 3 neutral, 3 dissatisfied, 1 did not know. Screening raised questions for 28 and no questions for 44. 79 were positive about the test and 4 negative. Information on the test was sufficient for 64 and insufficient for 9. The majority of parents were positive about the screening; most felt early detection was good, test was easy and did not bother their infant.Negative comments included the test being too demanding, test took too long, clearing the ear canal would be difficult for newborn. Complaints included getting information about the test earlier and test methodology. Parents of 6 of the 10 infants needing retesting reported anxiety.
Russ, 2004 ^56^ | Survey (questionnaire) | Parents of 134 hearing impaired children after hearing aid fitting (61% response rate). | ABR; distraction test | Victoria, Australia | Themes analysis showed parents had a generally positive response to ABR screening and mixed response to the distraction test; denial and shock at diagnosis; frustrations in delays in diagnosis; and communication difficulties with providers. Difficulty testing children with other medical and development problems were also reported.
Vohr, 2001 ^54^ | Survey (interview) | Mothers of 307 screened newborns (85% response rate); Mothers of 40 newborns needing rescreening (90% response rate). | OAE | Rhode Island, USA | Significantly more mothers with infants who were rescreened worried about the test results compared to mothers with infants undergoing only one screening (p<0.001). For mothers of infants requiring rescreening, the degree of worry at the time of the rescreening was significantly greater than at the first screen (p<0.001). Greater worry at the initial screening was seen in mothers with less than high school education (p=0.003) and who were bilingual (p=0.006), non-married (p=0.02), and non-white race (p=0.005). Learning about screening during hospitalization versus before arriving was also associated with greater worry (p=0.012).

Abbreviations: ABR, auditory brainstem response OAE, otoacoustic emissions; UNHS, universal newborn hearing screening.

In a subset of the Wessex Trial, 100 parents of infants who passed UNHS and 100 parents with infants who did not pass were given questionnaires 2 to 12 months after screening. All infants were considered low risk for hearing impairment. No differences were found on the Spielberger State-Trait Anxiety Inventory or the Attitudes Toward the Baby Scale between parents with infants who passed and did not pass screening. ^49^ In another fair-quality cohort study in Austria, using non-validated measures, 85 mothers of infants who did not pass either a one-step or two-step screening test were found to have no significant differences in their levels of concern. ^50^ In this study, 14% to 21% of parents reported feeling highly concerned, with the mothers whose infants failed the 2nd test showing the highest levels of anxiety.

In a poor-quality case-control study evaluating the impact of false positive results from screening, 2 groups of screen positive infants (failed risk assessment and failed distraction test) and 2 matched control groups were compared. ^51^ Response rates were 51% or lower in the control groups. The majority of parents whose infants initially screened positive showed relief and improved negative emotions after a normal diagnostic test. However, approximately 20% of parents showed some residual worry 6 months after the normal test. ^51^

In a survey of 344 mothers in the U.K. administered 3 weeks and 6 months after newborn hearing screening, there was an increase in worry (p<0.001) and decrease in certainty (p<0.001) as the number of testing recalls increased. ^52^ Although general understanding of the screening test did not moderate anxiety, mothers who understood that receipt of a positive first test was unlikely to mean that the baby had a hearing loss had lower anxiety (p=0.01) and lower worry (p<0.01) than mothers who did not.

Parents at two university hospitals in Colorado were interviewed following their first newborn hearing screening test that required referral. ^53^ Although 78% reported not feeling angry about what was happening to them and their child and 81% felt informed, 38% did not feel comforted by hospital staff. Half of parents with a child with a confirmed hearing loss expressed negative emotions including frustration, anger, depression, and confusion. ^53^

Mothers of 307 infants participating in the Rhode Island Hearing Assessment Program indicted in a survey that learning about UNHS during hospitalization versus before arriving to the hospital was associated with greater worry. ^54^ Significantly more mothers with infants who were retested worried about the test results compared to mothers with infants undergoing only one screening test. For mothers of infants requiring retesting, the degree of worry at the time of the retesting was significantly greater than at the first screening test. Factors associated with increased maternal stress about UNHS included mothers who were non-married, bilingual, non-white race, and/or achieving less than a high school education. ^54^

In a survey 6 months after UNHS, 87 mothers in Sweden were asked about their feelings about the screening experience. ^55^ The parents of the 6 of 10 infants that needed to be retested reported anxiety, while the majority were satisfied with the service, thought the information about the procedure was sufficient, and had a positive feeling about the test. ^55^ A small number of complaints centered around getting information about the test earlier, and the test being too demanding or taking too long.

A survey of 81 Australian mothers with hearing impaired children fitted with hearing aids showed that parents had a generally positive response to ABR screening and mixed responses to the distraction test. ^56^ Parents displayed feelings of denial and shock about their child's diagnosis, frustrations in delays in diagnosis, and communication difficulties with providers. ^56^

### Adverse Effects of Early Treatment

No studies addressed the potential adverse effects of early intervention using hearing aids or other amplification, American Sign Language, English instruction, speech and language therapy, or family education and support.

A growing literature about cochlear implantation in infants and children includes descriptive information about adverse effects. Case series reports of cochlear implantation indicate few surgical complications in children. A series of 300 children receiving cochlear implants in Greece, ranging from age 1 to 17 years, reported an overall rate of 2.3% for major surgical complications and 16% for minor complications. ^57^ There were no surgical complications among children under age 12 months in small U.S. case series, ^58,^ ^59^ or in those under age 2 years in a small U.K. case series. ^60^

The FDA released public health notifications about the increased risk of bacterial meningitis in children with cochlear implants, with highest risks among those using implants with positioners. ^61^ A positioner is a wedge inserted next to the implanted electrode to facilitate transmission. Implants with the positioner were voluntarily recalled in the U.S. in 2002. Among children who had cochlear implantation from 1997 to 2002 at less than age 6 years, 41 episodes of postimplantation bacterial meningitis occurred among 38 children. ^62,^ ^63^ Of these, 71% had implants with positioners. Although the rate of meningitis decreased as the time after implantation increased, 20% of cases occurred after 24 months or more and were found exclusively in children with positioners. ^63^ None of the children with meningitis received their implants at less than age 12 months and rates of infection did not indicate age-related risks.

Although several studies of psychological issues relating to cochlear implantation in children, such as parental distress, have been published, only one specifically focused on young children. Parents of 28 children (age 12 to 30 months) undergoing cochlear implantation in Turkey noted on questionnaires that making the decision for cochlear implantation was stressful. ^64^ Families were anxious about possible device failure and maintenance of the equipment, and acknowledged that their children needed more support from the family after the implantation. Most parents reported benefits of implantation including improved communication, self-confidence, well-being, and social relationships.

### Yield of Screening

Although no studies directly compare the yields of universal versus targeted screening approaches, estimates can be determined by applying results of relevant studies in an outcomes table model (Table 5). Assumptions for the model include proportion of newborns considered high risk, ^17^ prevalence of PCHL in high risk and average risk populations, ^3^ proportion not screened in the hospital, ^65^ sensitivity of 2-stage screening, ^17^ compliance with follow up testing (estimated), accuracy of diagnostic tests, ^3^ and proportion of average risk newborns diagnosed with PCHL by 3 months (estimated). Using these assumptions, if 10,000 newborns underwent UNHS, there would be 11 to 12 diagnosed cases by age 3 months, 86 false positive screening tests, and possibly 1 missed case. The number needed to screen (NNS) to diagnose one case would be 878. If only high-risk newborns underwent screening, there would be 4 or 5 diagnosed cases, 6 false positive screening tests, and 8 or 9 missed cases. The NNS to diagnose one case would be 178.

Table 5 Yield of Screening in a Hypothetical Cohort of 10,000 Newborns for Moderate to Profound PCHL

| | Hypothetical Model
Relevant Factors | Probability or effect size | UNHS | High-risk screening^*^
Assumptions
Proportion high risk ^17^ | 0.08
Target group for screening | | 10000 | 800
Prevalence ^3^
High risk group | 0.008
Average risk group | 0.0008
Miss rate for UNHS (proportion not screened in hospital; estimate)
In high risk | 0.05
In average risk | 0.05
Follow-up rate for misses | 0.9
Miss rate for high-risk screening
In high risk ^65^ | 0.23
Follow-up rate for misses | 0
Sensitivity of 2-stage screening ^17^ | 0.92
Specificity of 2-stage screening ^17^ | 0.99
Compliance with follow-up (estimate) | 0.9
Accuracy of diagnostic ABR ^3^
Sensitivity | 1
Specificity | 0.995
Proportion of low-risk diagnosed by 3 months without screening (estimate) | 0.1
Results
Number of infants screened | | 9500 | 616
High risk | | 760 | 616
Average risk | | 8740 | 0
High risk cases in screened group | | 6 | 5
Average risk cases in screened group | | 7 | 0
Cases diagnosed by 3 months | | 11 to 12 | 4 to 5
High risk cases missed by screening | | <1 | 1 to 2
Average risk cases missed by screening | | <1 | 7
Total number of cases | | 13 | 13
False positive screening tests | | 86 | 6
Normal infants incorrectly diagnosed to have PCHL at first post-hospital audiologic examination | | <1 | <1
NNS to diagnose 1 case | | 878 | 178
NNS to diagnose 1 additional case by 3 months | | 1333 | NA

* High risk defined by risk factors (family history of hearing impairment, perinatal infection, low birthweight, anatomical deformity, birth asphyxia, chromosomal abnormality, exchange transfusion).

Abbreviations: ABR, automated brainstem response; NA, not applicable; NNS, number needed to screen; PCHL, permanent congenital hearing loss; UNHS, universal newborn hearing screening.