# Acknowledgements

The authors acknowledge Andrew Hamilton, MLS, MS, Oregon Health & Science University, for assistance with literature searches; and Christi Sperry, AuD, Newborn Hearing Screening Coordinator, Providence Health & Services, for her expertise. We also thank AHRQ Officers Iris Mabry, MD, MPH and Janelle Guirguis-Blake, MD; and USPSTF leads Ned Calonge, MD, MPH, Leon Gordis, MD, MPH, DrPH, and George Sawaya, MD for their contributions to this report.