# Summary Tables

Table 1. Diabetes Guidelines.

Table 2. Studies Modeling Screening for Type 2 Diabetes (KQ1).

Table 3. Randomized Controlled Trials of Hypertension Treatment in Diabetic Populations (KQ2).

Table 4. Randomized Controlled Trials of Lipid Interventions in Diabetic and Nondiabetic Populations (KQ2).

Table 5. Studies Modeling Treatment of Persons with Newly-Diagnosed Type 2 Diabetes (KQ2).

Table 6. Randomized Controlled Trials of Interventions in Prediabetes (KQ3).

Table 7. Studies Modeling Treatment of Prediabetes (KQ3).

Table 8. Studies Examing the Adverse Effects of Screening (KQ4).

Table 9. Systematic Reviews Examining the Adverse Effects of Treatment (KQ5).

Table 10. Outcomes Table.

Table 11. Summary of Evidence.

Table 1 Diabetes Guidelines

Organization Year | Screening Test | Recommendations
American Academy of Family Physicians^71^ 2003 | FPG test or 2-h OGTT (75-g glucose load); the recommended initial screening test in nonpregnant adults is FPG. | Follows 2003 recommendations of US Preventive Services Task Force.
American Diabetes Association^46^ 2007 | FPG test or 2-h OGTT (75-g glucose load); the recommended initial screening test in nonpregnant adults is FPG | Testing should be considered in all adults at age 45 years and above, particularly those with BMI ≥ 25 (kg/m^2^); if normal, repeat at 3 year intervals. Testing should be considered in younger adults or carried out more frequently if BMI ≥ 25 (kg/m^2^) and have additional risk factors (physically inactive, family history of diabetes, high-risk ethnic population, hypertension, prediabetes, have vascular disease, HDL <35 mg/dl and/or triglyceride >250 mg/dl Screen for pre-diabetes and diabetes in high-risk, asymptomatic, undiagnosed adults and children in health care setting.
Australian evidence-based guideline^72^ 2001 | FPG should be measured for initial screening; OGTT for all people with an equivocal result | Recommend identifying and treating type 2 diabetes at a stage before clinical presentation; case detection has a favorable risk:benefit ratio; screening and diagnostic tests are cost-effective and safe; potential harms are uncertain. High risk individuals (IGT, IFG, > 45 years with hypertension or BMI > 30, known cardiovascular disease, women with polycystic ovary syndrome who are obese, various ethnic groups) Recommend testing each year for people with IGT or IFG and every 3 years for people with high risk and a negative screening test.
Diabetes UK^73^ 2006 | Limited evidence available to identify the most effective and practical method of screening. Recommends fasting capillary or venous blood glucose measurement Test every 3 years for those with increased risk. | General population screening is not recommended. Targeted case finding of high risk groups is encouraged (Caucasians >40 years and minority ethnic groups > 25 years with one or more risk factors [family history, overweight or obese, sedentary]; people with known IFG or IGT; women who have had gestational diabetes; women with polycystic ovary syndrome who have a BMI > 30; people who have ischemic heart disease, cerebrovascular disease, peripheral vascular disease or treated hypertension)
US Preventive Services Task Force^75^ 2003 | FPG test or 2-h OGTT (75-g glucose load); the recommended initial screening test in nonpregnant adults is FPG. | The evidence is insufficient to recommend for or against routinely screening asymptomatic adults for type 2 diabetes, impaired glucose tolerance, or impaired fasting glucose. Could not determine the balance of benefits and harms of routine screening. Recommends screening for type 2 diabetes in adults with hypertension or hyperlipidemia.
World Health Organization^74^ 2003 | Method(s) should depend on resources available, acceptability of method for the population, and levels of sensitivity and specificity required | There is no direct evidence (i.e., from randomized controlled trials) that individuals will benefit from early detection of type 2 diabetes through screening. Health authorities and professional organizations should formulate their own policies based on individual benefits and costs.

Abbreviations: BMI, body mass index; FPG, fasting plasma glucose; HDL, high density lipoprotein; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; OGTT, oral glucose tolerance test.

Table 2 Studies Modeling Screening for Type 2 Diabetes (KQ1)

Author Year (in date order) | Type of screening; Perspective | Type of model; Time horizon | Population Country | Included costs; Discount rate | Intervention | Outcomes | Conclusions | Quality assessment
CDC Diabetes Cost-Effectiveness Study Group 1998^90^ | One-time opportunistic screening during regular physician visit; Single-payer health care system | Monte Carlo computer simulation model Lifetime or age 95y | 10,000 cohort with newly-diagnosed DM2; general population US | Used data from DM1 for microvascular disease risk reduction with treatment 3% annual rate | One-time screening intervention with FPG, OGTT for confirmation of positives | Incremental cost of screening is $236,449 per life-year gained and $56,649/QALY; more CE among younger persons and among African Americans | Screening may produce cost/QALY within range of currently acceptable, especially for younger persons Model does not take into account effect of blood glucose control on CVD | Limited sensitivity analyses CVD not modeled; screening and treatment only influence microvascular complications No information on how QALYs determined No mention harms of screening Lack of transparency of details of model Used data from DM1 for microvascular disease risk reduction with treatment
Goyder et al, 2000^91^ | Universal screening Perspective: NA (does not involve cost) | Decision analysis Lifetime | 10,000 cohort UK | NA 3% annual rate for QALYs | Various interventions for hyperglycemia, HT, lipids | QALYs gained by screening 10,000 persons: 10.5 | The immediate disutility of earlier diagnosis and additional treatment may be greater than the potential long-term benefit from postponing microvascular complications; screening decisions should be based largely on CVD risk and interventions to reduce that risk | Used data from DM1 for microvascular disease risk reduction with treatment Details and assumptions of the model not clear
Hofer et al, 2000^92^ | Mass screening Not an economic analysis | Markov model Lifetime | Recent onset of diabetes (<5y) derived from NHANES III | NA | Hypertension and lipid NHANES III; DCCT | Number blind/1000 diabetics age 40y, A1c 12%: Case finding: 141 Perfect screening: 133 Case finding, A1c <9%: 90 Screening, A1c <9%: 41 Screening produces 7% of the benefit of reduced number of cases of blindness; improved treatment alone is 65% | Largest impact of improving treatment and diagnosis is in younger persons with high A1c; focus should first be on improving glycemic control of known diabetics with high A1c; if that is achieved, then the benefits of screening will become more important | Does not include benefits of HT and lipid treatment Only examines microvascular complications
Chen et al, 2001^43^ | Mass screening Single payer health plan | Markov process Monte Carlo simulation 30y or death | Over age 30y, general community population Taiwan | Direct costs including costs of screening, treatment 3% annual rate | Screening program lasts for 10y; standard treatments such as that of UKPDS for persons with DM2 | Cumulative incidence rates of microvascular complications with screening: 2y frequency: Blindness: 3.06%; ESRD: 0.19%; LEA: 0.97% 5y frequency: Blindness 3.13%; ESRD: 0.19%; LEA: 0.99% Control (no screening): Blindness: 4.3%; ESRD: 0.54%; LEA: 1.43% NSD between 2 and 5y screening CE (cost/QALY): 2y: $17,833; 5y: $10,531 Incremental cost/QALY: lowest 40–49y group ($9,193), highest 70+y ($36,467) | Mass screening is relatively cost-effective compared to opportunistic screening as costs incurred with mass screening are offset with life-years gained Mass screening for DM2 is relatively cost-effective compared to other screening interventions (e.g., cervical cancer or HT) Screening is more cost-effective in younger than older persons Model focuses on microvascular complications | Lack of transparency for assumptions, data synthesis No sensitivity analyses Does not include CVD risk reduction in model Does not include adverse effects of screening
Hoerger et al, 2004^87^ | One-time opportunistic screening targeted to persons with HT Health care system perspective | Markov Lifetime | General primary care population US | Direct medical costs: screening, diagnostic tests, treatment 3% annual rate | Treatment of HT to goal of DBP 80mm Hg (HOT); intensive glycemic control for diagnosed DM2 (UKPDS) | Results per true diabetes case, compared to no screening: QALYs gained per person screened (cost/QALY): Targeted screening for people with HT only: range 0.08 with screening at 35y ($87,096) to 0.23 for screening at 65y ($31,228) Universal screening: range 0.05 with screening at 35y ($126,238) to 0.11 for screening at 75y ($48,146) Universal vs targeted screening, incremental cost/QALY: 35y: $143,830; 75y $443,433 | Targeting screening to persons with HT is more CE than universal screening at every age when each alternative is compared to no screening Targeted and universal screening more CE when take into account reduction in CVD events from earlier treatment of HT for ages 55, 65, 75 than for 35 and 45y The most CE approach to one-time screening: target people with HT 55 to 75y Benefit of screening comes mainly from reducing CVD events by control of HT rather than from reducing microvascular complications | Did not include adverse effects of screening Thorough sensitivity analyses Includes sub-models for CVD and stroke Includes benefits for tight BP control, but not other CVD risk reduction interventions Assumes 100% uptake and follow-up
Glumer et al, 2006^93^ | Population screening Health care system | Population-based simulation model 5y | Community-based Denmark | Screening and treatment for DM2 and complications | Based on community sample age 30–60y | Least conservative model (low costs and multiplicative risk reduction for combined treatments): Cost/number of events prevented: £23,000 to 82,000; major contributors to uncertainty: risk reduction for hypertension treatment and UKPDS risk model intercept Model not sensitive to decisions about which groups to screen nor to costs of screening or treatment; model strongly affected by assumptions about how treatments combine to reduce risk. | There is considerable uncertainty about the CE of screening for DM2; the most important parameter is the effect of treatment and whether risk reductions are multiplicative or additive | Model combines effects of treatment of hyperglycemia, hypertension and dyslipidemia Time horizon only 5y
Waugh et al, 2007^13^ | Population screening National Health Service | Markov Lifetime | General population UK | Screening and treatment for DM2 and complications 3.5% for costs and benefits | Screen with A1c then OGTT Various interventions for hyperglycemia, HT, lipids | Cost reduction and QALYs gained from fewer CVD events, largely from statin treatment, as well as fewer microvascular complications | Screening is relatively cost-effective for persons 40–70y; more CE for the older group and for persons with hypertension or obesity | Includes macro and microvascular complications; relatively simple model

Abbreviations: BP, blood pressure; CVD, cardiovascular disease; DBP, diastolic blood pressure; DCCT, Diabetes Control and Complications Trial; DM1, diabetes mellitus type 1; DM2, diabetes mellitus type 2; CDC, Centers for Disease Control and Prevention; CE, cost-effectiveness; ESRD, end-stage renal disease; FPG, fasting plasma glucose; HOT, Hypertension Outcomes Trial; HT, hypertension; LEA, lower extremity amputations; NA, not applicable; NHANES, National Health and Nutrition Examination Survey; NSD, no significant difference; OGTT, oral glucose tolerance test; QALYs, quality adjusted life-years; UK, United Kingdom; UKPDS, United Kingdom Prospective Diabetes Study; y, year(s).

Table 3 Randomized Controlled Trials of Hypertension Treatment in Diabetic Populations (KQ2)

Study Author, year | Intervention | Sample size (diabetes subgroup/total) | Baseline cardiovascular risk factors* | Achieved blood pressure (mm Hg) | Outcomes | Quality rating; comments
ALLHAT (Antihypertensive and Lipid-lowering Treatment to Prevent Heart Attack Trial) Whelton et al, 2005^103^ ALLHAT Officers, 2002^115^ Barzilay et al, 2001^231^ | Chlorthalidone vs lisinopril vs amlodipine† | 13,101 / 31,512 | HTN: 100/100 History of CVD: 36% / 62% Smoking: 13% / 28% Hyperlipidemia: NR | Mean SBP (SD) in DM subgroup: Chlorthalidone: 135.0 (15.6) Amlodipine: 136.3 (15.9) ‡ Lisinopril: 137.9 (19.0) ‡ Mean SBP (SD) in normoglycemia subgroup: Chlorthalidone: 133.4 (14.9) Amlodipine: 133.5 (14.1) Lisinopril: 134.8 (17.3) | Fatal CVD or nonfatal MI in the DM subgroup: Amlodipine-chlorthalidone: 0.97 (0.86 – 1.10), p = 0.64 Lisinopril-chlorthalidone: 0.97 (0.85 – 1.10), p = 0.59 Fatal CVD or nonfatal MI in the normoglycemia subgroup: Amlodipine-chlorthalidone: 0.94 (0.82 – 1.07), p = 0.36 Lisinopril-chlorthalidone: 1.02 (0.89 – 1.16), p = 0.79 Difference between DM and normoglycemia subgroups: p = NR§ | Fair; significantly higher rate of attrition in the lisinopril group
CONVINCE (Controlled Onset Verapamil Investigation of Cardiovascular End Points Trial) Black et al, 2003^104^ | Verapamil vs atenolol or HCTZ | 3,239 / 16,476 | HTN: 100% Hyperlipidemia: 31.2% Previous MI: 7.6% Established vascular disease: 16.7% Stroke: 4.6% | Mean SPB/DBP in total study sample (DM subgroup NR): Verapamil: 136.5 / 79.0 Atenolol or HCTZ: 136.6 / 79.5 | Fatal CVD, stroke, or MI: DM subgroup: 0.86 (0.66 – 1.12), p = NR Normoglycemia subgroup: 1.10 (0.92 – 1.31), p = NR Difference between DM and normoglycemia subgroups: p = 0.16§ | Fair

* Data reported as percentages for the DM/non-DM groups in the ALLHAT study and for the total study sample for the CONVINCE study (data for the DM subgroup alone NR)

† Doxazosin arm was prematurely discontinued because of an excess of heart failure events

‡ p < 0.5 compared with chlorthalidone

§ p-value for interaction between diabetes and normoglycemia subgroups for primary outcome

Abbreviations: CI, confidence interval; CVD, cardiovascular disease; DBP, diastolic blood pressure; DM, diabetes; HCTZ, hydrochlorothiazide; HR, hazard ratio; HTN, hypertension; LIFE, Losartan Intervention For Endpoint reduction in hypertension study; MI, myocardial infarction; NR, not reported; RR relative risk; SBP systolic blood pressure.

Table 4 Randomized Controlled Trials of Lipid Interventions in Diabetic and Nondiabetic Populations (KQ2)

Study Author, Year | Intervention | Sample Size (Diabetes Subgroup/Total), n/n | Baseline Cardiovascular Risk Factors | Mean Achieved LDL-C Level (SD), mg/dL | Outcome: Relative Risk (95%CI) | Quality; Comments
ALLHAT (Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial) Allhat Officers, 2002^115^ | Pravastatin titrated to achieve 25% reduction in LDL-C vs. usual care | 3635/10 355* | Total group (DM subgroup information NR): HTN: 100% History of CVD: 14.2% Smoking: 23.1% Mean LDL-C: 145.6 mg/dL (SD, 21.4) | Pravastatin: 104.0 (29.1) Usual care: 121.2 (34.6) | All-cause mortality, pravastatin vs. usual care†: DM subgroup: 1.03 (0.86–1.22); P = NR Non-DM subgroup: 0.96 (0.84–1.1); P = NR CHD death or nonfatal MI: DM subgroup: 0.89 (0.71–1.10); P = NR Non-DM: 0.92 (0.76–1.10); P = NR Difference between diabetes and normoglycemia subgroups‡: P = NR | Fair; Relatively small difference in LDL-C between intervention and usual care groups due to withdrawals in intervention group and off-protocol statin use in usual care group
ASCOT (Anglo-Scandinavian Cardiac Outcomes Trial) Sever et al, 2003,^116^ 2005^118^ | Atorvastatin, 10 mg, vs. placebo | 2532/10 305 | DM/total group: HTN: 100%/100% Mean LDL-C: 28.7 mg/dL (SD, 27.3)/124.8 mg/dL (SD, 27.3) Smoking: 20.3%/32.2% Cerebrovascular disease: 7.5%/9.7% Peripheral vascular disease: 5.3%/5.0% Mean number CVD risk factors: 4.1/3.7 | Atorvastatin: 83.9 (26.5) Placebo: 117.8 (30.4) | Nonfatal MI or fatal CHD†: DM subgroup: 0.84 (0.55–1.29); P = NR Non-DM subgroup: 0.56 (0.41–0.77); P = NR Total CVD events and procedures: DM subgroup: 0.77 (0.61–0.98); P = NR Non-DM subgroup: 0.80 (0.68–0.94); P = NR Difference between diabetes and normoglycemia subgroups‡: P = 0.82 | Fair; Study stopped early; relatively low number total events in diabetes subgroup
HPS (Heart Protection Study) HPS, 2003^95^ | Simvastatin, 40 mg, vs. placebo | 5963/20 536 | DM/non-DM: Previous MI: 19%/51% Other history of CVD: 14%/28% Smoking: 67%/78% Blood pressure: 148/82 mm Hg/143/81 mm Hg Mean LDL-C: 124.8 mg/dL (SD, 32.0)/132.6 mg/dL (SD, 32.0) | Simvastatin: 89.7 Placebo: 128.7 | Nonfatal MI or fatal CVD†: DM subgroup: 0.73 (0.62–0.85); P < 0.001 Non-DM subgroup: 0.73 (0.66–0.81); P < 0.001 Stroke: DM subgroup: 0.76 (0.61–0.94); P = 0.01 Non-DM subgroup: 0.74 (0.64–0.86); P < 0.001 Difference between diabetes and normoglycemia subgroups‡: P = 0.10 | Good (for overall trial); Baseline characteristics differed significantly between diabetes and normoglycemic subgroups
PROSPER (Prospective Study of Pravastatin in the Elderly at Risk Trial) Shepherd et al, 2002^117^ | Pravastatin, 40 mg, vs. placebo | 623/5804 | Total group (DM subgroup information NR): Previous angina: 26.9% Previous MI: 13.4% Cerebrovascular disease: 11.2% Vascular disease: 44.2% Mean LDL-C: 148.2 mg/dL (SD, 31.2) Hypertension: 61.9% Smoking: 26.8% | Mean LDL at 3 months: Pravastatin: 96.7 Placebo: 146.6 | Nonfatal MI, fatal CVD, nonfatal and fatal stroke†: DM subgroup: 1.27 (0.90–1.80); P = NR Non-DM subgroup: 0.79 (0.69–0.91); P = NR Difference between diabetes and normoglycemia subgroups‡: P = 0.015 | Fair; Little diabetes-specific information and relatively few persons with diabetes limit conclusions

* Including persons in the doxazosin group

† Primary outcome

‡ P value for interaction between DM and normoglycemia subgroups for primary outcome

Abbreviations: CHD, coronary heart disease; CVD, cardiovascular disease; DM, diabetes; HTN, hypertension; LDL-C, low-density lipoprotein cholesterol; MI, myocardial infarction; NR, not reported.

Table 5 Studies Modeling Treatment of Persons with Newly-Diagnosed Type 2 Diabetes (KQ2)

Author, Year Model (in date order) | Type of screening; Perspective | Type of model Time Horizon | Population Country | Included costs Discount rate | Intervention Data sources | Outcomes | Conclusions
Global Diabetes Model Brown et al, 2000^126,^ ^133^ | NA Payer | Monte Carlo microsimulation, using continuous prediction equations 20y | 5000 newly diagnosed DM2 white males; no CVD or other macro- or microvascular complications; based on Kaiser health maintenance organization US | Direct medical costs 0% | Intensive lipid management (LDL from 150 to 100 mg/dl and HDL from 40 to 50 mg/dl) Kaiser databases, world scientific literature, observational data such as Framingham Heart Study | A1c 9.5%, SBP 130: % survival: 82.7% Total costs per person ($US): $85,920 Lower costs for lower A1c, higher costs for higher SBP | Survival improves with intensive lipid therapy
CDC/RTI (Center for Disease Control and Prevention/Research Triangle Institiute) Diabetes Group 2002^123^ | Health care system (for costs) | Markov model; emphasis on macrovascular complications Subjects proceed through 5 different disease paths; nethropathy, neuropathy, retinopathy, CVD, stroke Death or age 95y | Newly diagnosed DM2; 55% female, 8% 25–34y, 8% 35–44y, 26% 45–54y, 18% 55–64y, 23% 65–74y, 13% 75–84, 4% 84–94y US | Health care system only; no indirect or direct patient costs Costs and QALYs discounted at 3% annually | All subjects received conventional treatment to control BG (UKPDS control arm) Intensive glycemic control: to reduce FPG to <108 mg/dl using chlorpropamide, glipizide, insulin Intensified HT control: ACE-I or Beta-blocker for baseline BP≥160/95 Reduction in TC: pravastatin for baseline level ≥200 mg/dl UKPDS and other sources | Intensive glycemic control applied to all persons newly diagnosed with DM2 in the US: increase in QALY of 0.1915 (discounted), CE ratio: $41,384 per QALY; CE ratio increases markedly with age; cumulate incidence of nethropathy, neuropathy, retinopathy decreased by 11 to 27% Intensified HT control: increased QALYs by 0.392 relative to moderate HT control; CE ratio - $1,959/QALY (ie cost savings); age had little effect; Reduction in TC: increase discounted QALYs 0.3475, CE ratio $51,889 per QALY, lowest ratio for 45–85y | Intensified HT control reduced costs and improved health outcomes relative to moderate HT control; intensive glycemic control and reduction in serum TC increase costs and improve health outcomes Intensive glycemic control is most cost-effective for younger persons
CORE Model (Center for Outcomes Research) Palmer et al, 2004^124,^ ^128^ | Third party payer | Markov using Monte Carlo simulation; 15 submodels each of which simulates different complications associated with DM Lifetime | Newly diagnosed patients: baseline age 52y, A1c 9.1%, SBP 137 mm Hg, TC 212 mg/dl, HDL 39 mg/dl Switzerland; modeled using US payer costs | Direct medical costs; day-to-day DM management costs excluded; expressed in 2003 values in the US setting 3% annual rate for costs; outcomes not discounted | Hypothetical interventions that led to individual 10% improvements in A1c, SBP, TC, HDL UKPDS, Framingham, other published sources | QALE: increased 1.72y with improvements in all of A1c, SBP, TC, HDL Lifetime costs of DM-related complications: decreased $14,533 with improvements in all of A1c, SBP, TC, HDL; improved A1c alone: decreased $10,800, SBP alone: decreased $7,048 | 10% improvements in A1c, SBP, TC, HDL, individually and in combination are likely to improve length and quality of life; most marked improvement with all 4; individually A1c had greatest gains in QALE
UKPDS (United Kingdom Prospective Diabetes Study) Outcomes Model Clarke et al, 2005^125^ 2004^131^ 2003^130^ 2001^129^ | Health care purchaser | Probabilistic discrete-time illness-death model Lifetime (Clarke 2005^125^) Within-trial data: mean duration 10.3y (Clarke 2003^130^) | Newly diagnosed DM2 aged 25–65y; mean age 52.4y, 58% male; 81% Caucasian; n=3867 UK | Direct medical costs 3.5% annually | Intensive BG control with insulin or sulphonylurea vs conventional glucose control (mainly diet); 342 patients >120% ideal body weight assigned to metformin and 411 overweight patients on conventional treatment Embedded study randomized 1148 patients with HT to BP<180/<105 vs n=758 with BP goal <150/85 mm Hg UKPDS for both outcomes and costs | QALY per patient modeled over lifetime: Intensive BG control: 0.15(-0.20, 0.49) Metformin therapy: 0.55(-0.10, 1.20) Tight BP control: 0.29(-0.14, 0.59) Probability of being cost-effective at a ceiling ratio of 20,000 Pounds per QALY: Intensive BG control: 74% Metformin therapy: 98% Tight BP control: 86% Life years gained per patient with metformin treatment versus conventional, within-trial data: 0.6 (95% CI, 0.0, 1.2) | Intensive BG control and BP control for persons with HT adds QALYs over lifetime; relatively cost-effective compared to many other accepted uses of health care resources

Abbreviations: ACE, angiotension-converting enzyme; BG, blood glucose; BP, blood pressure; CDC, Centers for Disease Control; CE, cost effectiveness; CVD, coronary vascular disease; DM2, type 2 diabetes; FPG, fasting plasma glucose; HDL, high-density lipoprotein; HT, hypertension; LDL, low-density lipoprotein; NA, Not applicable; QALE, quality-adjusted life expectancy; QALY, quality-adjusted life years; RTI, Research Triangle Institute; SBP, systolic blood pressure; TC, total cholesterol; UKPDS, United Kingdom Prospective Diabetes Study; y, year.

Table 6 Randomized Controlled Trials of Interventions in Prediabetes (KQ3)

Study Author, Year Quality Rating | Country | Total sample size, n | Mean length of follow-up | Sample characteristics* | Intervention | Outcomes
Diabetes Prevention Program DPP Research Group 2000^139^ 2002^79^ 2005^140,^ ^145^ Fujimoto et al, 2000^141^ Good | United States | 3,234 | 2.8 y; 3.2 y for CVD outcomes | Age, 51 y (10.7); 32.3% men | Intensive lifestyle vs. metformin vs. placebo | Cumulative incidence T2DM: metformin, 58% lower (95% CI, 48%–66%); lifestyle, 31% lower (CI, 17%–43%) than placebo Cumulative incidence of CVD and CVD event rate: NSD among groups, but underpowered for this outcome
DREAM Trial DREAM Trial Investigators 2006^82,^ ^148^ 2004^147^ Good | International multi-center | 5,269 | Median, 3.0 y | Age, 5.7 y (10.9); 40.8% men; BMI, 30.9 kg/m^2^ (5.6) | Rosiglitazone vs. placebo; ramipril vs. placebo | Rosiglitazone: Death: HR, 0.91 (CI, 0.55–1.49); P = 0.7 T2DM incidence: HR, 0.38 (CI, 0.33– 0.44); P < 0.001 Composite CVD outcome: HR, 0.40 (CI, 0.35–0.46); P = 0.08 Ramipril: Death: HR, 0.98 (CI, 0.60–1.60) T2DM incidence: HR, 0.91 (CI, 0.80– 1.03) Composite CVD outcome: HR, 0.91 (CI, 0.81–1.03); P = 0.68
Finnish Diabetes Prevention Study Tuomilehto et al, 2001^138^ Lindstrom et al, 2003^149,^ ^150^ Lindstrom et al, 2006^153^ Laaksonen et al, 2005^152^ Eriksson et al, 1999^151^ Fair | Finland | 522 | 3.2 y for post-intervention outcomes; median total follow-up, 7 y | Age, 55 y (7); 32.9% men | Lifestyle vs. usual care | Cumulative incidence of T2DM: At 3.2 y: HR, 0.4 (CI, 0.3–0.7); P < 0.001 At 7 y: HR, 0.57 (CI, 0.43–0.76); P < 0.001
Heymsfield et al, 2000^80^ Fair-poor | International multi-center | 675 | 2.0 y | Age, 43.9 y; 17.5% men | Orlistat vs. placebo; both received lifestyle intervention | IGT at baseline, and at follow-up: Normoglycemia: orlistat, 71.6%; placebo, 49.1% IGT: orlistat, 25.4%; placebo, 43.4% T2DM: orlistat, 3.0%; placebo, 7.6% P = 0.04 between groups
Indian Diabetes Prevention Programme Ramachandran et al, 2006^154^ Fair | India | 531 | Median, 2.5 y | Age, 54.9 y (5.7); 79.0% men | Lifestyle and metformin vs. lifestyle vs. metformin vs. placebo | Relative risk reduction in incidence of T2DM at year 3: Lifestyle: 28.5% (CI, 20.5%–37.3%) Metformin: 26.4% (CI, 19.1%–35.1%) Lifestyle and metformin: 28.2% (CI, 20.3%–37.0%)
Kosaka et al, 2005^81^ Fair | Japan | 458 | 4.0 y | Age, NR; 100% men | Lifestyle vs. usual care | Cumulative incidence T2DM over 4 y: lifestyle, 3%; control, 9.3%; P = 0.043 between groups
Pan et al, 2003^156^ Fair | China | 261 | 16 wk | Age, 54.5 y (8.5); 40.0% men | Acarbose vs. placebo | T2DM incidence: acarbose, 5.6%; placebo, 9.5%; P = 0.245
STOP-NIDDM (Study to Prevent Noninsulin-dependent Diabetes Mellitus Trial) Chiasson et al, 2002^136^ Chiasson et al, 2003^159^ Chiasson et al, 1998^158^ Fair | International multi-center | 1,429 | 3.3 y | Age, 54.5 y (7.9); 49% men | Acarbose vs. placebo; both received lifestyle intervention | Cumulative incidence of: T2DM: HR, 0.75 (CI, 0.63–0.90); P = 0.0015 Any CVD event: HR, 0.51 (CI, 0.28–0.95); P = 0.02 MI: HR, 0.09 (CI, 0.01–0.72); P = 0.02
Swinburn et al, 2001^157^ Fair-poor | New Zealand | 136 | 5.0 y | Age, 52.2 y (6.5); 50.7% men | Reduced-fat diet vs. usual diet | Intervention was associated with a lower proportion of subjects with T2DM or IGT at 1 y (P< 0.05); NSD at 2, 3, or 5 y Included population all had IGT at recruitment, but only 31% had prediabetes with repeated testing at randomization; results are for all included patients
Watanabe et al, 2003^155^ Fair | Japan | 173 | 1.0 y | Age, 55.1 y (7.1); 100% men | Dietary counseling vs. usual care | T2DM incidence: NSD between groups (data not provided)
XENDOS (XENical in the Prevention of Diabetes in Obese Subjects Study) Torgerson et al, 2004^161^ Torgerson et al, 2001^160^ Fair-poor | Sweden | 3,305 total (694 with IGT) | 4.0 y | Age, 43.8 y (8.0); 44.8% men; BMI, 37.3 kg/m^2^ (4.3) | Orlistat vs. placebo; both received lifestyle intervention | Cumulative incidence of T2DM in IGT subgroup after 4 y: HR, 0.551; P = 0.0024

* Data are means (SDs), unless otherwise noted

Abbreviations: BMI, body mass index; CI, confidence interval; CVD, cardiovascular disease; DPP, Diabetes Prevention Program; DREAM, Diabetes Reduction Assessment with Ramipril and Rosiglitazone Medication; HR, hazard ratio; IGT, impaired glucose tolerance; MI, myocardial infarction; NR, not reported; NSD, no significant difference.

Table 7 Studies Modeling Treatment of Prediabetes (KQ3)

Model Author, year (in date order) | Perspective | Type of model Time horizon | Population Country | Included costs Discount rate | Data sources | Intervention | Outcomes | Conclusions
Segal et al, 1998^173^ | Health care system | Markov 25y | Based on Australian cohort; IGT, normoglycemia and DM2 | Program costs and direct medical costs 5%/y for benefits and costs | Various trial and observational data with follow-up >5y | 1 Intensive weight loss and fitness program for obese; 2 Standard care | Net cost per life-year saved for persons with IGT (US$): Behavioral program for seriously obese: net saving Surgery for BMI >40: $3300 | Primary prevention of DM2 for persons with IGT is relatively cost-effective
Caro et al, 2004^174^ | Health care system | Markov 10y or death | Representative cohort of 1000 Canadians with IGT | Direct medical costs 5%/y cost and health outcomes | Various epidemiological data sources; STOP-NIDDM; DPP; Ontario cost data | 1 Acarbose; 2 Metformin; 3 Intensive lifestyle; 4 No treatment | Incremental cost per life-year gained: relative to no treatment: Metformin: Cost savings Acarbose: Cost savings Lifestyle: $749 | Treatment of IGT to prevent DM2 is cost-effective: lifestyle interventions lead to greatest healthy benefits at reasonable cost
Palmer et al, 2004^176^ | Health care system | Markov Lifetime | Resembled the DPP population (IGT 5.3 –7.0 mml/l): mean age 50.6y, BMI 34.0 32% from minority population | Direct medical costs 5%/y for costs and outcomes | DPP, UKPDS | 1 Intensive lifestyle (DPP intervention); 2 Metformin; 3 Control | Mean number of years free from diabetes: Lifestyle: 10.0 Metformin: 9.0 Control: 8.1 Incremental increase in LE if treatment effect lasted a lifetime in years, vs control: Lifestyle: 0.90 Metformin: 0.35 Lifestyle and metformin cost savings in most countries Metformin had more impact on decreasing costs in increasing LE in younger and more obese patients | DPP produces clinically important improvements in LE, with either overall cost savings or minor increases in total costs per patient.
Archimedes Eddy et al, 2005^169^ 2003^170,^ ^171^ | Patient, health plan, societal | Archimedes model built from underlying anatomy, biological variables, and pathways 5 to 30y (for societal) | Adults at high risk for DM2 (BMI >24 kg/m2, FPG 95–125 mg/dl, or 2-h OGTT 140–199 mg/dl); 100,000 simulated persons for health plan US | Direct and indirect (for societal perspective) 3%/y | Data derived from variety of empirical sources; no data are assumed; costs from DPP study, Kaiser Permanente, and others | 1 DPP lifestyle program; 2 Baseline: no lifestyle or other intervention; 3 Lifestyle when FPG>125 mg/dl; 4 Metformin as in DPP study | Individual at high-risk for DM2, 30y probability of developing DM2: baseline risk 72%; lifestyle: 61%, NNT for benefit: 9; metformin 68% Societal perspective: Incremental 30y cost/QALY: DPP lifestyle for all compared to lifestyle when FPG >125mg/dl: $201,818; Lifestyle when FPG>125 mg/dl compared to no intervention: $24,523; lifestyle intervention for all high-risk compared to no intervention: $62,600/QALY Health plan perspective: 30y cost/QALY of DPP lifestyle program compared to no intervention $143,000; increases with decreased time horizon and smaller plans; over 5y: $2.7 million | The DPP program reduces the risk of developing diabetes over a lifetime but is not particularly cost-effective compared to other health interventions
CDC/RTI (Centers for Disease Control and Prevention / Research Triangle Institute) Herman et al, 2005^172^ | Health care system and societal | Markov; modified CDC/RTI model Lifetime | DPP population: 3234 nondiabetic persons ≥ 25y with IGT and FPG 95–125 mg/dl; mean age 51y, 68% female; 45% members of racial/ethnic minority groups US | Health care system perspective: direct medical costs; societal perspective: also included direct nonmedial costs 3%/y for costs and QALYs | DPP, UKPDS | DPP lifestyle intervention: 7% or more weight loss and 150 minutes/week of activity; or metformin 850mg bid; or placebo | Delay in onset DM2: compared to placebo: lifestyle delays onset by 11y, metformin by 3y Lifetime development of DM2: 83% in placebo, 63% with lifestyle, 75% with metformin Increase in LE compared to placebo: lifestyle 0.5y, metformin 0.2y Reduction in cumulative incidence complications: Lifestyle vs placebo: blindness 39%, ESRD 38%, amputation 35%, stroke 9%, CHD 8% Metformin vs placebo: blindness 16%, ESRD 17%, amputation 16%, stroke 3%, CHD 2% Incremental cost/QALY compared to placebo: Lifestyle: $1,124; metformin: $31,286 | Lifestyle interventions are relatively cost-effective compared to placebo, producing gains in survival and a decrease in microvascular and cardiovascular complications
Lindgren et al, 2007^177^ | Health care system | Markov 6y | Population-based screening in Stockholm; 60y old men and women | Direct and indirect medical costs 3%/y for costs and benefits | Finnish Diabetes Study, UKPDS, Swedish cost data | Finnish lifestyle intervention | Intervention is associated with an increase in survival of 0.18y; mean QALYs gained: 0.20y; the cost-effectiveness ratio is Euros 2,363/QALY | This model predicts that the Finnish Diabetes Study lifestyle intervention targeted at persons with high risk would be cost-savings for the health case plan and cost-effective for society

Abbreviations: BID, twice daily; BMI, body mass index; CDC, Centers for Disease Control; CHD, cardiovascular heart disease; DM2, type 2 diabetes; DPP, Diabetes Prevention Program; DPS, Finnish Diabetes Prevention Study; ESRD, end-stage renal disease; FPG, fasting plasma glucose; IGT, impaired glucose tolerance; LE, life expectancy; NNT, number needed to treat; OGTT, oral glucose tolerance test; QALY, quality-adjusted life year; RTI, Research Triangle International; STOP-NIDDM, Stop Non-Insulin-Dependent Diabetes Mellitus study; UKPDS, United Kingdom Prospective Diabetes Study; y, year.

Table 8 Studies Examing the Adverse Effects of Screening (KQ4)

Study Author, year Quality rating | Study design; N | Study population; Participant selection method | Follow-up | Measures used (operationalized outcomes) | Main results | Conclusions
ADDITION Study Thoolen et al, 2006^188^ Not rated | 2X2 factorial cross-sectional 196 | Newly diagnosed DM2 Population-based screening in Netherlands Comparison groups = DM2 diagnosis <1y vs 2–3y | 0 | HADS (anxiety and depression) PAID (diabetes distress) Diabetes Illness Representations questionnaire - revised for study (perceived seriousness Diabetes self-care activities measure - revised for study (self care) Independent measures created for study (self-efficacy; perceived vulnerability) | Time effects found for perceived vulnerability (increases significantly with time since diagnosis) (F=14.3, p<0.001) No time effects found for anxiety (F=0.3, ns) nor depression (F=1.2, ns) No time effects found for DM-distress (F=3.0, ns), perceived seriousness (F=1.8, ns), self efficacy (F=0.2, ns), nor self management (F=0.0, ns) Some reported clinically relevant anxiety (HADS score ≥8; clinically definite scores ≥11) in group diagnosed < 1 y, but it seems to be effect of intensive treatment × time, because the intensive treatment group is significantly higher (mean scores, 6.8 vs 4.5, F=5.8, p<0.001). 2–3 y group mean scores = 5.0 vs 5.5, ns | Screen-detected persons generally do not experience difficulty with DM2 in the first 2–3y Early and intensive treatment can lead to relatively more anxiety and less self-efficacy in the first y after diagnosis, compared to less intensive treatment
ADDITION Study Eborall et al, 2007^190^ Fair | Controlled clinical trial (embedded in the ADDITION RCT) 5,334 | Population-based screening in the United Kingdom | 15m | SSAI (anxiety) HADS (anxiety and depression) Lerman Cancer Worry Scale, adapted (DM-specific worry) Single item on general health | Comparison of screening attendees and control at the time of random BG (initial screen): NSD between groups in any outcome Comparison of patients invited for screening (attendees and non-attendees) and control: at 3–6m and 12–15m: NSD between groups in any outcome Immediate impact of initial positive screening test compared to negative screening test: poorer health; higher anxiety, depression, DM-specific worry (p all ≤ 0.05) | Screening has limited psychological impact on patients Being required to return for further tests after an initial positive random BG has small negative psychological impact of doubtful clinical significance
ADDITION Study Eborall et al, 2007^189^ Not rated | Cross-sectional, qualitative interviews 23 | Sample of subjects scheduled for OGTT in the United Kingdom Unclear how sampled | 0 | Open-ended questions | Initial stages of screening processes: Most participants not very worried who tested positive on the first tests Prediagnostic test expectations: many accepted possibility of positive diagnosis Reactions after new diagnosis of DM2: tendency to downplay importance; all had plans to control the disease; most were grateful for screening program Diagnosed with IFG or IGT: many were confused by this diagnosis; most were unconcerned and unaware of this diagnosis as a risk factor for DM2 or CVD | Patients' perceptions changed at different stages of a stepwise screening program; patients adjust There is a tendency to downplay individual risk By the time of a positive diagnosis, most patients accepted the diagnosis and had plans to control their disease Persons with IGT/IFG were confused by this diagnosis and did not plan to change their lifestyle
Edelman et al, 2002^182^ Good | Longitudinal cohort 1,253 | All undiagnosed DM2 at baseline Population-based screening in the United States At screening, 56 DM2+ and 1177 nonDM2 | 1y | SF-36 MCS (health-related quality of life, mental component) SF-36 PCS (health-related quality of life, physical component) | NSD between DM and nonDM groups, nor between baseline and 1 y follow-up Baseline PCS: NonDM vs with newly-diagnosed DM (36.3 vs 35.6, p=0.67), ns Baseline MCS: NonDM vs with newly-diagnosed DM (49.6 vs 48.8, p=0.70), ns 1y follow-up PCS: NonDM vs with newly-diagnosed DM (35.2 vs 34.6, p=0.68), ns 1y follow-up MCS: NonDM vs with newly-diagnosed DM (48.2 vs 48.0, p=0.94), ns | HRQoL in persons with newly-diagnosed, screen-detected DM2 is similar to those who screen negative 1y after screening
Farmer et al, 2003^183^ Good/fair | Cohort 431 | High risk of developing DM2 GP-identified siblings of DM2 family members in the United Kingdom | 1y | SSAI-SF (anxiety) WBQ-12 (well-being) HAI (health anxiety) | Within group effect of time: Anxiety fell from 34.5 (95% CI 33.4–35.6) to 32.3 (31.2–33.4) at 1 y (p<0.0001) Well-being scores rose (improved) from 26.8 (26.0–27.4) to 27.4 (26.7–28.1, p=0.008) Anxiety (p=0.56) and well-being (p=0.79) over 1y did not differ between participants receiving a normal or an at-risk test result | Siblings of persons with DM2 have slightly elevated anxiety levels at the time of screening, but these levels decrease over 1y follow-up There were no differences in anxiety or well-being between subjects with a normal FPG and those with elevated glucose levels at 1y
Hoorn Study Adriaanse et al, 2004^178^ Fair | Cohort 165 | Newly diagnosed DM2 Screen-detected and GP-identified in Hoorn region of the Netherlands | 2w 6m 1y | DSC-type 2 (perceived burden of DM) WBQ-12 (well-being) SF-36 (perceived health status) | DSC-type 2 scores (higher scores indicate more symptom distress): GPDM: 2w: 0.56; 6 m: 0.21; 1y: 0.26, p<0.001 SDM: 2w: 0.24; 6 m: 0.24; 1y: 0.29, p=0.093 SF-36 scores: Differences were statistically significant (worse) for GPDM group on SF-36 for Role Emotional (F=5.2, p=0.024), Mental Health (F=5.0, p=0.027), Vitality (F=3.9,p=0.049), compared with SDM GPDM General Health (F=3.7, p=0.028) and Vitality (F=4.5, p=0.012) scores improved significantly over time, compared with SDM Differences were statistically significant (worse) for GPDM group on WBQ-12 for General well-being, p=0.048, compared with SDM | The psychological impact of screening positive for DM2 is minimal and screening is generally not perceived as burdensome in this exploratory study
Hoorn Study Adriaanse et al, 2004^180^ Fair | Cohort 259 | Newly diagnosed DM2 vs high risk nonDM2 Population-based, targeted screening in Hoorn region of the Netherlands | 2w 6m 1y | WBQ-12 (well-being) SF-36 (perceived health status) | 2w after diagnosis: no significant mean differences between DM and nonDM on WBQ-12 nor SF-36 6m after diagnosis: statistically significant (worse) for DM for Role Physical (mean diff -8.2 [95% CI -16.2; -0.1], p=0.046) and Role Emotional (mean difference -7.9 [95% CI -15.3; -0.5], p=0.038), compared with nonDM 1y after diagnosis: no significant mean differences between DM and nonDM on WBQ-12 nor SF-36 | Screening positive for DM2 does not have a substantial adverse psychological effect compared to nonDM subjects at up to 1y of follow-up
Hoorn Study Adriaanse et al, 2005^179^ Fair | Cohort 246 | Newly-diagnosed DM2 vs high risk nonDM2 Population-based, targeted screening in Hoorn region of the Netherlands | 2w 6m 1y | DSC-type 2 (DM related symptom distress) NWB Subscale of WBQ-12 (negative mood) | Total symptom distress (range 0–4) differences ns: DM (median scores at 2w, 6m, and 1y: 0.24, 0.24, 0.29) nonDM (0.15, 0.15, 0.18) No average difference nor change over time in negative well-being was found between DM and nonDM Negative well-being was significantly positively related with the total symptom distress score (regression coefficient beta = 2.86, 95% CI 2.15–3.58) | Persons with screen-detected, newly diagnosed DM2 have more hypoglycemic and fatigue symptoms than nonDM subjects at up to 1y follow-up
Nichols et al, 2004^185^ Poor (44% response rate) | Cohort 273 | Newly diagnosed DM2 vs undiagnosed DM2 Registry in the United States | 1y | SF-12 MCS (health-related quality of life, mental component) SF-12 PCS (health-related quality of life, physical component) | Between groups at baseline: Mental health: 51.4 vs 51.9, p=0.406, ns 1y follow-up: No difference in change in health status (mental or physical health) in those who reported receiving a diagnosis (n=105) compared with those who did not (n=168). Adjusted for age difference between those receiving diagnosis (younger) and those not (67.0 vs 69.6, p=0.031). After adjustment, diagnosis was not associated with any difference in functional status, or with a change in physical (1.55 vs 0.05, p=0.233) or mental (-0.63 vs 0.01, p=0.598) health status | Receiving a diagnosis of DM2 after a change in diagnostic criteria does not adversely affect either mental or physical health status
Skinner et al, 2005^187^ Not rated | Cross-sectional 1,339 | High risk of developing DM2 GP, hospital, registry, and media identified in the United Kingdom | 0 | SSAI-SF (anxiety) Emotional Stability Scale of Big Five Inventory 44 (emotional stability) 3 scales from Diabetes Illness Representations Questionnaire - revised for study (DM related illness beliefs) | No effect of family history of DM, ethnic group, or recruitment methods on anxiety 45% of all participants reported “little to moderate” amounts of anxiety (mean 35.5, SD 11.6) Emotional stability was significantly (negatively) associated with anxiety, r=-0.45; n=930; p<0.001. | Screening for DM2 does not induce significant anxiety

Abbreviations: ADDITION Study, Anglo-Danish-Dutch Study of Intensive Treatment and Complication Prevention in Type 2 Diabetic Patients Identified by Screening in Primary Care; BG, blood glucose; CVD, cardiovascular disease; DM, diabetes; DM2, Type 2 diabetes; DSC-Type 2, Diabetes Symptom Checklist - Type 2 diabetes; FPG, fasting plasma glucose; GP, general practitioner; GPDM, General practitioner group with diabetes; HADS, Hospital Anxiety and Depression Scale; HAI, Health Anxiety Inventory; HRQoL, health-related quality of life; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; m, month; MCS, Mental Component Score; N, number of participants in study; nonDM, without diabetes; ns, not significant; NSD, no significant difference; NWB, Negative Well-Being subscale; OGTT, oral glucose tolerance test; PAID, Problem Areas in Diabetes scale; PCS, Physical Component Score; RCT, randomized controlled trial; SDM, Screened group with diabetes; SF-12, Medical Outcomes Study Short Form 12; SF-36, Medical Outcomes Study Short Form 36; SSAI-SF, Spielburger State-Trait Anxiety Inventory-Short Form; w, week; WBQ-12, Well-being Questionnaire-12; y, year.

Note: Selected studies omitted from this Summary Table; see Appendix Evidence Table B11 for full abstraction of all studies

Table 9 Systematic Reviews Examining the Adverse Effects of Treatment (KQ5)

Drugs Study, Year, Quality | Intervention; Population | Total withdrawals; Withdrawals due to adverse events | Adverse events: Intervention group | Conclusions
α-glucosidase inhibitors
Van de Laar et al, 2005^194^ Fair | α-glucosidase inhibitors: acarbose (30 studies); miglitol (7 studies); voglibose (1 study) + 3 studies combined various DM2 | NR | Acarbose: Any diabetes-related endpoint: RR 1.00 (0.81–1.23) vs placebo Microvascular disease: RR 0.91 (0.61–1.35) vs placebo Number of patients with side effects, odds ratio treated vs placebo; 3.37 (95% CI, 2.60 – 4.36) | NSD between acarbose and placebo with respect to morbidity and mortality
Van de Laar et al, 2007^193^ Good | α-glucosidase inhibitors: acarbose (5 studies) IGT and IFG | NR | Gastrointestinal (flatulence, diarrhea): OR 3.5 (2.7–4.4) vs placebo | Acarbose causes significant gastrointestinal side effects compared to placebo
ACE inhibitors and ARBs
McDonald et al, 2005^197^ Good | ARBs At risk for CV events | NR | MI pooled effect: OR=0.94 (0.75 – 1.16) | ARBs are not associated with an increased risk of MI when compared with placebo.
Strippoli et al, 2006,^195^ 2004^196^ Fair | ACE inhibitor ARBs placebo DM1: 20 studies DM2: 23 studies Mixed DM population: 6 studies | Total withdrawals: 0.2 to 1.0% Withdrawal due to AEs: NR | ACE inhibitors, I vs C: All-cause mortality (any dose) 12.3%; 12.7% (p>0.05) CV mortality 5.8%; 5.9%(p=0.6) Doubling of serum creatinine 3.0%; 4.3% (p=0.05) End-stage kidney disease 0.85%; 1.5% (p=0.02) Cough (vs placebo): 3.17 (2.29, 4.38) Hyperkalemia: NSD vs placebo ARBs: All-cause mortality 13.7%; 15.6% (p=0.9) Doubling of serum creatinine 15.1%; 21.5% (p=0.004) End stage kidney disease 13.3%; 19.3% (p=0.001) Cough (vs placebo): 4.93 (1.00, 24.35) | ACE inhibitors vs ARBs: Based on indirect analysis no significant differences for any outcome, including: all-cause mortality, end-stage renal disease, doubling of serum creatinine concentration, progression from microalbuminuria to macroalbuminuria or regression from microalbuminuria to normoalbuminuria. ACE inhibitors or ARBs vs placebo: All-cause mortality: ACE inhibitors, but not ARBs, were associated with a significant reduction in all-cause mortality; end-stage renal disease and doubling of serum creatinine concentration: weak evidence of reduced risk with ACE inhibitor use with no significant difference in risk for ARBs; both ACE inhibitors and ARBs associated with significantly reduced risk of progression from microalbuminuria to macroalbuminuria and increased rate of regression from microalbumunuria to normoalbuminuria.
Velazquez-Armenta et al, 2007^198^ Fair | ARBs Pregnancy | NR (case series) | Favorable pregnancy outcomes: 57.8% (37 cases) Unfavorable pregnancy outcomes (eg: abnormalities including limb and face deformations, enlarged kidneys, anuria, severe hypotension, etc): 42.2% (27 cases) ARBs in this group included valsartan, losartan, candesartan, and irbesartan Duration of treatment during pregnancy among women who had adverse fetal outcomes was 26.3±10.5 weeks vs 17.3±11.6 weeks for those who had favorable outcomes (p=0.04) | Exposure to ARBs for a period longer than the first trimester of pregnancy appears to be associated with an increased risk of adverse fetal outcomes (p=0.04)
Verdecchia et al, 2005^199^ Fair | ARBs At risk for CV events | NR | MI: OR 0.96 (95% CI, 0.84 – 1.10), p=0.57 CVD mortality: OR 0.91 (95% CI, 0.83 – 0.99), p=0.042 | ARBs are not associated with an increased risk of MI when compared with placebo.
Aspirin
Berger et al, 2006^201^ Good | Aspirin Primary prevention of cardiovascular events | NR | Bleeding in men: OR 1.72 (1.35 – 2.20; p<0.001) Bleeding in women: OR 1.68 (1.13 – 2.52; p=0.01) Stroke in men: OR 1.13 (0.96 – 1.33) Stroke in women: OR 0.83 (0.70 – 0.97) Ischemic stroke in men: OR 1.00 (0.72 – 1.41) Ischemic stroke in women: OR 0.76 (0.63 – 0.93) Hemorrhagic stroke in men: OR 1.69 (1.04 – 2.73) Hemorrhagic stroke in women: OR 1.07 (0.42 – 2.69) | Reduced risk of CV events for men and women with aspirin use; significant increase in bleeding risk for both groups; NSD in CV or all-cause mortality
McQuaid et al, 2006^200^ Good | Aspirin or Clopidogrel For cardiovascular prophylaxis | Aspirin: All events: RR=1.16 (05% CI, 0.94 – 1.44) GI events: RR=1.26 (0.94 – 1.70) non-GI events: RR=0.84 (0.55 – 1.28) | Aspirin : Major bleeding: RR=1.71 (95% CI, 1.41 – 2.08) Major GI bleeding: RR=2.07 (1.61 – 2.66) Intracranial bleeding: RR=1.65 (1.06 – 5.99) Dyspepsia: RR=1.09 (0.97 – 1.22) Diarrhea: RR=3.30 (1.42 – 7.66) Constipation: RR=1.98 (1.14 – 3.44) Rash: RR=0.77 (0.38 – 1.58) 769 patients need to be treated with aspirin to cause 1 additional major bleeding episode annually No study compared clopidogrel with placebo | Low-dose aspirin associated with an increase in risk of major bleeding (~70%; NNT: 796) relative to placebo/no use Compared to clopidogrel, aspirin associated with higher risk of GI bleeding (NNT 883 to prevent one major GI bleeding episode)
Beta-blockers
Wiysonge et al, 2007^202^ Good | Beta-blocker (not stratified; including atenolol, propranolol, oxeprenolol, metoprolol) Placebo Hypertension, >18 years | Total withdrawals NR Withdrawals due to AEs I vs C 18.2% vs 8.6%; p=0.1 RR 2.34 (0.84–6.62) | I vs C: Total mortality 5.0%; 5.2% (p=0.8) CHD 3.5%; 3.7% (p=0.3) Stroke 1.8%; 2.3% (p=0.02) CV mortality 2.6%; 2.9% (p=0.4) CV disease 5.7%; 6.4% (p=0.01) | No significant difference between beta-blockers and placebo in total mortality or CHD. Use of beta-blockers was associated with a significantly lower risk of stroke and CV events, relative to placebo.
Hypoglycemic agents
Bolen et al 2007^203^ Good | Various oral hypoglycemic agents: pioglitazone rosiglitazone metformin sulfonylureas repaglinide nateglinide acarbose placebo DM2 | Total withdrawals: I vs C Pioglitazone: NR Rosiglitazone 3.8–6.3% vs 2.7–12.0% Metformin NR Sulfonylurea 2.4% vs 7.9% (1 study) Meglitinide (repaglinide or nateglinide) NR Acarbose NR Withdrawals due to AEs: I vs C Pioglitazone 1.1–3.0% vs 2.4–4.8% Rosiglitazone 0.9%–7.4% vs 1.2–10.3% Metformin 3.0–15.4% vs 0–17.2% Sulfonylurea 0–14.3% vs 1.9–30.4% Meglitinide (repaglinide or nateglinide) 1.5–7.6% vs 3.0–4.3% Acarbose 2.5% vs 5.3% and 58.1% vs 44.8% (2 studies; rate varied widely) | I; C Pioglitazone: Hypoglycemia 0.6–11.0%; 0–11% Edema 3.0–13.6%; 0–7.5% CHF 3.6–14.0%; 0.6–16.0% ALT elevations 0–6%; 0–6.0% AST elevations 0–1%; 1% Rosiglitazone: Hypoglycemia 3.4–12%; 2.0–6.0% Edema 6.0–18.0%; 3% CHF 4.1–13.6%; 0–2.5% ALT elevations 0–1.2%; 0–1.1% Metformin: Mortality (1 study) 0.3%; 0% Hypoglycemia 1.3–13.4%; 0–10.3% Sulfonylurea: Hypoglycemia 0–17.7%; 0–1.2% CHF 4.2%; 3.5% (1 study each) Meglitinide (repaglinide or nateglinide): Hypoglycemia 0–12.8%; 0–11.0% Acarbose: Hypoglycemia 9.7%; 10.3% (1 study each) | No clear conclusions regarding all-cause mortality associated with metformin + second generation sulfonylurea vs metformin and/or a second generation sulfonylurea could be drawn due to conflicting results and/or lack of evidence. The effect of metformin + second generation sulfonylurea vs metformin or a second generation sulfonylurea on CV mortality was unclear; other oral diabetes medications lack adequate evidence to draw conclusions No conclusions can be made regarding CV morbidity due to limited number of studies; pioglitazone+metformin associated with improved CV morbidity relative to placebo/diet
Gangji et al, 2007^204^ Good | Glyburide, other secretagogues, insulin DM2 | NR; loss to follow-up ranged from 0 to 37% | Glyburide compared to other secretagogues Hypoglycemia: RR 1.52 (1.21–1.92); compared to other sulfonylureas, RR 1.83 (1.35–2.49)) Cardiovascular risk: RR 0.84 (0.56–1.26) Death: RR 0.87 (0.70–1.07) | Glyburide caused more hypoglycemia than other secretagogues and other sulfonylureas, but was not associated with increased risk of cardiovascular events or death.
Saenz et al, 2005^205^ Good | Metformin DM2 | NR | Metformin; comparator All-cause mortality: 0.51%; 0.0% (p=0.3) Hypoglycemia: 2.7%; 0.5% (p=0.2) No cases of lactic acidosis | Pooled data from trials of various active interventions, placebo and/or diet changes found no difference in rates of all-cause mortality or ischemic heart disease.
Salpeter et al 2003^207^, 2006^206^ Good | Metformin DM2 | NR | Fatal or non-fatal lactic acidosis: 0% Estimated upper limit 95% confidence interval for incidence of lactic acidosis metformin vs non-metformin (cases/100,000 patient-years): 6.3 vs 7.8 No other AEs reported Control group: 0% with various hypoglycemic agents as comparators | No evidence of an association between metformin use and lactic acidosis relative to other anti-hyperglycemic agents
Setter et al, 2003^208^ Poor | Metformin DM2 | Unable to tolerate as a result of prolonged adverse effects: <5% | Episodes of severe hypoglycemia: ‘negligible’ (no other data) Lactic acidosis: rate 8 cases/100,000 person-years (1 study) | Very limited data found that potentially fatal lactic acidosis can be associated with metformin use, although absolute risk is low.
Statins
Bonovas et al, 2007^209^ Fair | Pravastatin Cardiovascular therapy for different ages | NR | Cancer risk: random-effects model (RR 1.06 (95% CI, 0.97 – 1.14)) Cancer risk as age increases: meta-regression, p=0.006 | Possible association between pravastatin use and increased cancer risk in the elderly. Findings need to be replicated.
Law et al, 2006^211^ Fair-Poor | Various statins Those prescribed statin treatment (details NR) | NR | Peripheral neuropathy (OR from 4 cohort studies): 1.8 (1.1 – 3.4) Rhabdomyolysis: Incidence per 100,000 person years Cohort studies: Cervistatin: 46 (13 – 120) Statins (without cervistatin): 1.6 and 6.5 (2 studies) Gemfibrozil: 28 (6–81) FDA Reporting System: Cervistatin: 21 (19 – 25) Statins (without cervistatin): 0.70 (0.62 – 0.79) Mortality estimated at 10% of incidence Treated minus placebo, Per 100,000 person years Rhabdomyolysis: 1.6 (-2.4 – 5.5) Myopathy: 5 (-17 – 27) Minor muscle pain: 190 (-38 – 410) Elevated Creatine kinase: 23 (-4 – 50) Elevated ALT (single measure): 100 (64 – 140) Elevated ALT (2 consecutive measures): 70 (50 – 90) | Despite high risk with cervistatin, incidence of rhabdomyolysis is low in patients taking simvastatin, lovastatin, atorvastatin, provastatin, or fluvastatin - estimated as 3 per 100,000 person-years. Myopathy attributable to these statins is also rare (11 per 100,000 person years). Most muscle symptoms in patients taking statins are not attributable to the statins.
McClure et al, 2007^210^ Good | Statins Those prescribed statin treatment (details NR) | Discontinuation due to AEs: OR (95% CI) Overall (w/o cervastatin) : OR 0.88 (0.84 – 0.93) Lovastatin: 1.10 (0.98 – 1.24) Pravastatin: 0.79 (0.74 – 0.84) Simvastatin: 1.00 (0.89 – 1.11) Fluvastatin: 0.93 (0.75 – 1.16) Atorvastatin: 0.93 (0.75 – 1.14) Rosuvastatin: 0.68 (0.26 – 1.77) Cervastatin: 1.45 (0.98 – 2.16) | OR (95% CI) Rhabdomyolysis (w/o cervistatin): 1.59 (0.54 – 4.70) Myositis (w/o cervistatin): 2.56 (1.12 – 5.85) Myositis (cervistatin): 3.36 (0.59 – 19.3) Creatine kinase (w/o cervistatin): 1.11 (0.78 – 1.59) Creatine kinase (cervistatin): 2.93 (1.08 – 7.92) Myalgia (w/o cervistatin): 1.09 (0.97 – 1.23) Myalgia (cervistatin): 1.74 (0.51 – 5.91) | Overall, discontinuation of statin therapy was no worse than placebo. Risks of muscle related AEs in agreement with known risks of statins; rates are much higher with ceruvistatin than other statins.
Silva et al, 2006^212^ Fair | Statins Those prescribed statin treatment or placebo | NR | Risk of any AE: OR 1.4 (1.09 – 1.80), p=0.008 vs placebo, NNH 197 Risk of clinical CV event: OR 0.74 (0.69 – 0.80), p<0.001, NNT = 27 Treating 1000 pts with statin would prevent 37 CV events, and 5 AEs would be observed. Serious events (creatine kinase > 10× upper limit of rhabdomyolysis) are infrequent, NNH = 7428 Nonurgent AEs (myalgia and liver function tests) responsible for 2/3 of AEs reported in trials: 0.48 (0.25 – 0.7), NNH = 209 Rate of liver failure: 1 per 100,000 person years of statin use. Person years for any event/serious event: Placebo: 181/48 | Statin therapy in associated with greater odds of AEs compared with placebo, but with there is also substantial clinical benefit. Similar rates of serious AEs was observed between statins and placebo.
Thiazolidinediones
Norris et al, 2006^213^ Good | Pioglitazone (pio) 7.5–45 mg qd Rosiglitazone (rosi) 4–12 mg qd DM2, pre-DM, the metabolic syndrome | Total withdrawals, I v C (placebo): pio: 7.0–33.0% v 2.4–20.0%; pooled RD v placebo -1.0% (-3.0 – 1.0%) rosi: 0–27.0% v 0–38.4%; pooled RD v placebo -3.0% (-9.0 – 2.0%) Withdrawals due to AEs, I v C (placebo): pio: 4.8% v 4.5%; pooled RD 0% (-2.0 – 2.0%) rosi: 4.9% v 7.2%; pooled RD v placebo -2% (-4% – -1%) | Thiazolidinedione; placebo Pioglitazone: Cardiac-related events: 3.6%; 6.3% CHF: 11.0%; 8.0% (p<0.05) Peripheral edema: 0–22.0%; 0–16.0% Abnormal LFT: 0.77%–2.4%; 1.3% Hypoglycemia: 0–28.0%; 0–20.0% Rosiglitazone Peripheral edema: 4.1–6.6%; 1.6% (p<0.05 (4mg bid dose only, rosiglitazone rate 6.6%) Abnormal LFT: 0–0.6%; 0.0% | Total withdrawals and withdrawals due to AEs were similar in each of the rosi, pio, and placebo groups. The incidence of edema was significantly greater in both rosi and pio, than placebo. The risk difference for hypoglycemic events between placebo and each of rosi and pio was not significant. Weight gain was greater with both rosi and pio compared to placebo.
Richter et al, 2007^215^ Fair | Pioglitazone RCTs in adults with DM2 and trial duration ≥ 24w | Total withdrawals: NR% drop-outs due to AEs; similar between pio and comparators | Decrease in A1c: consistent in 6 studies which examined this outcome compared to : range 0.5 to 0.75 g/dl Body weight: increased in 15 studies compared to various comparators: up to 3.9 kg Hypoglycemic episodes (%): somewhat lower rates with pio than various active controls Edema: relative risk pio vs various other comparators: 2.86 (95% CI, 2.14 – 2.52) | Pioglitaone appears to decrease A1c, increase body weight, and increase edema compared to various other active therapies or placebo.
Richter et al, 2007^214^ Fair | Rosiglitazone RCTs in adults with DM2 and trial duration ≥ 24 weeks | Total withdrawals: NR Withdrawals due to AEs: I 2.7 to 11.6%, C: 2.0 to 14.9% (no pooled estimates available; no between-group-values available) | Edema: OR 2.27 (95% CI, 1.83 – 2.81) Fractures, CVD events, CHF, PVD, mortality: data reported from the ADOPT trial only Severe hypoglycemic episodes: I 0–5.4%, C 0–2.9%; no pooled data and no statistics | Rates of edema are increased with rosiglitazone compared with various other drugs or placebo. The ADOPT trial suggests that fractures rates in women may be increased.
Singh et al, 2007^216^ Fair | Rosiglitazone RCTs in DM2 or IGT and trial duration ≥ 12 months | NR | Relative risk 95% CI) rosiglitazone vs comparator: MI: 1.42 (1.06 – 1.91) Heart failure: 2.09 (1.52 – 2.88) CV mortality: 0.90 (0.63 – 1.26) | Rosiglitazone use for 12 or more months increases the risk of MI and heart failure, without significantly increasing the risk of CV mortality.
Weight loss drugs
Li et al, 2005^218^ Good | Sibutramine, phentermine, diethylpropion, orlistat, fluoxetine, bupropion, topiramate, sertraline, zonisamide Those prescribed obesity management treatment | NR | Pooled OR (95% CI): [underlined: Orlistat]: Diarrhea 54.85 (44.88 – 67.48) Flatulence 3.72 (3.16 – 4.39) Bloating, abdominal pain, dyspepsia 1.55 (1.18 – 2.06) Headache 1.18 (0.68 – 2.05) [underlined: Fluoxetine]: Nervousness, sweating tremors 7.85 (3.87 – 17.63) Nausea, vomiting 3.27 (1.94 – 5.67) Fatigue, asthenia, hypersomnia, somnolence 2.83 (1.82 – 4.45) Insomnia 2.19 (1.10 – 4.58) Diarrhea 1.86 (1.10 – 3.23) Urticaria, pruritus, rash 1.67 (0.53 – 5.65) Headache 1.35 (0.91 – 2.03) [underlined: Bupropion]: Dry mouth 3.26 (1.71 – 6.64) Diarrhea 1.37 (0.52 – 4.01) Constipation 1.31 (0.72 – 2.44) Upper respiratory problems 1.22 (0.88 – 1.69) [underlined: Topriamate]: Paresthesia 20.18 (13.99 – 29.67) Taste perversion 11.14 (2.80 – 23.57) Central nervous system effects 3.97 (2.90 – 5.49) Constipation 3.96 (1.77 – 9.77) Dry mouth 3.13 (1.59 – 6.55) Upper abdominal symptoms 1.76 (1.27 – 2.47) Fatigue 1.36 (1.03 – 1.80) Upper respiratory problems 1.32 (0.87 – 1.99) | Sibutramine: Effects on BP varied; A1c and fasting blood glucose decreased; heart rate was consistently elevated by 4 beats per minute. Orlistate was associated with diarrhea, abdominal pain, and dyspepsia; it was unclear if these improved over time. Fluoxitine: nervousness, sweating, tremors, nausea and vomiting, and insomnia increased significantly compared with placebo. There were few studies with long-term adverse effects data.
Norris et al, 2005^217^ Good | Fluoxetine, orlistat, sibutramine Placebo DM2 | Total withdrawals NR Withdrawals due to AEs fluoxetine v control: 1–9% v 0–2% orlistat v control: 0.3–22% v 0.5–28% sibutramine: 3–7% v 0%(1 study) | Data based on 1 study (no pooled data available) Orlistat; placebo Hypoglycemia: 7–17%; 3–10.0% GI events: 65–80%; 27–62% Fluoxitine; placebo Tremor: 5–15%; 0–3% Somnolence: 11–22%; 4–7% Sweating: 28%; 11% Sibutramine; placebo Palpitations 41%; 29% Dry mouth: 38%; 223% | Gastrointestinal adverse effects were common with orlistate; tremor, somnolence, and sweating with fluoxetine; and palpitations with sibutramine.

Abbreviations: ACE, Angiotensin-converting enzyme; ADOPT, A Diabetes Outcomes Progression Trial; AE, adverse event; ALT, Alanine aminotransferase; ARBs, Angiotensin II Receptor Blockers; AST, Aspartate aminotransferase; bid, twice daily; C, control group; CHD, coronary heart disease; CHF, congestive heart failure; CI, confidence interval; CV, cardiovascular; CVD, cardiovascular disease; DM, diabetes; DM1, type 1 diabetes; DM2, type 2 diabetes; FDA, Food and Drug Administration; GI, gastrointestional; I, intervention group; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; LFT, liver function tests; MI, myocardial infarction; NNH, number needed to harm; NNT, number needed to treat; NR, not reported; NSD, no significant difference; OR, odds ratio; pio, pioglitazone; PVD, peripheral vascular disease; qd, daily; RCT, randomized controlled trial; RD, risk difference; rosi, rosiglitazone; RR, relative risk; y, years.

Table 10 Outcomes Table

Number needed to screen for type 2 diabetes to prevent one adverse event
| | Tight glycemic control to prevent one case of blindness in one eye (screening 1000 people with given prevalence) | | | Tight blood pressure control to prevent one CVD event (screening 1000 hypertensive people with given prevalence)
Prevalence of undiagnosed disease (%) | Population | Increase in persons with tight glycemic control due to screening (%) | Cases of blindness averted* | NNS | Increase in persons with tight blood pressure control due to screening (%) | CVD events averted† | NNS
5.0 years of additional treatment
2.8 | Standardized prevalence in US‡ | 25 50 90 | 0.03 0.06 0.11 | 32,841 16,420 9,122 | 25 50 90 | 0.26 0.53 0.95 | 3,810 1,905 1,058
3.6 | Standardized prevalence, US non-Hispanic blacks‡ | 25 50 90 | 0.04 0.08 0.14 | 25,543 12,771 7,095 | 25 50 90 | 0.34 0.68 1.22 | 2,963 1,481 823
5.8 | Crude prevalence, US, ≥ 65y‡ | 25 50 90 | 0.06 0.13 0.23 | 15,854 7,927 4,404 | 25 50 90 | 0.54 1.09 1.96 | 1,839 920 511
6.0 | Prevalence estimated for prior review | 25 50 90 | 0.07 0.13 0.23 | 15,326 7,663 4,257 | 25 50 90 | 0.56 1.13 2.03 | 1,778 889 494
2.5 years of additional treatment
2.8 | Standardized prevalence in US‡ | 25 50 90 | 0.02 0.03 0.05 | 65,681 32,841 18,245 | 25 50 90 | 0.13 0.26 0.47 | 7,619 3,810 2,116
3.6 | Standardized prevalence, US non-Hispanic blacks‡ | 25 50 90 | 0.02 0.04 0.07 | 51,086 25,543 14,190 | 25 50 90 | 0.17 0.34 0.61 | 5,926 2,963 1,646
5.8 | Crude prevalence, US, ≥ 65 years‡ | 25 50 90 | 0.03 0.06 0.11 | 31,708 15,854 8,808 | 25 50 90 | 0.27 0.54 0.98 | 3,678 1,839 1,022
6.0 | Prevalence estimated for prior review | 25 50 90 | 0.03 0.07 0.12 | 30,651 15,326 8,514 | 25 50 90 | 0.28 0.56 1.01 | 3,556 1,778 988
Number needed to screen for prediabetes to prevent 1 case of diabetes after 3 years
Prevalence of IGT or IFG (%) | Population | Lifestyle intervention to prevent one case of diabetes (screening 1000 people with given prevalence)§ | | | Metformin to prevent one case of diabetes (screening 1000 people with given prevalence)‖
| | Increase in persons adhering to intervention (%) | Cases of diabetes delayed | NNS | Increase in persons adhering to intervention (%) | Cases of diabetes delayed | NNS
15.0 | IGT only, total US population¶ | 25 50 90 | 2.39 4.79 8.61 | 418 209 116 | 25 50 90 | 1.28 2.56 4.60 | 782 391 217
26.0 | IFG only, total US population‡ | 25 50 90 | 4.15 8.29 14.93 | 241 121 67 | 25 50 90 | 2.22 4.43 7.98 | 451 226 125
40.0 | Estimate IFG and/or IGT# | 25 50 90 | 6.38 12.76 22.97 | 157 78 44 | 25 50 90 | 3.41 6.82 12.28 | 293 147 81

* Relative risk reduction 0.29 over 5 years, based on incidence of retinal photocoagulation in one eye, from United Kingdom Prospective Diabetes Study; rate of blindness in no-treatment group 1.5% over five years^223^

† Relative risk reduction 0.50 over 5 years, based on the Hypertension Optimal Treatment trial; usual treatment 5-year incidence 7.5%^94^

‡ Prevalence data from National Health and Nutrition Examination Survey, 2002 data, IFG 100–126 mg/dl ^2^

§ Relative risk reduction based on the Diabetes Prevention Program: 58%; 38% achieved weight loss goal of 7% at end of 3-year follow-up (intention-to-treat analysis); control rate 11%^79^

‖ Relative risk reduction based on Diabetes Prevention Program: 31%, with compliance rates (80+% of medications taken) 77% in control, 72% in intervention group^79^

¶ Based on National Health and Nutrition Examination Survey, 1994 data^242^

# From National Institute of Diabetes and Digestive and Kidney Fact Sheet, 1994 data^241^

Abbreviations: CVD, cardiovascular disease; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; NNS, number needed to screen.

Table 11 Summary of Evidence

Number of Studies: Overall Quality Rating | Design; References | Limitation | Consistency | Primary Care Applicability | Summary of Findings
Key Question 1: Overall effect of screening on final outcomes
3 studies Poor | Case-control and cross-sectional studies^84^–^86^ | Data were limited; studies considered microvascular complications only. | Studies were consistent. | Case-control study was representative of a primary care population, but results did not represent population-level results from a screening program. Fair-quality cross-sectional study was a non-US population in an area of high screening rates and national registries; however, an unknown percentage was clinically detected. | Both fair-quality studies demonstrated no benefit for screening: Case-control study: Patients with 1 or more glucose screening event in 10 years had a 13% reduction in risk of severe microvascular T2DM complications. Cross-sectional study: No significant differences between T2DM population and general Swedish population (where there is a high level of screening for T2DM) in most measures of visual acuity. One poor-quality study showed NSD.
Key Question 2: Diabetes treatment
8 studies Fair | RCTs with diabetes vs. nondiabetes (subgroup analyses); RCTs with duration of T2DM ≤1 y^95^–^98,^ ^103,^ ^104,^ ^115^–^117^ | Several studies were probably underpowered for the diabetes subgroup. Because diabetes as a cardiovascular risk factor was itself an entry criterion for some studies, baseline characteristics differed between the diabetes and nondiabetes subgroups. | Studies generally showed no evidence of significant differential effect between diabetes and nondiabetes subgroups. | Studies were representative of a primary care population, but results did not represent population-level results from a screening program. | Persons with T2DM without known CVD seem to benefit from aggressive lipid-lowering treatment as much as persons without T2DM with known CVD. There is little strong evidence that specific antihypertensive drugs benefit persons with T2DM more than those without. Persons with T2DM seem to benefit from a lower BP target than persons without. Fair evidence suggests a marginal benefit of aspirin for primary prevention of CVD, although no clear evidence suggests that those with diabetes benefit more than other subgroups at high-risk for CVD.
Key Question 3: Prediabetes treatment
11 studies Fair | RCTs^79^–^81,^ ^136,^ ^138,^ ^148,^ ^154^–^157,^ ^161^ | Mean follow-up, approximately 3 years; longest follow-up, 7 years; only 3 studies examined long-term health outcomes. | Lifestyle and drug interventions consistently produced a decrease in incidence of T2DM | Trials consisted of highly selected participants. | Intensive lifestyle and pharmacotherapeutic interventions reduce the progression of prediabetes to T2DM at follow-up up to 7 years. Few data exist on the effect of these interventions on cardiovascular events, death, or other long-term health outcomes.
Key Question 4: Adverse effects of screening
8 studies Fair-poor | Cohort and cross-sectional studies^178^–^180,^ ^182,^ ^183,^ ^185,^ ^187,^ ^190^ | All observational studies; predominantly white study samples were composed of volunteers; short follow-up. | It is difficult to compare results across studies because of heterogeneous outcome measures and control groups; however, no serious adverse effects were noted. | Studies included persons at high risk for T2DM, so results may not be applicable to primary care populations. | Data were sparse on the psychological effects of screening for T2DM and no available data suggested significant adverse effects at up to 1-year follow-up. No study reported serious, long-term, adverse effects of a new diagnosis of T2DM.
Key Question 5: Adverse effects of treatment
24 studies Fair | Systematic reviews^193^–^195,^ ^197^–^206,^ ^208^–^218^ | Reviews were almost entirely based on trials of short to moderate duration; long-term data were lacking. | Not applicable; different drugs were examined in each review. | Included studies were largely trials of selected populations with limited applicability to real-world, primary care populations. | Acarbose: NSD in death from placebo; gastrointestinal side effects common Metformin: NSD in death, hypoglycemia, lactic acidosis vs. placebo or diet ACE-I: significant increase in cough vs. placebo β-Blockers: increase in withdrawals secondary to adverse events vs. placebo; NSD in total deaths Rosiglitazone: new data on potential for increased risk for cardiac events and heart failure

Abbreviations: ACE-I, angiotensin-converting enzyme inhibitor; BP, blood pressure; CVD, cardiovascular disease; NSD, no significant difference; OR, odds ratio; RCT, randomized controlled trial; T2DM, type 2 diabetes mellitus.