# References

1 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2007;30(Supp 1):S42-47. [pmid: 17192378].
2 Cowie CC, Rust KF, Byrd-Holt DD, et al. Prevalence of diabetes and impaired fasting glucose in adults in the U.S. population: National Health And Nutrition Examination Survey 1999-2002. Diabetes Care. 2006;29(6):1263-1268. [pmid: 16732006].
3 Gregg EW, Cadwell BL, Cheng YJ, et al. Trends in the prevalence and ratio of diagnosed to undiagnosed diabetes according to obesity levels in the U.S. Diabetes Care. 2004;27(12):2806-2812. [pmid: 15562189].
4 Centers for Disease Control and Prevention. National diabetes fact sheet: General information and national estimates on diabetes in the United States, 2003. Rev ed. Atlanta: U.S. Department of Health and Human Services; 2004.
5 Bergman RN, Finegood DT, Kahn SE. The evolution of beta-cell dysfunction and insulin resistance in type 2 diabetes. Eur J Clin Invest. 2002;32(Suppl 3):35-45. [pmid: 12028373].
6 Caro JJ, Lee K. An economic evaluation of atenolol vs. captopril in patients with type 2 diabetes (UKPDS 24). Curr Hypertens Rep. 2002;4(6):417.
7 Meigs JB, Muller DC, Nathan DM, et al. The natural history of progression from normal glucose tolerance to type 2 diabetes in the Baltimore Longitudinal Study of Aging. Diabetes. 2003;52(6):1475-1484. [pmid: 12765960].
8 Santaguida PL, Balion C, Hunt D, et al. Diagnosis, prognosis, and treatment of impaired glucose tolerance and impaired fasting glucose. Evidence Report/Technology Assessment No. 128. AHRQ Publication No. 05-E026-2. (Prepared by the McMaster University Evidence-based Practice Center under Contract no. 290-02-0020). Rockville, MD: Agency for Healthcare Research and Quality. September 2005.
9 Davies MJ, Raymond NT, Day JL, et al. Impaired glucose tolerance and fasting hyperglycaemia have different characteristics. Diabet Med. 2000;17(6):433-440. [pmid: 10975211].
10 European Diabetes Epidemiology Group. Glucose tolerance and mortality: comparison of WHO and American Diabetes Association diagnostic criteria. Lancet. 1999;354:617-621. [pmid: 10466661].
11 Tirosh A, Shai I, Tekes-Manova D, et al. Normal fasting plasma glucose levels and type 2 diabetes in young men. N Engl J Med. 2005;353(14):1454-1462. [pmid: 16207847].
12 Jarrett RJ. Do we need IGT?. Diabet Med. 1987;4(6):544-545. [pmid: 2962811].
13 Waugh N, Scotland G, McNamee P, et al. Screening for type 2 diabetes: literature review and economic modeling. Health Technol Assess. 2007;11(17).
14 Harris R, Klein R, Welborn T, et al. Onset of NIDDM occurs at least 4–7 years before clinical diagnosis. Diabetes Care. 1992;15:815-819. [pmid: 1516497].
15 Klein R, Klein BE, Moss SE, et al. Glycosylated hemoglobin predicts the incidence and progression of diabetic retinopathy. JAMA. 1988;260(19):2864-2871. [pmid: 3184351].
16 Stratton IM, Kohner EM, Aldington SJ, et al. UKPDS 50: risk factors for incidence and progression of retinopathy in Type II diabetes over 6 years from diagnosis. Diabetologia. 2001;44(2):156-163. [pmid: 11270671].
17 Younis N, Broadbent DM, Vora JP, et al. Incidence of sight-threatening retinopathy in patients with type 2 diabetes in the Liverpool Diabetic Eye Study: a cohort study. Lancet. 2003;361(9353):195-200. [pmid: 12547541].
18 Henricsson M, Tyrberg M, Heijl A, et al. Incidence of blindness and visual impairment in diabetic patients participating in an ophthalmological control and screening programme. Acta Ophthalmol Scand. 1996;74(6):533-538. [pmid: 9017036].
19 Davis TM, Stratton IM, Fox CJ, et al. U.K. Prospective Diabetes Study 22. Effect of age at diagnosis on diabetic tissue damage during the first 6 years of NIDDM. Diabetes Care. 1997;20(9):1435-1441. [pmid: 9283793].
20 Hu FB, Stampfer MJ, Haffner SM, et al. Elevated risk of cardiovascular disease prior to clinical diagnosis of type 2 diabetes. Diabetes Care. 2002;25(7):1129-1134. [pmid: 12087009].
21 Coutinho M, Gerstein HC, Wang Y, et al. The relationship between glucose and incident cardiovascular events. A meta-regression analysis of published data from 20 studies of 95,783 individuals followed for 12.4 years. Diabetes Care. 1999;22:233-240. [pmid: 10333939].
22 Chowdhury TA, Lasker SS. Complications and cardiovascular risk factors in South Asians and Europeans with early-onset type 2 diabetes. QJM. 2002;95(4):241-246. [pmid: 11937651].
23 Pan WH, Cedres LB, Liu K, et al. Relationship of clinical diabetes and asymptomatic hyperglycemia to risk of coronary heart disease mortality in men and women. Am J Epidemiol. 1986;123(3):504-516. [pmid: 3946397].
24 Haffner SM, Stern MP, Hazuda HP, et al. Cardiovascular risk factors in confirmed prediabetic individuals. Does the clock for coronary heart disease start ticking before the onset of clinical diabetes?. JAMA. 1990;263(21):2893-2898. [pmid: 2338751].
25 McPhillips JB, Barrett-Connor E, Wingard DL. Cardiovascular disease risk factors prior to the diagnosis of impaired glucose tolerance and non-insulin-dependent diabetes mellitus in a community of older adults. Am J Epidemiol. 1990;131(3):443-453. [pmid: 2301354].
26 Meigs JB, Nathan DM, Wilson PW, et al. Metabolic risk factors worsen continuously across the spectrum of nondiabetic glucose tolerance. The Framingham Offspring Study. Ann Intern Med. 1998;128(7):524-533. [pmid: 9518396].
27 Khaw KT, Wareham N, Luben R, et al. Glycated haemoglobin, diabetes, and mortality in men in Norfolk cohort of European prospective investigation of cancer and nutrition (EPIC-Norfolk). BMJ. 2001;322(7277):15-18. [pmid: 11141143]. [pmcid: 26599].
28 Verdecchia P, Reboldi G, Angeli F, et al. Adverse prognostic significance of new diabetes in treated hypertensive subjects. Hypertension. 2004;43(5):963-969. [pmid: 15037557].
29 Niskanen L, Turpeinen A, Penttila I, et al. Hyperglycemia and compositional lipoprotein abnormalities as predictors of cardiovascular mortality in type 2 diabetes: a 15-year follow-up from the time of diagnosis. Diabetes Care. 1998;21(11):1861-1869. [pmid: 9802734].
30 Taubert G, Winkelmann BR, Schleiffer T, et al. Prevalence, predictors, and consequences of unrecognized diabetes mellitus in 3266 patients scheduled for coronary angiography. Am Heart J. 2003;145(2):285-291. [pmid: 12595846].
31 Vancheri F, Curcio M, Burgio A, et al. Impaired glucose metabolism in patients with acute stroke and no previous diagnosis of diabetes mellitus. QJM. 2005;98(12):871-878. [pmid: 16239309].
32 Rathmann W, Icks A, Haastert B, et al. Undiagnosed diabetes mellitus among patients with prior myocardial infarction. Z Kardiol. 2002;91(8):620-625. [pmid: 12426825].
33 Norhammar A, Tenerz A, Nilsson G, et al. Glucose metabolism in patients with acute myocardial infarction and no previous diagnosis of diabetes mellitus: a prospective study. Lancet. 2002;359(9324):2140-2144. [pmid: 12090978].
34 Selvin E, Coresh J, Shahar E, et al. Glycaemia (haemoglobin A1c) and incident ischaemic stroke: the Atherosclerosis Risk in Communities (ARIC) Study. Lancet Neurol. 2005;4(12):821-826. [pmid: 16297840].
35 Selvin E, Coresh J, Golden SH, et al. Glycemic control and coronary heart disease risk in persons with and without diabetes: the Atherosclerosis Risk in Communities study. Arch Intern Med. 2005;165(16):1910-1916. [pmid: 16157837].
36 Selvin E, Marinopoulos S, Berkenblit G, et al. Meta-analysis: glycosylated hemoglobin and cardiovascular disease in diabetes mellitus. Ann Intern Med. 2004;141(6):421-431. [pmid: 15381515].
37 Stettler C, Allemann S, Juni P, et al. Glycemic control and macrovascular disease in types 1 and 2 diabetes mellitus: meta-analysis of randomized trials. Am Heart J. 2006;152(1):27-38. [pmid: 16824829].
38 Harris MI. Undiagnosed NIDDM: clinical and public health issues. Diabetes Care. 1993;16(4):642-652. [pmid: 8462395].
39 Blunt B, Barrett-Connor E, Wingard D. Evaluation of fasting plasma glucose as screening test for NIDDM in older adults. Rancho Bernardo Study. Diabetes Care. 1991;14(11):989-993. [pmid: 1797513].
40 Harris RP, Lux LJ, Bunton AJ, et al. Screening for Type 2 Diabetes Mellitus. (Prepared by RTI International Evidence-based Practice Center under contract 290-97-0011 for the Agency for Healthcare Research and Quality.) Rockville, MD: U.S. Department of Health and Human Services; February 2003. Systematic Evidence Review No. 19. Available at: http://www.ncbi.nlm.nih.gov/books/bv.fcgi?rid=hstat3.chapter.3895 Accessed January 2007.
41 Spijkerman AM, Adriaanse MC, Dekker JM, et al. Diabetic patients detected by population-based stepwise screening already have a diabetic cardiovascular risk profile. Diabetes Care. 2002;25(10):1784-1789. [pmid: 12351478].
42 Lindeman RD, Yau CL, Baumgartner RN, et al. Longitudinal study of fasting serum glucose concentrations in healthy elderly. The New Mexico Aging Process Study. J Nutr Health Aging. 2003;7(3):172-177. [pmid: 12766795].
43 Chen TH, Yen MF, Tung TH. A computer simulation model for cost-effectiveness analysis of mass screening for Type 2 diabetes mellitus. Diabetes Res Clin Pract. 2001;54(Suppl 1):S37-42. [pmid: 11580967].
44 Johnson SL, Tabaei BP, Herman WH. The efficacy and cost of alternative strategies for systematic screening for type 2 diabetes in the U.S. population 45–74 years of age. Diabetes Care. 2005;28(2):307-311. [pmid: 15677784].
45 Lawrence JM, Bennett P, Young A, et al. Screening for diabetes in general practice: cross sectional population study. BMJ. 2001;323(7312):548-551. [pmid: 11546702]. [pmcid: 48161].
46 American Diabetes Association. Standards of medical care in diabetes - 2007. Diabetes Care. 2007;30(Supp 1):S4-41. [pmid: 17192377].
47 Gomez-Perez FJ, Aguilar-Salinas CA, Lopez-Alvarenga JC, et al. Lack of agreement between the World Health Organization Category of impaired glucose tolerance and the American Diabetes Association category of impaired fasting glucose. Diabetes Care. 1998;21(11):1886-1888. [pmid: 9802737].
48 Mannucci E, Bardini G, Ognibene A, et al. Screening for diabetes in obese patients using the new diagnostic criteria. Diabetes Care. 1998;21(3):468-469. [pmid: 9540043].
49 Unwin N, Alberti KG, Bhopal R, et al. Comparison of the current WHO and new ADA criteria for the diagnosis of diabetes mellitus in three ethnic groups in the UK. Diabet Med. 1998;15(7):554-557. [pmid: 9686694].
50 Anand SS, Razak F, Vuksan V, et al. Diagnostic strategies to detect glucose intolerance in a multi-ethnic population. Diabetes Care. 2003;26(2):290-296. [pmid: 12547851].
51 Bennett CM, Guo M, Dharmage SC. HbA(1c) as a screening tool for detection of Type 2 diabetes: a systematic review. Diabet Med. 2007;24(4):333-343. [pmid: 17367307].
52 Perry RC, Shankar RR, Fineberg N, et al. HbA1c measurement improves the detection of type 2 diabetes in high-risk individuals with nondiagnostic levels of fasting plasma glucose: the Early Diabetes Intervention Program (EDIP). Diabetes Care. 2001;24(3):465-471. [pmid: 11289469].
53 Colagiuri S, Hussain Z, Zimmet P, et al. Screening for type 2 diabetes and impaired glucose metabolism: the Australian experience. Diabetes Care. 2004;27(2):367-371. [pmid: 14747215].
54 Edelman D, Olsen MK, Dudley TK, et al. Utility of hemoglobin A1c in predicting diabetes risk. J Gen Intern Med. 2004;19(12):1175-1180. [pmid: 15610327]. [pmcid: 1492588].
55 Ellison TL, Elliott R, Moyes SA. HbA1c screening for undiagnosed diabetes in New Zealand. Diabetes Metab Res Rev. 2005;21(1):65-70. [pmid: 15386815].
56 Geberhiwot T, Haddon A, Labib M. HbA1c predicts the likelihood of having impaired glucose tolerance in high-risk patients with normal fasting plasma glucose. Ann Clin Biochem. 2005;42(Pt 3):193-195. [pmid: 15949153].
57 Jesudason DR, Dunstan K, Leong D, et al. Macrovascular risk and diagnostic criteria for type 2 diabetes: implications for the use of FPG and HbA(1c) for cost-effective screening. Diabetes Care. 2003;26(2):485-490. [pmid: 12547886].
58 Maynard JD, Rohrscheib M, Way JF, et al. Noninvasive type 2 diabetes screening: superior sensitivity to fasting plasma glucose and A1C. Diabetes Care. 2007;30(5):1120-1124. [pmid: 17337498].
59 McAullay D, Sibthorpe B, Knuiman M. Evaluation of a new diabetes screening method at the Derbarl Yerrigan Health Service. Aust NZ J Public Health. 2004;28(1):43-46.
60 Norberg M, Eriksson JW, Lindahl B, et al. A combination of HbA1c, fasting glucose and BMI is effective in screening for individuals at risk of future type 2 diabetes: OGTT is not needed. J Intern Med. 2006;260(3):263-271. [pmid: 16918824].
61 Peters AL, Davidson MB, Schriger DL, et al. Meta-analysis Research Group on the Diagnosis of Diabetes Using Glycated Hemoglobin Levels. A clinical approach for the diagnosis of diabetes mellitus: an analysis using glycosylated hemoglobin levels. JAMA. 1996;276(15):1246-1252. [pmid: 8849753].
62 Rohlfing CL, Little RR, Wiedmeyer HM, et al. Use of GHb (HbA1c) in screening for undiagnosed diabetes in the U.S. population. Diabetes Care. 2000;23(2):187-191. [pmid: 10868829].
63 Shibata K, Suzuki S, Sato J, et al. Diagnostic accuracy of glycohemoglobin A1c (HbA1c) for postprandial hyperglycemia was equivalent to that of fasting blood glucose. J Clin Epidemiol. 2005;58(10):1052-1057. [pmid: 16168351].
64 Simmons D, Thompson CF, Engelgau MM. Controlling the diabetes epidemic: how should we screen for undiagnosed diabetes and dysglycaemia?. Diabet Med. 2005;22(2):207-212. [pmid: 15660740].
65 Wang W, Lee ET, Fabsitz R, et al. Using HbA(1c) to improve efficacy of the American diabetes association fasting plasma glucose criterion in screening for new type 2 diabetes in American Indians: the strong heart study. Diabetes Care. 2002;25(8):1365-1370. [pmid: 12145236].
66 Khaw KT, Wareham N, Bingham S, et al. Association of hemoglobin A1c with cardiovascular disease and mortality in adults: the European prospective investigation into cancer in Norfolk. Ann Intern Med. 2004;141(6):413-420. [pmid: 15381514].
67 Little RR, Rohlfing CL, Wiedmeyer HM, et al. The national glycohemoglobin standardization program: a five-year progress report. Clin Chem. 2001;47(11):1985-1992. [pmid: 11673367].
68 Hoelzel W, Weykamp C, Jeppsson JO, et al. IFCC reference system for measurement of hemoglobin A1c in human blood and the national standardization schemes in the United States, Japan, and Sweden: a method-comparison study. Clin Chem. 2004;50(1):166-174. [pmid: 14709644].
69 McCarter RJ, Hempe JM, Gomez R, et al. Biological variation in HbA1c predicts risk of retinopathy and nephropathy in type 1 diabetes. Diabetes Care. 2004;27(6):1259-1264. [pmid: 15161772].
70 Zhang P, Engelgau MM, Valdez R, et al. Efficient cutoff points for three screening tests for detecting undiagnosed diabetes and pre-diabetes: an economic analysis. Diabetes Care. 2005;28(6):1321-1325. [pmid: 15920046].
71 American Academy of Family Physicians (AAFP). Recommendations for Clinical Preventive Services. Available at: http://www.aafp.org/online/en/home/clinical/exam/a-e.html. Accessed December 2007.
72 Diabetes Australia. Part 3: Evidence based guideline for case detection and diagnosis of type 2 diabetes. National Evidence Based Guideline. Available at: http://www.diabetesaustralia.com.au/education_info/nebg.html. Accessed September, 2007.
73 Diabetes UK. Position statement 2006. Early identification of people with type 2 diabetes. Available at: www.diabetes.org.uk. Accessed September, 2007.
74 World Health Organization. Screening for type 2 diabetes. Report of a World Health Organization and International Diabetes Federation meeting. Available at:http://www.who.int/diabetes/publications/en/screening_mnc03.pdf. Accessed June 18, 2007.
75 U.S. Preventive Services Task Force. Screening for type 2 diabetes in adults: Recommendations and rationale. Ann Intern Med. 2003;138:215-229. [pmid: 12558362].
76 Harris R, Donahue K, Rathore S, et al. Screening adults for type 2 diabetes: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;138(3):215-229. [pmid: 12558362].
77 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
78 Stevens RJ, Kothari V, Adler AI, et al. United Kingdom Prospective Diabetes Study Group. The UKPDS risk engine: a model for the risk of coronary heart disease in Type II diabetes (UKPDS 56). Clin Sci. 2001;101(6):671-679. [pmid: 11724655].
79 Diabetes Prevention Program Research Group. Reduction in the Incidence of Type 2 Diabetes with Lifestyle Intervention or Metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527]. [pmcid: 1370926].
80 Heymsfield SB, Segal KR, Hauptman J, et al. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000;160(9):1321-1326. [pmid: 10809036].
81 Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67(2):152-162. [pmid: 15649575].
82 Dream Trial Investigators. Effect of ramipril on the incidence of diabetes. N Engl J Med. 2006;355(15):1551-1562. [pmid: 16980380].
83 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
84 Schellhase KG, Koepsell TD, Weiss NS, et al. Glucose screening and the risk of complications in Type 2 diabetes mellitus. J Clin Epidemiol. 2003;56(1):75-80. [pmid: 12589873].
85 Olafsdottir E, Andersson DK, Stefansson E. Visual acuity in a population with regular screening for type 2 diabetes mellitus and eye disease. Acta Ophthalmol Scand. 2007;85(1):40-45. [pmid: 17244208].
86 Agarwal S, Raman R, Kumari RP, et al. Diabetic retinopathy in type II diabetics detected by targeted screening versus newly diagnosed in general practice. Ann Acad Med Singapore. 2006;35(8):531-535. [pmid: 17006579].
87 Hoerger TJ, Harris R, Hicks KA, et al. Screening for type 2 diabetes mellitus: a cost-effectiveness analysis. Ann Intern Med. 2004;140(9):689-699. [pmid: 15126252].
88 Lauritzen T, Griffin S, Borch-Johnsen K, et al. The ADDITION study: proposed trial of the cost-effectiveness of an intensive multifactorial intervention on morbidity and mortality among people with Type 2 diabetes detected by screening. Int J Obes Relat Metab Disord. 2000;24(Supp 3):S6-S11. [pmid: 11063279].
89 Varma R, Ying-Lai M, Klein R, et al. Prevalence and risk indicators of visual impairment and blindness in Latinos: the Los Angeles Latino Eye Study. Ophthalmology. 2004;111(6):1132-1140. [pmid: 15177963].
90 CDC Diabetes Cost-Effectiveness Study Group. The cost-effectiveness of screening for type 2 diabetes. JAMA. 1998;280(20):1757-1763. [pmid: 9842951].
91 Goyder EC, Irwig LM. Screening for Type 2 diabetes mellitus: a decision analytic approach. Diabet Med. 2000;17(6):469-477. [pmid: 10975217].
92 Hofer TP, Vijan S, Hayward RA. Estimating the microvascular benefits of screening for type 2 diabetes mellitus. Int J Technol Assess Health Care. 2000;16(3):822-833. [pmid: 11028137].
93 Glumer C, Yuyun M, Griffin S, et al. What determines the cost-effectiveness of diabetes screening?. Diabetologia. 2006;49(7):1536-1544. [pmid: 16752172].
94 Hansson L, Zanchetti A, Carruthers G, et al. Effects of intensive blood-pressuring lowering and low-dose aspirin in patients with hypertension: principal results of the hypertension optimal treatment (HOT) randomised trial. Lancet. 1998;351:1755-1762. [pmid: 9635947].
95 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet. 2003;361(9374):2005-2016. [pmid: 12814710].
96 Sacco M, Pellegrini F, Roncaglioni MC, et al. Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes Care. 2003;26(12):3264-3272. [pmid: 14633812].
97 Ridker PM, Cook NR, Lee IM, et al. A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. 2005;352(13):1293-1304. [pmid: 15753114].
98 Olivarius NF, Beck-Nielsen H, Andreasen AH, et al. Randomised controlled trial of structured personal care of type 2 diabetes mellitus. BMJ. 2001;323(7319):970-975. [pmid: 11679387]. [pmcid: 59690].
99 U.K. Prospective Diabetes Study Group. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). Lancet. 1998;352(9131):854-865. [pmid: 9742977].
100 Wright AD, Cull CA, Macleod KM, et al. Hypoglycemia in Type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS 73. J Diabetes Complications. 2006;20(6):395-401. [pmid: 17070446].
101 Engelgau M, Narayan K, Herman W. Screening for type 2 diabetes. Diabetes Care. 2000;23(10):1563-1580. [pmid: 11023153].
102 Action to Control Cardiovascular Risk in Diabetes (ACCORD) [clinical trial]. ClinicalTrials.gov identifier: NCT00000620. Available at: www.clinicaltrials.gov/ct2/show/NCT00000620?term=NCT00000620&rank=1 on 8 Accessed January 2007.
103 Whelton PK, Barzilay J, Cushman WC, et al. Clinical outcomes in antihypertensive treatment of type 2 diabetes, impaired fasting glucose concentration, and normoglycemia: Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Arch Intern Med. 2005;165(12):1401-1409. [pmid: 15983290].
104 Black HR, Elliott WJ, Grandits G, et al. Principal results of the Controlled Onset Verapamil Investigation of Cardiovascular End Points (CONVINCE) trial. JAMA. 2003;289(16):2073-2082. [pmid: 12709465].
105 Lindholm LH, Ibsen H, Dahlof B, et al. Cardiovascular morbidity and mortality in patients with diabetes in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolo. Lancet. 2002;359(9311):1004-1010. [pmid: 11937179].
106 Dahlof B, Devereux RB, Kjeldsen SE, et al. Cardiovascular morbidity and mortality in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359(9311):995-1003. [pmid: 11937178].
107 Blood Pressure Lowering Treatment Trialists Collaboration. Effects of different blood pressure-lowering regimens on major cardiovascular events in individuals with and without diabetes mellitus. Arch Intern Med. 2005;165:1410-1419. [pmid: 15983291].
108 HOPE and HOPE-TOO Investigators. Long-term effects of ramipril on cardiovascular events and diabetes: results of the HOPE Study Evaluation. Circulation. 2005;112(9):1339-1346. [pmid: 16129815].
109 HOPE (Heart Outcomes Prevention Evaluation) Study Investigators. Effects of ramipril on cardiovascular and microvascular outcomes in people with diabetes mellitus: results of the HOPE study and MICRO-HOPE substudy. Lancet. 2000;355(9200):253-259. [pmid: 10675071].
110 Brenner BM, Cooper ME, de Zeeuw D, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. N Engl J Med. 2001;345(12):861-869. [pmid: 11565518].
111 Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. 2001;345(12):851-860. [pmid: 11565517].
112 United Kingdom Prospective Diabetes Study (UKPDS) Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes, UKPDS 38. BMJ. 1998;317:703-713. [pmid: 9732337]. [pmcid: 28659].
113 Estacio RO, Jeffers BW, Glifford N, et al. Effect of blood pressure control on diabetic microvascular complications in patients with hypertension and type 2 diabetes. Diabetes Care. 2000;23(Supp 2):B54-64. [pmid: 10860192].
114 Schrier RW, Estacio RO, Esler A, et al. Effects of aggressive blood pressure control in normotensive type 2 diabetic patients on albuminuria, retinopathy and strokes. Kidney Int. 2002;61(3):1086-1097. [pmid: 11849464].
115 ALLHAT Officers. Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). JAMA. 2002;288(23):2998-3007. [pmid: 12479764].
116 Sever PS, Dahlof B, Poulter NR, et al. Prevention of coronary and stroke events with atorvastatin in hypertensive patients who have average or lower-than-average cholesterol concentrations, in the Anglo-Scandinavian Cardiac Outcomes Trial—Lipid Lowering Arm (ASCOT-LLA): a multi-centre randomised controlled trial. Lancet. 2003;361(9364):1149-1158. [pmid: 12686036].
117 Shepherd J, Blauw GJ, Murphy MB, et al. Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002;360:1623-1630. [pmid: 12457784].
118 Sever PS, Poulter NR, Dahlof B, et al. Reduction in cardiovascular events with atorvastatin in 2,532 patients with type 2 diabetes: Anglo-Scandinavian Cardiac Outcomes Trial—lipid-lowering arm (ASCOT-LLA). Diabetes Care. 2005;28(5):1151-1157. [pmid: 15855581].
119 Costa J, Borges M, David C, et al. Efficacy of lipid lowering drug treatment for diabetic and non-diabetic patients: meta-analysis of randomised controlled trials. BMJ. 2006;332(7550):1115-1124. [pmid: 16585050]. [pmcid: 1459619].
120 Antithrombotic Trialists Collaboration. Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction and stroke in high-risk patients. BMJ. 2002;324:71-86. [pmid: 11786451]. [pmcid: 64503].
121 Early Treatment Diabetic Retinopathy Study Group. Early Treatment Diabetic Retinopathy Study design and baseline patient characteristics. ETDRS Report No. 7. Ophthalmology. 1991;98(5 Suppl):741-756. [pmid: 2062510].
122 Steering Committee of the Physicians' Health Study Research Group. Final report on the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1989;321:129-135. [pmid: 2664509].
123 CDC Diabetes Cost-effectiveness Group. Cost-effectiveness of intensive glycemic control, intensified hypertension control, and serum cholesterol level reduction for type 2 diabetes. JAMA. 2002;287(19):2542-2551. [pmid: 12020335].
124 Palmer AJ, Roze S, Valentine WJ, et al. The CORE Diabetes Model: Projecting long-term clinical outcomes, costs and cost-effectiveness of interventions in diabetes mellitus (types 1 and 2) to support clinical and reimbursement decision-making. Curr Med Res Opin. 2004;20(Suppl 1):S5-26.
125 Clarke PM, Gray AM, Briggs A, et al. Cost-utility analyses of intensive blood glucose and tight blood pressure control in type 2 diabetes (UKPDS 72). Diabetologia. 2005;48(5):868-877. [pmid: 15834550].
126 Brown JB, Palmer AJ, Bisgaard P, et al. The Mt. Hood challenge: cross-testing two diabetes simulation models. Diabetes Res Clin Pract. 2000;50(Suppl 3):S57-64. [pmid: 11080563].
127 Mount Hood 4 Modeling Group. Computer modeling of diabetes and its complications: a report on the Fourth Mount Hood Challenge Meeting. Diabetes Care. 2007;30(6):1638-1646. [pmid: 17526823].
128 Palmer AJ, Roze S, Valentine WJ, et al. Impact of changes in HbA1c, lipids and blood pressure on long-term outcomes in type 2 diabetes patients: an analysis using the CORE Diabetes Model. Curr Med Res Opin. 2004;20(Suppl 1):S53-S58. [pmid: 15324516].
129 Clarke P, Gray A, Adler A, et al. Cost-effectiveness analysis of intensive blood-glucose control with metformin in overweight patients with type II diabetes (UKPDS No. 51). Diabetologia. 2001;44(3):298-304. [pmid: 11317659].
130 Clarke P, Gray A, Legood R, et al. The impact of diabetes-related complications on healthcare costs: results from the United Kingdom Prospective Diabetes Study (UKPDS 65). Diabet Med. 2003;20(6):442-450. [pmid: 12786677].
131 Clarke P, Gray A, Briggs A, et al. A model to estimate the lifetime health outcomes of patients with Type 2 diabetes; the United Kingdom Prospective Diabetes Study outcomes model (UKPDS 68). Diabetologia. 2004;47:1747-1759. [pmid: 15517152].
132 Gray A, Raikou M, McGuire A, et al. United Kingdom Prospective Diabetes Study Group. Cost effectiveness of an intensive blood glucose control policy in patients with type 2 diabetes: economic analysis alongside randomised controlled trial (UKPDS 41). BMJ. 2000;320(7246):1373-1378. [pmid: 10818026]. [pmcid: 27380].
133 Brown JB, Russell A, Chan W, et al. The global diabetes model: user friendly version 3.0. Diabetes Res Clin Pract. 2000;50(Suppl 3):S15-46. [pmid: 11080561].
134 Dyson PA, Hanmmersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997;46:50-55. [pmid: 9439560].
135 Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20:537-544. [pmid: 9096977].
136 Chiasson JL, Josse RG, Gomis R, et al. Acarbose for prevention of type 2 diabetes mellitus: the STOP-NIDDM randomised trial. Lancet. 2002;359(9323):2072-2077. [pmid: 12086760].
137 Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527]. [pmcid: 1370926].
138 Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343-1350. [pmid: 11333990].
139 Diabetes Prevention Program Research Group. The Diabetes Prevention Program: baseline characteristics of the randomized cohort. Diabetes Care. 2000;23(11):1619-1629. [pmid: 11092283]. [pmcid: 1360735].
140 Diabetes Prevention Program Research Group. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. 2005;28(4):888-894. [pmid: 15793191]. [pmcid: 1307521].
141 Fujimoto WY. Background and recruitment data for the U.S. Diabetes Prevention Program. Diabetes Care. 2000;23(Suppl 12):B11-B13. [pmid: 10860185].
142 Diabetes Prevention Program Research Group. Effects of withdrawal from metformin on the development of diabetes in the diabetes prevention program. Diabetes Care. 2003;26(4):977-980. [pmid: 12663559]. [pmcid: 1360737].
143 Diabetes Prevention Program Research Group. The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61(10):1075-1081. [pmid: 17077202]. [pmcid: 1783677].
144 Kriska AM, Edelstein SL, Hamman RF, et al. Physical activity in individuals at risk for diabetes: Diabetes Prevention Program. Med Sci Sports Exerc. 2006;38(5):826-832. [pmid: 16672833]. [pmcid: 1570396].
145 Diabetes Prevention Program Research Group. Strategies to identify adults at high risk for type 2 diabetes: the Diabetes Prevention Program. Diabetes Care. 2005;28(1):138-144. [pmid: 15616247]. [pmcid: 1314971].
146 Diabetes Prevention Program Research Group. Relationship of body size and shape to the development of diabetes in the diabetes prevention program. Obesity. 2006;14(11):2107-2117. [pmid: 17135629]. [pmcid: 2373982].
147 Dream Trial Investigators. Rationale, design and recruitment characteristics of a large, simple international trial of diabetes prevention: the DREAM trial. Diabetologia. 2004;47(9):1519-1527. [pmid: 15322749].
148 Dream Trial Investigators. Effect of rosiglitazone on the frequency of diabetes in patients with impaired glucose tolerance or impaired fasting glucose: a randomised controlled trial. Lancet. 2006;368(9541):1096-1105. [pmid: 16997664].
149 Lindstrom J, Eriksson JG, Valle TT, et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14(7 Suppl 2):S108-113. [pmid: 12819313].
150 Lindstrom J, Louheranta A, Mannelin M, et al. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26(12):3230-3236. [pmid: 14633807].
151 Eriksson J, Lindstrom J, Valle T, et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42(7):793-801. [pmid: 10440120].
152 Laaksonen DE, Lindstrom J, Lakka TA, et al. Physical activity in the prevention of type 2 diabetes: the Finnish Diabetes Prevention Study. Diabetes. 2005;54(1):158-165. [pmid: 15616024].
153 Lindstrom J, Ilanne-Parikka P, Peltonen M, et al. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet. 2006;368(9548):1673-1679. [pmid: 17098085].
154 Ramachandran A, Snehalatha C, Mary S, et al. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49(2):289-297. [pmid: 16391903].
155 Watanabe M, Yamaoka K, Yokotsuka M, et al. Randomized controlled trial of a new dietary education program to prevent type 2 diabetes in a high-risk group of Japanese male workers. Diabetes Care. 2003;26(12):3209-3214. [pmid: 14633803].
156 Pan CY, Gao Y, Chen JW, et al. Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003;61(3):183-190. [pmid: 12965108].
157 Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24(4):619-624. [pmid: 11315819].
158 Chiasson JL, Gomis R, Hanefeld M, et al. The STOP-NIDDM Trial: an international study on the efficacy of an alpha-glucosidase inhibitor to prevent type 2 diabetes in a population with impaired glucose tolerance: rationale, design, and preliminary screening data. Study to Prevent Non-Insulin-Dependent Diabetes Mellitus. Diabetes Care. 1998;21(10):1720-1725. [pmid: 9773737].
159 Chiasson JL, Josse RG, Gomis R, et al. Acarbose treatment and the risk of cardiovascular disease and hypertension in patients with impaired glucose tolerance: the STOP-NIDDM trial. JAMA. 2003;290(4):486-494. [pmid: 12876091].
160 Torgerson JS, Arlinger K, Kappi M, et al. Principles for enhanced recruitment of subjects in a large clinical trial. The XENDOS (XENical in the prevention of Diabetes in Obese Subjects) study experience. Control Clin Trials. 2001;22(5):515-525. [pmid: 11578785].
161 Torgerson JS, Hauptman J, Boldrin MN, et al. XENical in the prevention of diabetes in obese subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. 2004;27(1):155-161. [pmid: 14693982].
162 Gillies CL, Abrams KR, Lambert PC, et al. Pharmacological and lifestyle interventions to prevent or delay type 2 diabetes in people with impaired glucose tolerance: systematic review and meta-analysis. BMJ. 2007;334(7588):299. [pmid: 17237299]. [pmcid: 1796695].
163 Yamaoka K, Tango T. Efficacy of lifestyle education to prevent type 2 diabetes: a meta-analysis of randomized controlled trials. Diabetes Care. 2005;28(11):2780-2786. [pmid: 16249558].
164 Wein P, Beischer N, Harris C, et al. A trial of simple versus intensified dietary modification for prevention of progression to diabetes mellitus in women with impaired glucose tolerance. Aust N Z J Obstet Gynaecol. 1999;39(2):162-166. [pmid: 10755770].
165 The DREAM (Diabetes REduction Assessment with ramipril and rosiglitazone Medication) Trial Investigators. Effect of rosiglitazone on the frequency of diabetes in patients with impaired glucose tolerance or impaired fasting glucose: a randomized controlled trial. Lancet. 2006;368:1096-1105. [pmid: 16997664].
166 Zinman B, Hoogwerf BJ, Duran Garcia S, et al. The effect of adding exenatide to a thiazolidinedione in suboptimally controlled type 2 diabetes: a randomized trial. Ann Intern Med. 2007;146(7):477-485. [pmid: 17404349].
167 Zinman B, Harris SB, Gerstein HC, et al. Preventing type 2 diabetes using combination therapy: design and methods of the CAnadian Normoglycaemia Outcomes Evaluation (CANOE) trial. Diabetes Obes Metab. 2006;8(5):531-537. [pmid: 16918588].
168 Saaristo T, Peltonen M, Keinanen-Kiukaanniemi S, et al. National type 2 diabetes prevention programme in Finland: FIN-D2D. Int J Circumpolar Health. 2007;66(2):101-112. [pmid: 17515250].
169 Eddy DM, Schlessinger L, Kahn R. Clinical outcomes and cost-effectiveness of strategies for managing people at high risk for diabetes. Ann Intern Med. 2005;143(4):251-264. [pmid: 16103469].
170 Eddy DM, Schlessinger L. Archimedes: a trial-validated model of diabetes. Diabetes Care. 2003;26(11):3093-3101. [pmid: 14578245].
171 Eddy DM, Schlessinger L. Validation of the Archimedes diabetes model. Diabetes Care. 2003;26(11):3102-3110. [pmid: 14578246].
172 Herman WH, Hoerger TJ, Brandle M, et al. The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. 2005;142(5):323-332. [pmid: 15738451].
173 Segal L, Dalton A, Richardson J. Cost-effectiveness of the primary prevention of non-insulin dependent diabetes mellitus. Health Promot Int. 1998;13(3):197-210.
174 Caro JJ, Getsios D, Caro I, et al. Economic evaluation of therapeutic interventions to prevent Type 2 diabetes in Canada. Diabet Med. 2004;21(11):1229-1236. [pmid: 15498090].
175 Engelgau MM. Trying to predict the future for people with diabetes: a tough but important task. Ann Intern Med. 2005;143(4):301-302. [pmid: 16103474].
176 Palmer AJ, Roze S, Valentine WJ, et al. Intensive lifestyle changes or metformin in patients with impaired glucose tolerance: modeling the long-term health economic implications of the diabetes prevention program in Australia, France, Germany, Switzerland, and the United Kingdom. Clin Ther. 2004;26(2):304-321. [pmid: 15038953].
177 Lindgren P, Lindstrom J, Tuomilehto J, et al. Lifestyle intervention to prevent diabetes in men and women with impaired glucose tolerance is cost-effective. Int J Technol Assess Health Care. 2007;23(2):177-183. [pmid: 17493303].
178 Adriaanse MC, Dekker JM, Spijkerman AM, et al. Health-related quality of life in the first year following diagnosis of Type 2 diabetes: newly diagnosed patients in general practice compared with screening-detected patients. The Hoorn Screening Study. Diabet Med. 2004;21(10):1075-1081. [pmid: 15384953].
179 Adriaanse MC, Dekker JM, Spijkerman AM, et al. Diabetes-related symptoms and negative mood in participants of a targeted population-screening program for type 2 diabetes: The Hoorn Screening Study. Qual Life Res. 2005;14(6):1501-1509. [pmid: 16110930].
180 Adriaanse MC, Snoek FJ, Dekker JM, et al. No substantial psychological impact of the diagnosis of Type 2 diabetes following targeted population screening: The Hoorn Screening Study. Diabet Med. 2004;21(9):992-998. [pmid: 15317604].
181 Adriaanse MC, Snoek FJ, Dekker JM, et al. Screening for Type 2 diabetes: an exploration of subjects' perceptions regarding diagnosis and procedure. Diabet Med. 2002;19(5):406-411. [pmid: 12027929].
182 Edelman D, Olsen MK, Dudley TK, et al. Impact of diabetes screening on quality of life. Diabetes Care. 2002;25(6):1022-1026. [pmid: 12032109].
183 Farmer AJ, Doll H, Levy JC, et al. The impact of screening for Type 2 diabetes in siblings of patients with established diabetes. Diabet Med. 2003;20(12):996-1004. [pmid: 14632700].
184 Farmer AJ, Doll HA. In a randomized trial, outcomes were not affected by intensive follow-up over 1 year. J Clin Epidemiol. 2005;58(10):991-996. [pmid: 16168344].
185 Nichols GA, Brown JB. Functional status before and after diagnosis of Type 2 diabetes. Diabet Med. 2004;21(7):793-797. [pmid: 15209777].
186 Peel E, Parry O, Douglas M, et al. Diagnosis of type 2 diabetes: a qualitative analysis of patients' emotional reactions and views about information provision. Patient Educ Couns. 2004;53(3):269-275. [pmid: 15186863].
187 Skinner TC, Davies MJ, Farooqi AM, et al. Diabetes screening anxiety and beliefs. Diabet Med. 2005;22(11):1497-1502. [pmid: 16241913].
188 Thoolen BJ, de Ridder DT, Bensing JM, et al. Psychological outcomes of patients with screen-detected type 2 diabetes: the influence of time since diagnosis and treatment intensity. Diabetes Care. 2006;10(Oct 29):2257-2262. [pmid: 17003303].
189 Eborall H, Davies R, Kinmonth AL, et al. Patients' experiences of screening for type 2 diabetes: prospective qualitative study embedded in the ADDITION (Cambridge) randomised controlled trial. BMJ. 2007;335(7618):490. [pmid: 17762000]. [pmcid: 1971165].
190 Eborall HC, Griffin SJ, Prevost AT, et al. Psychological impact of screening for type 2 diabetes: controlled trial and comparative study embedded in the ADDITION (Cambridge) randomised controlled trial. BMJ. 2007;335(7618):486. [pmid: 17761995]. [pmcid: 1971192].
191 The Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 1997;20:1183-1197. [pmid: 9203460].
192 Nissen SE. Effect of rosiglitazone on the risk of myocardial infarction and death from cardiovascular causes. N Engl J Med. 2007;356:2457-2471. [pmid: 17517853].
193 Van de Laar FA, Lucassen PLBJ, Akkermans RP, et al. Alpha-glucosidase inhibitors for people with impaired glucose tolerance or impaired fasting blood glucose. Cochrane Database Syst Rev 2006, Issue 4. Art. No.: CD005061. DOI:10.1002/14651858.CD005061.pub2.
194 Van de Laar FA, Lucassen PL, Akkermans RP, et al. Alpha-glucosidase inhibitors for patients with type 2 diabetes: results from a Cochrane systematic review and meta-analysis. Diabetes Care. 2005;28(1):154-163. [pmid: 15616251].
195 Strippoli GF, Bonifati C, Craig M, et al. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression of diabetic kidney disease. Cochrane Database Syst Rev. 2006(4):CD006257.
196 Strippoli GF, Craig M, Deeks JJ, et al. Effects of angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists on mortality and renal outcomes in diabetic nephropathy: systematic review. BMJ. 2004;329(7470):828. [pmid: 15459003]. [pmcid: 521570].
197 McDonald MA, Simpson SH, Ezekowitz JA, et al. Angiotensin receptor blockers and risk of myocardial infarction: systematic review. BMJ. 2005;331(7521):873. [pmid: 16183653]. [pmcid: 1255791].
198 Velazquez-Armenta EY, Han JY, Choi JS, et al. Angiotensin II receptor blockers in pregnancy: a case report and systematic review of the literature. Hypertens Pregnancy. 2007;26(1):51-66. [pmid: 17454218].
199 Verdecchia P, Angeli F, Gattobigio R, et al. Do angiotensin II receptor blockers increase the risk of myocardial infarction?. Eur Heart J. 2005;26(22):2381-2386. [pmid: 16081468].
200 McQuaid KR, Laine L. Systematic review and meta-analysis of adverse events of low-dose aspirin and clopidogrel in randomized controlled trials. Am J Med. 2006;119(8):624-638. [pmid: 16887404].
201 Berger JS, Roncaglioni MC, Avanzini F, et al. Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials. JAMA. 2006;295(3):306-313. [pmid: 16418466].
202 Wiysonge CS, Bradley H,Mayosi BM,et al. Beta-blockers for hypertension. Cochrane Database Syst Rev. 2007, Issue 1. Art. No.: CD002003. DOI: 10.1002/14651858.CD002003.pub2.
203 Bolen S, Feldman L, Vassy J, et al. Systematic Review: Comparative Effectiveness and Safety of Oral Medications for Type 2 Diabetes Mellitus. Ann Intern Med. 2007;147(6):386-399. [pmid: 17638715].
204 Gangji AS, Cukierman T, Gerstein HC, et al. A systematic review and meta-analysis of hypoglycemia and cardiovascular events: a comparison of glyburide with other secretagogues and with insulin. Diabetes Care. 2007;30(2):389-394. [pmid: 17259518].
205 Saenz A, Fernandez-Esteban I, Mataix A, et al. Metformin monotherapy for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2005(3):CD002966.
206 Salpeter S, Greyber E, Pasternak G, et al. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev. 2006(1):CD002967.
207 Salpeter SR, Greyber E, Pasternak GA, et al. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus: systematic review and meta-analysis. Arch Intern Med. 2003;163(21):2594-2602. [pmid: 14638559].
208 Setter SM, Iltz JL, Thams J, et al. Metformin hydrochloride in the treatment of type 2 diabetes mellitus: a clinical review with a focus on dual therapy. Clin Ther. 2003;25(12):2991-3026. [pmid: 14749143].
209 Bonovas S, Sitaras NM. Does pravastatin promote cancer in elderly patients? A meta-analysis. Can Med Assoc J. 2007;176(5):649-654. [pmid: 17325332]. [pmcid: 1800335].
210 McClure DL, Valuck RJ, Glanz M, et al. Systematic review and meta-analysis of clinically relevant adverse events from HMG CoA reductase inhibitor trials worldwide from 1982 to present. Pharmacoepidemiol Drug Saf. 2007;16(2):132-143. [pmid: 17072896].
211 Law M, Rudnicka AR. Statin safety: a systematic review. Am J Cardiol. 2006;97(8A):52C-60C.
212 Silva MA, Swanson AC, Gandhi PJ, et al. Statin-related adverse events: a meta-analysis. Clin Ther. 2006;28(1):26-35. [pmid: 16490577].
213 Norris SL, Carson S, Roberts C. Drug Class Review on Thiazolidinediones. Available at: http://www.ohsu.edu/drugeffectiveness/reports/final.cfm. Assessed 2007
214 Richter B, Bandeira-Echtler E, Bergerhoff K, et al. Rosiglitazone for type 2 diabetes mellitus. Cochrane Database Syst Rev 2007, Issue 3. Art. No.: CD006063. DOI: 10.1002/14651858.CD006063.pub2.
215 Richter B, Bandeira-Echtler E, Bergerhoff K, et al. Pioglitazone for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2006, Issue 4. Art. No.: CD006060. DOI: 10.1002/14651858.CD006060.pub2.
216 Singh S, Loke YK, Furberg CD. Long-term risk of cardiovascular events with rosiglitazone: a meta-analysis. JAMA. 2007;298(10):1189-1195. [pmid: 17848653].
217 Norris SL, Zhang X, Avenell A, et al. Pharmacotherapy for weight loss in adults with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2005, Issue 1. Art. No.: CD004096. DOI: 10.1002/14651858.CD004096.pub2.
218 Li Z, Maglione M, Tu W, et al. Meta-analysis: pharmacologic treatment of obesity. Ann Intern Med. 2005;142:532-546. [pmid: 15809465].
219 Strippoli GFM, Bonifati C, Craig M, et al. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression of diabetic kidney disease. Cochrane Database Syst. Rev. 2006, Issue 4. Art. No.: CD006257. DOI: 10.1002/14651858.CD006257.
220 Home PD, Pocock SJ, Beck-Nielsen H, et al. Rosiglitazone evaluated for cardiovascular outcomes — An interim analysis. N Engl J Med. 2007;357.
221 Lincoff AM, Wolski K, Nicholls SJ, et al. Pioglitazone and risk of cardiovascular events in patients with type 2 diabetes mellitus: a meta-analysis of randomized trials. JAMA. 2007;298(10):1180-1188. [pmid: 17848652].
222 Dormandy JA, Charbonnel B, Eckland DJ, et al. Secondary prevention of macrovascular events in patients with type 2 diabetes in the PROactive Study (PROspective pioglitAzone Clinical Trial In macroVascular Events): a randomised controlled trial. Lancet. 2005;366(9493):1279-1289. [pmid: 16214598].
223 U.K. Prospective Diabetes Study Group. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). Lancet. 1998;352(9131):837-853. [pmid: 9742976].
224 Stern MP, Williams K, Haffner SM. Identification of persons at high risk for type 2 diabetes mellitus: do we need the oral glucose tolerance test?. Ann Intern Med. 2002;136(8):575-581. [pmid: 11955025].
225 Lorenzo C, Okoloise M, Williams K, et al. The metabolic syndrome as predictor of type 2 diabetes: the San Antonio Heart Study. Diabetes Care. 2003;26(11):3153-3159. [pmid: 14578254].
226 Wilson PWF, Meigs JB, Sullivan L, et al. Prediction of Incident Diabetes Mellitus in Middle-aged Adults: The Framingham Offspring Study. Arch Int Med. 2007;167(10):1068-1074. [pmid: 17533210].
227 Greaves CJ, Stead JW, Hattersley AT, et al. A simple pragmatic system for detecting new cases of type 2 diabetes and impaired fasting glycaemia in primary care. Fam Pract. 2004;21(1):57-62. [pmid: 14760046].
228 Schmidt MI, Duncan BB, Bang H, et al. Identifying individuals at high risk for diabetes: The Atherosclerosis Risk in Communities (ARIC) study. Diabetes Care. 2005;28(8):2013-2018. [pmid: 16043747].
229 Colhoun HM, Betteridge DJ, Durrington PN, et al. Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet. 2004;364(9435):685-696. [pmid: 15325833].
230 Stamler J, Vaccaro O, Neaton JD, et al. Diabetes, other risk factors, and 12-yr cardiovascular mortality for men screened in the Multiple Risk Factor Intervention Trial. Diabetes Care. 1993;16(2):434-444. [pmid: 8432214].
231 Barzilay JI, Spiekerman CF, Kuller LH, et al. Prevalence of clinical and isolated subclinical cardiovascular disease in older adults with glucose disorders: the Cardiovascular Health Study. Diabetes Care. 2001;24(7):1233-1239. [pmid: 11423508].
232 Rodriguez BL, Abbott RD, Fujimoto W, et al. The American Diabetes Association and World Health Organization classifications for diabetes: their impact on diabetes prevalence and total and cardiovascular disease mortality in elderly Japanese-American men. Diabetes Care. 2002;25(6):951–5(6):951–955.
233 Orchard TJ, Temprosa M, Goldberg R, et al. The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Ann Intern Med. 2005;142(8):611-619. [pmid: 15838067]. [pmcid: 2505046].
234 Curb JD, Pressel SL, Cutler JA, et al. Systolic Hypertension in the Elderly Program Cooperative Research Group. Effect of diuretic-based antihypertensive treatment on cardiovascular disease risk in older diabetic patients with isolated systolic hypertension. JAMA. 1996;276(23):1886-1892. [pmid: 8968014].
235 Dailey GE 3rd. Early insulin: an important therapeutic strategy. Diabetes Care. 2005;28(1):220-221. [pmid: 15616256].
236 Diabetes Control and Complications Trial Research Group. The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. New Engl J Med. 1993;329(14):977-986. [pmid: 8366922].
237 Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications (DCCT/EDIC) Study Research Group. Intensive diabetes treatment and cardiovascular disease in patients with type 2 diabetes. New Engl J Med. 2005;353(25):2643-2653. [pmid: 16371630]. [pmcid: 2637991].
238 Grimes DA, Schultz KF. Uses and abuses of screening tests. Lancet. 2002;359:881-884. [pmid: 11897304].
239 Williamson DF, Vinicor F, Bowman BA. Centers for Disease Control and Prevention Primary Prevention Working Group. Primary prevention of type 2 diabetes mellitus by lifestyle intervention: implications for health policy. Ann Intern Med. 2004;140(11):951-957. [pmid: 15172920].
240 Zhang P, Engelgau MM, Valdez R, et al. Costs of screening for pre-diabetes among U.S. adults: a comparison of different screening strategies. Diabetes Care. 2003;26(9):2536-2542. [pmid: 12941715].
241 National Institute of Diabetes and Digestive and Kidney Diseases. National Diabetes Statistics fact sheet: general information and national estimates on diabetes in the United States, 2005. Bethesda, MD: U.S. Department of Health and Human Services, National Institute of Health, 2005. Available at: http://ndep.nih.gov/diabetes/pubs/2005_National_Diabetes_Fact_Sheet.pdf. Accessed January 2007.
242 Harris MI, Flegal KM, Cowie CC, et al. Prevalence of diabetes, impaired fasting glucose, and impaired glucose tolerance in U.S. adults. The Third National Health and Nutrition Examination Survey, 1988-1994. Diabetes Care. 1998;21(4):518-24. [pmid: 9571335].