# Acknowledgements

The authors gratefully acknowledge Andrew Hamilton, MLS, MS for assistance in developing and running search strategies. Mark Helfand, MD, MPH and Evelyn Whitlock, MD, MPH, (of the Oregon Evidence-based Practice Center); AHRQ Officers Tracy Wolff, MD, MPH and Mary Barton, MD, MPP; US Preventive Services Task Force leads Russ Harris, MD, MPH, Virginia Moyer, MD, MPH; Ned Calonge, MD, MPH, and George Isham, MD, MS provided valuable guidance and insights. Tracy Dana, MLS assisted with data abstraction. Sarah Baird, MS provided technical assistance.