# Discussion

The ultimate goal of screening is to identify individuals who would not have otherwise come to clinical attention, and who would experience improved health outcomes from the initiation of a specific treatment after diagnosis. Screening for hyperglycemia can identify persons with undiagnosed diabetes or those at risk for developing diabetes and classified as having prediabetes. The treatments prompted by diagnosis and addressed by the studies in our review include lifestyle interventions, the use of hypoglycemic agents, and cardiovascular risk reduction mainly through blood pressure and lipid control strategies.

As yet, there is no direct evidence that clearly determines whether or not screening asymptomatic individuals for diabetes or prediabetes alters final health outcomes. There is evidence both from the prior review,^76^ and from this update, showing that persons with diabetes who are at risk for cardiovascular disease do benefit from aggressive blood pressure lowering and lipid-lowering therapy, although this has not yet been demonstrated in screen-detected individuals. Persons with newly-diagnosed, largely clinically-detected diabetes, derive benefit from intensive glycemic control largely from a reduction in microvascular events.^223^ There is also evidence that in persons with prediabetes - an implicitly screen-detected population - intensive lifestyle modification likely delays the progression to clinical diabetes, although there is uncertainty about the ultimate benefit of such treatment in altering the natural history or improving final health outcomes.

The Outcomes Table (Table 10) shows the number-needed-to-screen (NNS) to prevent an outcome of interest in different theoretical populations. The NNS to prevent one case of blindness in one eye, or one cardiovascular event from aggressive blood pressure control over 5 years, has not changed from the prior estimates of Harris and colleagues,^76^ as no new data on the effectiveness of these interventions were identified in this review. As noted previously,^76^ interventions that target cardiovascular events produce greater effects than those targeting microvascular complications, which occur later in the disease process.

Using data from the HPS^95^ on the effects of tight lipid control on cardiovascular outcomes, estimates of the NNS to prevent one cardiovascular event are similar to estimates from aggressive blood pressure control estimated from the HOT trial;^94^ however given the lack of clear differential benefit of lipid-lowering therapy between the diabetic and non-diabetic subgroups in the HPS, these NNS estimates should be interpreted with caution.

Estimates of the NNS to delay one case of diabetes using an intensive lifestyle intervention based on the DPP^79^ and the Finnish Diabetes Study^138^ (i.e., to prevent one case over the duration of follow-up) are relatively favorable; screening 1,000 persons with prediabetes will delay 44 cases of DM2 over 3.0 years. Pharmacotherapy with metformin produced somewhat less favorable NNS, as the relative risk reduction was not as great as with the lifestyle intervention.^79^ As with the prior review,^40,^ ^76^ there remain a number of important assumptions underlying the estimates of NNS, including length of the asymptomatic period, prevalence of undiagnosed diabetes or prediabetes, incidence rates of diabetes complications, and the treatment effect.

The yield of screening depends on a number of factors. Screening targeted to populations at risk for diabetes would likely increase the yield and efficiency of a screening program; a variety of risk scores have been developed to identify those at high risk for developing diabetes.^150,^ ^224^–^228^ In the DPP, older age and higher BMI increased the yield of screening, and this was true across ethnic groups.^145^ On the other hand, the prevalence of diagnosed DM2 in certain high-risk groups such as non-Hispanic blacks and Mexican Americans has increased, while the proportion of those with undiagnosed disease in those groups has fallen, suggesting that opportunistic screening targeted to populations at high risk may already be occurring. This trend reduces the prevalence of undiagnosed DM2 and increases the NNS to prevent adverse events in the remaining unscreened group.^2^

## Targeting Persons at High-risk for Complications from Diabetes

The yield of screening for diabetes and prediabetes is likely to increase if targeted towards groups at higher risk of complications from diabetes. As noted previously,^76^ interventions that target cardiovascular events produce greater effects than those targeting microvascular complications which occur later in the disease process.

### Would the diagnosis of diabetes or prediabetes identify individuals who would benefit from aggressive macrovascular risk reduction strategies and who would not have been otherwise identified through hypertension and hyperlipidemia screening protocols, based on current recommendations?^75^

The current USPSTF guidelines recommend screening for diabetes in persons with hypertension or hyperlipidemia. The USPSTF also recommends screening all adults for hypertension, and recommends hyperlipidemia screening in males over age 35, females over age 45 and younger individuals with additional cardiovascular disease risk factors.^75^ If a subgroup of persons with diabetes or prediabetes derives benefit from antihypertensive, lipid-lowering, aspirin, glycemic control treatment, or lifestyle interventions, and these people would not have been detected by hypertension or hyperlipidemia screening, or because of hyperglycemia symptoms, then there might be a rationale for screening a larger group of individuals.

The presence of hyperlipidemia as defined by high LDL levels does not clearly identify those who would benefit from lipid-lowering treatment, as persons with high triglyceride or low HDL levels also benefit. In the HPS, persons with diabetes benefited from lipid-lowering treatment regardless of initial LDL level.^95^ A large primary prevention trial using fixed-dose atorvastatin compared with placebo (the Collaborative Atorvastatin Diabetes Study [CARDS] study)^229^ in persons with diabetes found significant reduction in cardiovascular events and stroke regardless of baseline LDL levels. (We excluded this study from our review given that it was not a newly-diagnosed population and there was no subgroup without diabetes to use to compare relative benefits of treatment.)

Many persons with diabetes are hypertensive and/or have additional cardiovascular disease risk factors and those with the highest cardiovascular risk profiles are likely to benefit most from treatment.^95,^ ^99,^ ^223,^ ^229,^ ^230^ It is therefore likely that many people with diabetes would have qualified for diabetes screening according to current USPSTF guidelines. The prevalence of diabetes among persons with average cardiovascular risk and no history of hypertension or dyslipidemia is unclear. A general population screening study found that screening persons simply on the basis of an age over 45 years was of very low yield, and nearly three-quarters of those found to have DM2 had a history of hypertension or were hyperlipidemic.^45^

There is good evidence that persons with diabetes and hypertension benefit from aggressive blood pressure lowering.^94^ There is therefore a reasonable rationale for screening hypertensive individuals for diabetes since this might alert physicians to aim for lower blood pressure targets. There was a significant risk reduction in cardiovascular events in the diabetic group assigned to the lowest blood pressure target, and the mean achieved blood pressure in that group was 135/81 mmHg. So, in defining hypertension for the purposes of screening, one could consider 135/80 as a threshold that should prompt screening.

Prediabetes populations are heterogeneous, with variation in cardiovascular disease risk and in the pathway and ultimate progression to DM2; those with IGT likely have an elevated risk of cardiovascular disease.^25,^ ^26,^ ^231,^ ^232^ Lifestyle intervention can improve cardiovascular risk profiles in prediabetic individuals, but there is currently little evidence demonstrating a reduction in health outcomes.^138,^ ^140,^ ^233^

Older individuals with diabetes are at substantial risk for cardiovascular disease, and likely do derive some benefit from cardiovascular risk reduction, but it is not clear that the diagnosis of diabetes would significantly alter the approach to treatment in these individuals.^94,^ ^95,^ ^234^ The role of tight glycemic control in older adults with diabetes is unclear. Given the relatively long duration of follow-up required to derive benefit from tight glycemic control and the exclusion of persons with limited life expectancy from many of the trials discussed herein, the implications of the diagnosis of diabetes in those with limited life expectancy is uncertain.

The possibility exists of a “legacy effect” of an early, aggressive glycemic control strategy in persons with diabetes whereby early initial aggressive management can produce improvements in clinical outcomes after many years of follow-up.^235^ The largest study of an initial strategy of sustained tight glycemic control in type 1 diabetes^236^ recently published an extension study with 17 years of follow-up accrued, and the results suggest that participants originally randomized to a tight glycemic control strategy experienced a significant reduction in cardiovascular events at long-term follow-up, despite similar glycemic control in the intervention and control groups during post-randomization follow-up.^237^ However, there is, as yet no evidence confirming this in persons with DM2. The UKPDS followed persons with diabetes for an average of 10 years, but more substantial benefit in cardiovascular outcomes may require an even longer follow-up period.

In persons with prediabetes, longer-term follow-up of the Finnish Diabetes Prevention Study revealed a significant, sustained relative risk reduction in diabetes incidence of 36%.^153^ It is unclear from these data whether the sustained reduction in diabetes incidence was due to maintenance of lifestyle changes in the intervention group or the “legacy effect” from the intervention period itself.

## Harms of Screening

The potential yield of diabetes and prediabetes screening must be weighed carefully against the potential harms of screening and diagnosis. We did not identify evidence suggesting serious adverse effects of a new diagnosis of DM2 achieved via screening. The literature does, however, have significant limitations. Included studies examined persons at high risk of developing diabetes, and thus the results may not be applicable to mass screening programs which are not targeted.^178^–^180^ There are other theoretic concerns with screening such as the effects of labeling^238^ and the financial and insurance ramifications of a new diagnosis, but to date there is not sufficient evidence to support or refute these concerns.

## Limitations

As there is very little direct evidence on the benefits of screening interventions for DM2, we reviewed and synthesized indirect evidence: treatment interventions for persons with newly-diagnosed DM2, comparisons of treatments between persons with and without diabetes, and modeling studies. There are a number of important limitations inherent in using indirect evidence.

We restricted our review of treatment for diabetes to studies with mean diabetes duration one year or less, as we felt that these populations would most closely resemble screen-detected populations. Since the natural history of diabetes and the progression from prediabetes to asymptomatic diabetes to diagnosed disease is not completely elucidated and there may be much variability, it remains unclear whether this restriction is valid. Individuals with long-standing DM2 (and more microvascular and macrovascular disease) will likely show greater benefits from treatment. Limiting applicable evidence on DM2 treatment to early disease only will shed a less favorable light on the effectiveness of treatment (and therefore screening) interventions. For studies comparing a given treatment among persons with and without DM2, we included studies with any duration of disease, and the applicability of these data to populations with screen-detected disease is uncertain.

Attempts to divide diagnosed patients into those with a “clinical diagnosis” based on symptoms, and those deemed to be “screened” due to alleged asymptomatic status do not truly compare “screened” to “not screened” patients, limiting the conclusions that can be drawn from comparisons between these two groups. However, studies such as the in-progress ADDITION study^88^ and the Hoorn study^41^ do provide useful data on risk profiles and outcomes with early treatment, particularly in view of the infeasibility of a trial randomizing persons to screening or no screening and following for long-term health outcomes. Also, as discussed above, given current opportunistic screening practices targeting high-risk groups and the ubiquity of glucose measurements in lab batteries drawn for other reasons (e.g., chemistry panels), the construct of clinical diagnosis versus screening asymptomatic individuals may not reflect true current practice.

Most of the data on diabetes treatment were from prespecified subgroup analyses of large trials which included both diabetic and nondiabetic populations. As discussed above, there are clear and important differences between the diabetes and non-diabetes subgroups, and the subgroup analyses were often underpowered to demonstrate significant changes in primary outcomes. Prevention trials among persons with prediabetes were powered to examine the primary outcome of new cases of DM2, and not to examine long-term health outcomes such as cardiovascular events.

Modeling studies can provide important insights into potential benefits, harms, and costs of screening and treatment interventions at the individual or population level. Models rely on data from observational studies and trials, and are only as good as the data and assumptions underlying them. All six models that we identified that examined the effect of screening interventions^13,^ ^43,^ ^87,^ ^90^–^92^ lack transparency to some degree, and all have had one or more of their important underlying assumptions criticized.^13^

## Emerging Issues/Next Steps

The ADDITION study^88^ should be available in 2010 and will provide important data on the effectiveness of treatment of screen-detected DM2 populations on long-term health outcomes.

## Future Research

The progression from normoglycemia to DM2 is complex and varied. Further research is needed to define the duration of the prediabetes phase and identify measurable risk factors for progression to DM2 and its complications. The relative roles of IFG versus IGT as cardiovascular risk factors need further delineation. It may be possible to stratify persons with prediabetes based on glycemia or other characteristics (e.g., visceral fat distribution) that might be helpful in identifying subpopulations, which would benefit most from the identification of prediabetes.

Diabetes prevention studies have primarily focused on IGT, a population that is not picked up by fasting plasma glucose, the currently recommended DM2 screening test.^46^ In addition, only 24% of persons with prediabetes have IFG,^239^ and IGT may be more predictive of mortality.^21^ Thus further research is needed to determine optimal approaches to identifying persons at high risk for cardiovascular events, given that the OGTT is infeasible as a universal screening test.

Further research examining lifestyle interventions which link sustainable improvements in insulin resistance to other cardiovascular risk factors, and improvements in pancreatic beta cell function to improvements in health outcomes in real-world settings would be useful in determining the long-term utility of screening for prediabetes, particularly in view of the low risk of adverse effects from lifestyle interventions.

The cost-effectiveness of diabetes screening programs is considered to be mainly determined by the long-term health benefits rather than the cost of detection and treatment of diabetes.^240^ Thus, long-term, sustainable interventions which impact health outcomes, and with a low risk of harms, need to continue to be the focus of intervention research. Further work is needed to examine the psychological and labeling effects of both the screening procedure and a new diagnosis of prediabetes or DM2. It is unclear what effect screening and diagnosis have on important determinants of behavior and health, such as self-efficacy and motivation for lifestyle change, intermediate outcomes, such as weight and physical activity, as well as long-term health outcomes. Persons with newly-diagnosed diabetes may adapt to their disease over time, and it is important to understand if screen-detected persons adapt over time also.

Given the burden of cardiovascular morbidity and mortality among persons with diabetes, as well as the uncertainty in assessing true cardiovascular risk among persons with diabetes, future studies might compare cardiovascular event rates among different subgroups of persons with diabetes. Screening protocols targeted to different risk factors (i.e., risk for diabetes diagnosis versus overall cardiovascular risk) should be examined and compared. Specifically, it would be useful to know if cardiovascular risk factors other than hypertension or hyperlipidemia identify persons with diabetes who might benefit from early identification and treatment.

Further modeling studies would be helpful if they examined the effect of screening targeted to persons with cardiovascular risk factors in addition to hypertension. As data become available, existing, high-quality models need to be updated and underlying assumptions reexamined. Modeling studies may also be useful to examine demographic subgroups such as racial and ethnic minorities, as well as re-screening intervals and optimal screening ages.

## Conclusions

The Summary of Evidence Table (Table 11) shows summarized evidence per Key Question. There are no RCTs examining the effectiveness of a screening program for DM2. The only direct evidence is a small, case-control study, which did not suggest a benefit from screening when microvascular complications were considered.^84^ The ADDITION study,^88^ which is currently in progress, may shed light on the long-term health outcomes of screen-detected DM2. Modeling studies suggest that screening for DM2 may be relatively cost-effective when macrovascular benefits of optimal blood pressure control are taken into account, and older persons may benefit more than younger age groups. The available evidence suggests that there are no serious adverse effects of a new diagnosis of DM2 achieved via screening.

There is clear evidence that intensive lifestyle interventions and some pharmacotherapies can decrease the incidence or delay the onset of diabetes up to 7 years. There is, however, no direct evidence that screening for prediabetes and intervening in screened-positive persons has health benefits compared to waiting to intervene at the time of clinical diagnosis. Several recent studies report cardiovascular outcomes, but these studies were either not powered to examine these outcomes, or they had other methodological limitations.

Cardiovascular events are the most frequent cause of morbidity and mortality in persons with diabetes; and elevated risk for cardiovascular events may occur early on, extending into the prediabetic period. It is not clear to what degree diabetes reflects atherogenic risk in persons with few other traditional risk factors. It is also not clear how to approach individuals with only borderline traditional risk factors, e.g., borderline hypertension or mildly elevated LDL levels (such as 120 mg/dl), and whether diabetes substantially elevates cardiovascular risk in these individuals. It is likely that there are diabetes subgroups that have a propensity towards atherosclerosis, while others have a more benign form of the disease. Future research should investigate screening algorithms incorporating such information that may identify and target more aggressive follow-up and treatment for those persons with DM2 with the highest cardiovascular risk.