# Results

See Appendix C6 for a literature flow diagram stratified by Key Question; excluded studies are catalogued in Appendix C7.

## Update Key Question 1. Is there direct evidence that systematic screening for type 2 diabetes, IFG, or IGT among asymptomatic adults over 20 years of age at high-risk for diabetes complications improves health outcomes? Does it improve health outcomes for asymptomatic individuals at average-risk for diabetes complications?

### Summary of Findings

There are no RCTs examining the effectiveness of a screening program for DM2. The prior review by Harris and colleagues ^40,^ ^76^ identified no direct evidence provided by studies of any design addressing screening effectiveness. For this updated review, we identified three studies addressing this question. A small, case-control study did not find benefit from screening when microvascular complications were considered. ^84^ In a cross-sectional study, the prevalence of visual impairment and blindness was no greater in a population that had been screened for DM2 and for diabetic eye disease than in a matched, non-diabetic group. ^85^ In a poor-quality, cross-sectional study, ^86^ the prevalence of diabetic retinopathy was similar in persons with newly-diagnosed DM2 via a community screening program, and persons newly-diagnosed in general practice. The limited data from these studies do not provide sufficient direct evidence of the effectiveness of screening for DM2 in either targeted or general populations.

Recent high-quality modeling studies ^13,^ ^87^ suggest that targeted screening for DM2 among persons with hypertension may be relatively cost-effective when macrovascular benefits of optimal blood pressure control are taken into account; also older persons benefit more than younger age groups. Waugh and colleagues also suggest that screening is more cost-effective among obese persons. ^13^

The Anglo-Danish-Dutch Study of Intensive Treatment in People with Screen Detected Diabetes in Primary Care (ADDITION) study, ^88^ currently in progress, may shed light on differences in baseline characteristics and long-term health outcomes between persons with screen-detected DM2 and those who present with symptoms.

### Study Details

To our knowledge, the effectiveness of a screening intervention for DM2 has not been tested to date in an RCT. In the ideal study, a population without diabetes or prediabetes would be randomized to either a screening intervention for DM2 or prediabetes, or to no intervention with usual care, when an individual presented with DM2. The screened population would be managed with usual care if they screened positive either for DM2 or prediabetes, and subjects would be followed for their lifetime for health outcomes. Such a study will not likely ever be performed because a large number of participants would have to be followed for long periods of time; case-finding and opportunistic screening for prediabetes and diabetes occur frequently in practice, using various diabetes risk factors for assessment; and laboratory panels, which include a plasma glucose, are commonly performed.

In the absence of trial data, we are left to consider: 1) direct evidence from studies comparing screening to no screening, but which are not RCTs; and 2) indirect evidence which examines various aspects of the relationship between screening and health outcomes. Key Questions 2 through 5 address various facets of the indirect evidence. Three studies in this updated review provide some direct evidence of the effects of a screening intervention on health outcomes; however, these data were not sufficient to determine the effect of screening directly.

A fair-quality, case-control study examined 303 cases of DM2 with one or more symptomatic, microvascular, diabetic complications matched 1:1 to control subjects (with or without DM2) (see Appendix B3 for study details). ^84^ The adjusted odds ratio (OR) for a history of screening at least once over a 10-year period compared to no screening, was 0.87 (95% confidence interval [CI], 0.38 – 1.98), suggesting that screening does not significantly reduce the risk of certain microvascular diabetic complications. The CI was wide, however, and was also consistent with a modest benefit.

In a Swedish community where systematic screening has occurred since 1983, Olafsdottir and colleagues ^85^ compared visual acuity and blindness in persons with known DM2 to vision in age- and sex-matched controls without diabetes, obtained from a national register. No significant differences were noted between these two populations in most measures of visual acuity, although more control subjects had visual acuity ≥ 1.0 (optimal vision) (p<0.05) (classification of the Los Angeles Latino Eye Study.) ^89^ Thus, in a population that had been screened for DM2 and for diabetic eye disease, the prevalence of visual impairment and blindness was no greater than in a matched, non-diabetic group. It was unclear in this study, however, how many subjects in the diabetes group were screen-detected versus presented with clinical symptoms, and the mean duration of known diabetes was 9 years. Given the presence of registries and an interest in diabetes in this community, standards of care for diabetes and diabetic eye disease may have been quite high. Thus, it is not possible to separate out the effects of DM2 screening specifically on the favorable eye outcomes.

In a poor-quality, cross-sectional study in rural and urban India, ^86^ diabetic retinopathy rates were compared between persons with newly-diagnosed DM2 via a community screening program who presented for retinopathy screening (n=173), and persons newly-diagnosed in general practice, who also presented for retinopathy screening (n=128). No significant differences were noted between the two groups in the prevalence of diabetic retinopathy, including sight-threatening retinopathy. Rates of retinopathy screening were only 15% for persons screened positive for DM2 in the community and were not reported for the subjects in the general practices. Thus, it is not possible to determine whether subjects examined in this study were representative of persons with newly-diagnosed DM2 in Indian communities, and these data are unlikely to be applicable to US populations and health care settings.

The in-progress ADDITION study ^88^ will provide important data on the effectiveness of treating persons with screen-detected diabetes (see Appendix B4 for details). In the first phase of the study, either targeted or community-based DM2 screening (depending on the location) will be performed, and the various outcomes examined among screen-detected persons include: cardiovascular risk profiles, psychological status, metabolic status, and costs. In the treatment phase of the study, persons with DM2 identified in the screening study will be randomized to conventional therapy or intensive multifactorial treatment focused on glycemic control and cardiovascular risk reduction, including aggressive blood pressure and lipid management. Primary endpoints at 5-year follow-up include mortality, cardiovascular events, and other health outcomes. This study is expected to be completed in 2009 (personal communication, Dr. T. Lauritzen, 1/26/07).

#### Modeling studies of screening interventions

In view of the paucity of data on the effectiveness of DM2 screening programs, we searched for studies modeling screening interventions using various simulation techniques. Models examining effectiveness and economic efficiency have been developed over the last 10 years. We identified seven studies modeling the effects of diabetes screening interventions, ^13,^ ^43,^ ^87,^ ^90^ – ^93^ as well as a systematic review ^13^ (see Table 2; Appendix B5.) Modeling studies were not considered previously in the review by Harris and colleagues. ^76^ Modeling has also been used to examine the effectiveness of treatment of prediabetes and diabetes. Those studies will be discussed under Key Questions 2 and 3.

A recent HTA ^13^ systematically reviewed studies of economic models for screening for DM2 and prediabetes, and concluded that a good case could be made for targeted screening for both DM2 and IGT. Waugh et al suggest first an assessment of risk based on age, weight, and hypertension, followed by a test of blood glucose, either fasting plasma glucose, OGTT or A1c, as none of these tests is ideal. They base their conclusions on the widespread availability of relatively inexpensive, effective prevention strategies for cardiovascular disease, particularly statins. Waugh et al concluded that targeted screening for DM2 is relatively cost-effective and they suggest that economic models to date may have underestimated long-term health benefits by not fully taking into account the effects of lifestyle interventions on reductions in various cardiovascular risk factors.

The first major publication of an economic model of diabetes screening was published by The Diabetes Cost-effectiveness Group at the Centers for Disease Control and Prevention (CDC), who developed a Monte Carlo simulation model to examine the effectiveness of a screening intervention ^90^ from the perspective of the health care system. The CDC group concluded that one-time opportunistic screening during a regular physician visit for persons 25 years of age or older produced significant gains in QALYs: 0.08 years all ages combined; 0.35 years for persons aged 25 to 34 years, with progressively fewer QALYs gained for each increased age grouping (e.g., 0.01 years for persons 65 years of age or older). The incremental gains in life-expectancy were higher for African Americans for all age groups. The cost per QALY was also lowest in the youngest age group and rose consistently with each decade of age, ranging from $56,649 per QALY for persons 25 to 34 years of age to $116,908 per QALY for persons 65 years of age and older. The screening intervention was more cost-effective in the younger population as they gained more life-years free of complications, despite higher screening costs per case detected.

This original CDC model ^90^ has become outdated; this model did not examine the effects of blood pressure or lipid control on life expectancy. Nor did the model examine the macrovascular effects of earlier glycemic control, as data to support that relationship were not available at the time of the publication (1998). This model has also been criticized for lack of transparency of some of the model components and assumptions, and for limited sensitivity analyses. ^13^

Goyder and Irwig ^91^ developed a decision analysis of a mass screening intervention and included both microvascular and macrovascular complications for treatment and outcomes. They concluded that benefits of screening outweigh harms by 10 QALYs for every 10,000 persons screened. They did not include economic data, however, and this model has been criticized for not being transparent, for inadequate justification of assumptions, and a there is no reporting of validation of the model. ^13^

Using a Markov model, Hofer and colleagues ^92^ examined a hypothetical American population with recent-onset DM2 under various scenarios. They found that with perfect screening (diagnosis at the onset of disease), and idealized treatment (A1c never rises above 9.0%), the rate of blindness was reduced by 71% compared to usual case-finding in a homogeneous population of persons with DM2-onset over age 40 years and A1c ≥ 12.0%. In a population of 1,000 persons with DM2 representative of an American population, the total benefit of universal screening and ideal treatment would be a reduction of about 30,000 cases of blindness. Screening would confer 7% of the benefit and improved treatment an additional 65%.

Chen and colleagues ^43^ developed a Markov Monte Carlo simulation model to examine cost-effectiveness of mass screening of a hypothetical Taiwanese population at 2- and 5-year intervals. They found that microvascular complications were reduced equally for the 2- and 5-year screening groups compared to the control group. The incremental costs per QALY were higher with screening every 2 years, compared to a 5-year interval. These authors concluded that mass screening was relatively cost-effective compared to opportunistic screening and to other commonly-implemented screening interventions. This model lacks transparency as presented in this publication: no sensitivity analyses were conducted, and macrovascular disease was not considered. ^43^

Both macrovascular and microvascular complications were included in a more recent Markov model, ^87^ using data from the Hypertension Optimal Treatment (HOT) trial ^94^ which demonstrated that lower blood pressure targets improved cardiovascular outcomes among persons with DM2 and hypertension, as well as United Kingdom Prospective Diabetes Study (UKPDS) data ^90^ on the effects of intensive blood glucose control on microvascular complications. In this model diabetes screening targeted to persons with hypertension was more cost-effective than universal screening, and both targeted and universal screening of older persons were more cost-effective than screening of younger persons. For example, the cost per QALY compared to no screening for a 55 year old was $34,375 for targeted screening and $62,934 for universal screening. Most of the benefit of screening came from reducing coronary heart disease events by intensive control of hypertension, rather than from reducing microvascular complications. This model is an important advance on the prior modeling studies, incorporating data on glycemic control in DM2 from the UKPDS ^90^ and on intensive blood pressure control. ^94^ The model parameters were relatively transparent and adequately justified, although the model assumed 100% adherence and follow-up. ^13^

Glumer and colleagues ^93^ modeled the effects of treatment for hyperglycemia, hypertension, and dyslipidemia combined, in screen-detected persons on cardiovascular events over 5 years. In their least conservative model with low costs and multiplicative risk reduction for combined treatments, the cost per event prevented was between £23,000 and £82,000. These authors noted that their model was most sensitive to assumptions about the effects of treatment and less sensitive to population characteristics.

The recent HTA of screening for DM2 ^13^ reported their own model of the cost-effectiveness of screening, developed for United Kingdom populations. This transitional probabilities model based on UKPDS data suggests that screening for DM2 is relatively cost-effective for individuals 40 to 70 years of age, with a cost per QALY of £2,266 compared to no screening for the base-case population 40 to 70 years of age. This low cost-effectiveness ratio was due to both cost reductions and QALYs gained from reductions in complications, largely from fewer cardiovascular events due to statin use and fewer microvascular complications. Screening was somewhat more cost-effective in the older age groups (among persons 60 to 69 years of age, the incremental cost per QALY was £1,152) and in hypertensive and obese subgroups. Cost-effectiveness was determined more by assumptions about the degree of glycemic control, the effectiveness of other treatments on cardiovascular risk, and the low cost of statins, than by assumptions about the screening program.

## Update Key Question 2. Does beginning treatment of type 2 diabetes early as a result of screening provide an incremental benefit in health outcomes compared with initiating treatment after clinical diagnosis?

### Summary of Findings

We identified no studies that directly explored this question by comparing treatment effects between persons with screen-detected and clinically-detected diabetes, nor did we identify studies reporting treatment effects in an exclusively screen-detected diabetes cohort. Due to the absence of direct evidence, we examined studies of populations with mean duration of diabetes less than or equal to one year, as well as studies comparing treatment effects in diabetic versus nondiabetic populations.

There were no new completed studies examining the effect of glycemic control strategies in persons with newly diagnosed DM2 since the prior review. There is no clear evidence that persons with diabetes detected by screening would respond differently to specific antihypertensive regimens compared to persons without diabetes, though methodologic issues limit the robustness of this conclusion. Studies of intensive lipid-lowering treatment in persons with and without diabetes suggest that persons with diabetes benefit to a similar extent as those without DM2. The results are largely driven by one study in which the subgroup of persons with diabetes, regardless of initial low-density lipoprotein (LDL) cholesterol, benefited significantly from lipid-lowering treatment despite a lesser cardiovascular risk profile than the subgroup of persons without diabetes, many of whom had known coronary heart disease. ^95^ The studies of aspirin for primary prevention of cardiovascular events suggest that aspirin may not reduce the risk of myocardial infarction in persons with diabetes, but aspirin does seem to lower the risk of ischemic stroke in women with diabetes. ^96,^ ^97^

Modeling of diabetes interventions is a relatively young field and models vary in their perspectives, methods, and results. Three models suggest that aggressive blood pressure, lipid, and glycemic control may be effective and relatively cost-effective. However, their assumptions are all based on data from trials which included both clinically- and screen-detected persons with diabetes, and thus these models do not directly address the question of the cost-effectiveness of screening.

### Study Details

Two types of evidence address the question of whether early treatment benefits screen-detected persons with DM2. (See Appendices B6 and B7 for details).

#### Does initiating treatment of diabetes, diabetes-complications, and cardiovascular disease risk factors in patients with newly-diagnosed DM2 improve health outcomes compared to treating clinically-detected patients?

No study has prospectively compared treatment effects between persons with screen-detected diabetes (either through mass or opportunistic screening) and those who were diagnosed after presenting with symptoms of hyperglycemia or with a diabetes-related complication (e.g., symptomatic ischemic heart disease, infected foot ulcer). The results of the ADDITION study, ^88^ discussed above, should help inform the question of the effectiveness of treatment for screen-detected persons with DM2.

We identified no new cardiovascular risk reduction studies which included persons newly diagnosed with diabetes. We examined a recent, high-quality systematic review of disease management interventions which included 66 studies, only one of which met our inclusion criteria. Most studies examined only intermediate outcomes or included persons with long-standing diabetes. The single relevant study randomized persons with screen-detected diabetes to usual care or a structured care intervention (a combination of scheduled chronic care visits, provider education, registry reports, and patient education) and found no significant difference in final health outcomes between the two groups. ^98^

#### Would knowledge of a diabetes diagnosis prompt a change in management?

Tight glycemic control. There have been no new trials in persons with DM2 examining the effects of tight glycemic control. As discussed in the last review, ^76^ the UKPDS is the largest and most influential trial of tight glycemic control in persons with newly diagnosed DM2. The study provided some evidence that tight glycemic control was associated with a 25% reduction in microvascular complications - mostly due to a reduction in need for retinal photocoagulation - as well as a trend towards reduced cardiovascular events in obese persons with diabetes. ^99^ Intensive glucose control was not associated with high rates of hypoglycemia. ^100^ A recent meta-analysis combined results from older trials examined in the last USPSTF review ^40,^ ^76^ and concluded that tight glycemic control resulted in a modest reduction of macrovascular events in persons with DM2. ^37^ This result was mainly driven by a reduction in peripheral vascular and cerebrovascular events, though examination of the individual trials showed largely nonsignificant results. It was unclear how overlapping populations from the UKPDS were accounted for in this meta-analysis.

It is unlikely that firm evidence of the final health benefits of early glycemic control from a controlled trial of a screen-detected population will ever be available because it would be unethical not to treat persons with known diabetes. ^101^ The ADDITION study should provide some valuable information, although the comparison group will be receiving usual care including glycemic control strategies; it will therefore be assessing the incremental benefit of very aggressive glycemic control over current standards for glycemic control in a screened population.

Similarly, the Action to Control Cardiovascular Risk in Diabetes (ACCORD) study, also in progress, will compare intensive glycemic control strategies to more moderate glycemic targets (target A1c 6.0% vs 7.0 – 7.9%), though not specifically in a screened population (the average duration of diabetes in the trial population remains unclear). ^102^

Specific antihypertensive treatment. Since the prior review, there were no new studies involving antihypertensive agents in screen-detected individuals, however we identified two new trials ^103,^ ^104^ comparing the effect of different antihypertensive regimens in persons with and without diabetes (see Table 3), and one trial discussed in the previous report. ^105,^ ^106^

None of the comparative effectiveness trials suggested that persons with diabetes would clearly benefit from a specific antihypertensive drug compared to those without diabetes. However, none of the studies was originally powered to detect differences between the diabetes and non-diabetes subgroups. Furthermore, the demographic and cardiovascular risk profile characteristics were significantly different between the diabetes and non-diabetes subgroups, so it is unclear whether persons with diabetes with similar cardiovascular risk profiles as the overall trial population would experience differing treatment effects.

The largest of these trials was the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT) study ^103^ which included over 15,000 persons with diabetes. Overall, this fair-quality study did not provide evidence that persons with diabetes would benefit from a particular antihypertensive drug more so than persons without diabetes. There were inconsistent and relatively small differences noted among the multiple treatment comparisons made across several subgroups. The lower risk of heart failure among those assigned to chlorthalidone was the only outcome that approached consistency across glycemic strata. ^103^ This study did not plan for a diabetes subgroup analysis a priori, so the study may have been underpowered to detect significant differences according to diabetes status. Moreover, the achieved systolic blood pressure at 5-year follow-up was significantly higher in those assigned to lisinopril than either amlodipine or chlorthalidone (137.9 mm Hg, 136.3 mm Hg, and 135.0 mmHg, respectively) in the diabetes subgroup.

The Losartan Intervention for Endpoint Reduction Trial (LIFE) study, covered in the previous review, which included persons with hypertension and left ventricular hypertrophy, showed persons with diabetes had lower cardiovascular mortality with losartan compared to atenolol, whereas those without diabetes experienced a reduction in stroke with losartan compared to atenolol. ^105,^ ^106^ The Controlled Onset Verapamil Investigation of Cardiovascular Endpoints Trial (CONVINCE) trial compared verapamil to either a beta-blocker or thiazide diuretic-based regimen; there was no evidence of differential effect of treatment on cardiovascular outcomes between those with and without diabetes. ^104^

We identified one meta-analysis of antihypertensive trials which compared outcomes between persons with and without diabetes. ^107^ Angiotensin-receptor blockers (ARBs) provided greater protection against congestive heart failure for those with diabetes than those without diabetes (p=0.002). Angiotensin converting enzyme (ACE) inhibitors seemed to offer more protection against cardiovascular death (p=0.05) and total mortality (p=0.03) for those with diabetes than without diabetes. However, all of the studies of ACE inhibitors compared to placebo were secondary prevention trials, except for the Heart Outcomes Prevention Evaluation (HOPE) trial, which was a combination of primary and secondary prevention.

The HOPE trial, discussed in the last review, did show that those with DM2 and one additional cardiovascular risk factor experienced a 25% risk reduction in cardiovascular events, cardiovascular mortality, and stroke with ramipril treatment - a similar benefit as those with a history of ischemic heart disease and no diabetes. Of interest, those with diet-controlled diabetes seemed to derive a more substantial benefit from ramipril than those on insulin, perhaps suggesting those with less advanced diabetes benefited more from treatment, although this conclusion was made in the context of multiple comparisons. ^108,^ ^109^

Of note, we excluded from our review two large RCTs published in 2001 which examined the role of the ARBs losartan and irbesartan in slowing progression of nephropathy in patients with DM2. ^110,^ ^111^ There was a 25–33% risk reduction in the doubling of the serum creatinine, and losartan was associated with a 28% risk reduction in the incidence of end-stage renal disease. Both trials were excluded because they enrolled persons with advanced diabetes and nephropathy at baseline and, therefore, did not address the issue of the benefits of early detection and treatment of diabetes.

Intensity of antihypertensive treatment. The previous USPSTF review ^40,^ ^76^ found good evidence that aggressive blood pressure control in persons with diabetes reduces cardiovascular morbidity. The most influential study was the HOT trial in which the diabetes subgroup experienced a 51% relative risk reduction in cardiovascular events from more aggressive blood pressure control, a greater benefit than observed for non-diabetic patients. ^94^

We did not find any new trials comparing intensive and less intensive blood pressure treatment targets in persons with and without diabetes. A recent meta-analysis presented limited evidence that higher intensity antihypertensive treatment reduces the risk of major cardiovascular events in persons with diabetes, but not in those without diabetes. ^107^ The differential effect on cardiovascular mortality was less clear. The four studies contributing to the diabetes subgroup meta-analysis were all reported in the last review. ^94,^ ^112^ – ^114^

The ACCORD trial, as described above, will also examine the relative benefits of very intensive blood pressure control as compared to more moderate standards (target systolic blood pressure < 120 mmHg vs < 140 mmHg). ^102^

Initiation of lipid-lowering treatment. At the time of the last review, there were no primary prevention trials with large numbers of participants with diabetes yet published. Secondary prevention trials including persons with diabetes and coronary heart disease had shown risk reductions ranging 19–42% in the incidence of recurrent cardiovascular events.

We identified four new trials and one meta-analysis examining the effects of lipid-lowering treatment in persons with and without diabetes (see Table 4). All of the trials examined the efficacy of HMG CoA reductase inhibitors in primary prevention of cardiovascular events and mortality. In one of the trials, neither the diabetes nor the non-diabetes subgroups benefited from statin treatment, but there was a high rate of non-study statin use in the control group, and the differential reductions in LDL cholesterol achieved were relatively small. ^115^ In two fair-quality trials, statin therapy did not significantly reduce the primary endpoint (coronary events in the Anglo-Scandinavian Cardiac Outcomes Trial [ASCOT] trial and coronary events plus stroke in the Prospective Study of Pravastatin in the Elderly at Risk [PROSPER] trial) in the diabetes subgroup, but did benefit the non-diabetes subgroup. ^116^ – ^118^ Comparisons between persons with and without diabetes were hampered by a relatively low absolute number of events in the diabetes subgroup. The findings of the PROSPER study, which showed a trend towards increased risk of coronary events and stroke in the statin group amongst persons with diabetes, are puzzling, but this study also had the lowest number of persons with diabetes. ^117^

The Heart Protection Study (HPS) ^95^ was a large, good-quality RCT examining the efficacy of an HMG CoA reductase inhibitor in primary and secondary prevention of cardiovascular events and mortality. Persons with diabetes and without a history of vascular disease experienced a similar reduction in cardiovascular events as persons without diabetes who had known vascular disease (27% relative risk reduction, p <0.001 in both groups). A detailed subgroup analysis of the 5,963 persons with diabetes revealed that risk reduction was similar among various subgroups, regardless of duration of diabetes, presence of treated hypertension, or initial LDL cholesterol. Although it appeared that persons with shorter diabetes duration benefited to a similar extent as those with much longer standing diabetes, there was not sufficient power to determine if newly-diagnosed (i.e., less than 1 year) participants benefited to a significant extent.

A recent meta-analysis included six primary prevention trials, including the four discussed above along with an older trial using a fibric acid derivative and an older statin trial which reported analyses of the subgroup of participants with diabetes. ^119^ Overall, lipid lowering drug treatment appeared to be equally efficacious in persons with and without diabetes. However, there was significant heterogeneity among the trials. The HPS contributed the largest number of persons with diabetes to the analysis, and also yielded the highest risk reduction. ^95^ Of note, the risk difference was significantly higher in secondary prevention trials, likely reflecting the much higher event rates. Excluding the fibrate trial yielded an almost identical risk reduction to the overall effect of the six studies, likely reflecting the very small number of persons with diabetes in fibrate trial.

Aspirin for primary prevention. The last review included a large meta-analysis of aspirin use in the prevention of cardiovascular events and stroke in high-risk patients, including over 5,000 persons with diabetes. This Antithrombotic Trialist's Collaborative meta-analysis showed a 7% risk reduction of borderline significance in the incidence of vascular events amongst diabetics. ^120^ The meta-analysis was mainly driven by the results of the Early Treatment Diabetic Retinopathy Study (ETDRS) trial which showed a 17% relative risk reduction in the incidence of fatal and non-fatal coronary events (95% CI, 0.66 – 1.04). ^121^ The Physicians Health Study showed that the use of aspirin was associated with a significant cardiovascular risk reduction in persons with diabetes. ^122^

Since the prior review, we identified two new studies of low-dose aspirin use for primary prevention of cardiovascular events in persons with and without diabetes. ^96,^ ^97^ In the Primary Prevention Study, the nondiabetes subgroup experienced a 41% relative risk reduction (95% CI, 0.37 – 0.94) in the incidence of major cardio- and cerebrovascular events, while the subgroup of persons with diabetes did not derive any benefit. ^96^ This fair-quality study was stopped early with a resultant low event rate in both groups. Given the small size of the groups with diabetes, the trial was likely underpowered to detect a difference in this group. Another large trial of good quality showed that aspirin did reduce the incidence of ischemic stroke in women with diabetes, ^97^ and there was no evidence that the effect of aspirin was significantly more pronounced in diabetic women than those without diabetes. The difference in results from the Primary Prevention Program ^96^ may be due to differences in the populations considered and perhaps in the differential risks for stroke versus myocardial infarction (the rate of stroke was actually higher than the rate of myocardial infarction in the Women's Health Study ^97^ ).

#### Modeling studies of treatment of diabetes

In addition to examining the effects of screening interventions, economic models have also been used to examine the effects of treatment of persons newly-diagnosed with DM2. ^123^ – ^126^ Several additional models are reported to be under development (The Cardiff Diabetes Model of newly-diagnosed type 2 patients and the Sheffield Diabetes Model). ^127^ The CDC Diabetes Cost-effectiveness Group estimated the incremental cost-effectiveness of intensive glycemic and blood pressure control as well as the use of pravastatin to reduce total cholesterol in persons newly-diagnosed with DM2. ^123^ This model assumed that intensified blood pressure control did not have an effect on coronary heart disease (based on UKPDS data ^112^ ). Intensive blood pressure control and reduction of serum cholesterol increased QALYs by more than intensive glycemic control (see Table 5 and Appendix B8). Blood pressure treatment was, in fact, cost saving.

In the Center for Outcomes Research (CORE) model, Palmer and colleagues ^124,^ ^128^ examined hypothetical interventions that led to 10% improvements in one or more of A1c, systolic blood pressure, total cholesterol, or HDL. The costs of interventions were not included in this model. They noted an increase in quality-adjusted life expectancy of 1.7 years with improvements in all four parameters, and the lifetime costs of complications decreased the most with improvements in all four. As a single intervention, costs improved the most with A1c improvement (costs decreased by $10,800).

The UKPDS Outcomes Model ^125,^ ^129^ – ^131^ examined the lifetime economic efficiency of intensive blood glucose control compared to conventional control, with metformin therapy given to a subgroup who were more than 120% of ideal body weight. This model found that the most QALYs gained were with metformin therapy and the probability of being cost-effective at a ceiling ratio of 20,000 pounds per QALY was also greatest with metformin therapy in the overweight subgroup. In a comparison of conventional glucose control versus intensive control with a sulphonylurea or insulin, ^132^ the incremental cost per event-free year gained was £1166.

The Global Diabetes Model examined the effects of intensive lipid management in a staff-model health maintenance organization but does not provide comparison data for persons without such treatment (the comparator was another model). ^126,^ ^133^

## Update Key Question 3. Does beginning treatment for IFG and/or IGT early as a result of screening provide an incremental benefit in final health outcomes compared with initiating treatment after clinical diagnosis of type 2 diabetes?

### Summary of Findings

A number of studies suggest that intensive lifestyle and various pharmacotherapeutic interventions decrease the incidence of DM2 over follow-up periods up to 7 years. There are few data on the prevention or delay of cardiovascular and other long-term health outcomes, including death. There are also very few data on treatments for cardiovascular risk factors among persons with prediabetes compared to normoglycemic populations. There is thus little direct evidence that identifying persons with prediabetes by screening will lead to long-term health benefits. Several high-quality modeling studies suggest that screening and treatment of prediabetes with a lifestyle intervention or metformin is relatively cost-effective, although the cost-effectiveness ratios vary widely depending on the assumptions used in the model.

### Study Details

Evidence addressing several different questions informs the issue of whether the identification of persons with either IFG or IGT provides long-term health benefits compared to waiting until clinical presentation of DM2.

#### Does initiating treatment of dysglycemia or other cardiovascular risk factors among persons with prediabetes improve health outcomes compared to treating clinically-detected or screen-detected DM2?

If treatment of persons with prediabetes reduces diabetes-related complications compared to waiting until the onset of DM2 (screen- or clinically-detected), this would suggest that identifying persons with prediabetes is beneficial. In the prior USPSTF review, Harris and colleagues ^40,^ ^76^ identified five trials ^134^ – ^138^ of lifestyle or drug interventions among persons with prediabetes, three of which reported a reduced incidence of DM2 between 42% and 58% over 3 to 6 years with an intensive lifestyle intervention compared to usual care. ^76^ None of these studies examined cardiovascular outcomes, however, and none compared the treatment of prediabetes to clinically-unscreened diabetes.

We identified additional data published since 2003 that examined the effect of interventions on the incidence of diabetes or on long-term health outcomes among persons with prediabetes (see Table 6 and Appendix B9). ^79^ – ^82,^ ^136,^ ^138^ – ^161^ Two of these studies were included in the prior report, with more recent data published on cardiovascular outcomes. ^140,^ ^159^ Two recent reviews examined the effectiveness of interventions to prevent or delay diabetes among persons with IGT; ^162,^ ^163^ all English-language studies included in that review, save one, are included in this report or in the prior review. ^76^ One study contained in the review by Gillies and colleagues was not reviewed in the prior USPSTF review: a small study by Wein and colleagues ^164^ who compared an intervention group given 3-monthly telephone contacts with a dietician to a comparison group that received routine dietary advice. In this study the intervention group had a nonsignificant decrease in the risk of diabetes. This intervention was much less intense than the interventions included in both this review and the prior one. ^76^

In the Diabetes Prevention Program (DPP) ^79^ an intensive lifestyle intervention and treatment with metformin both reduced the incidence of diabetes at 3-year follow-up. Neither the cumulative incidence of cardiovascular disease nor the event rate was different among treatment groups, however, the study was not adequately powered to examine these outcomes. ^140^ The DPP screened participants based on risk factors such as obesity, age, and family history and found that older age and higher BMI increased the yield of screening, and this was true across ethnic groups. ^145^

In the Study to Prevent Non-insulin-dependent Diabetes Mellitus (STOP-NIDDM) trial, subjects with IGT were randomized to placebo or acarbose. ^158^ The cumulative incidence of DM2 was reduced significantly over the 3.3-year intervention (HR 0.75 [95% CI, 0.63 – 0.90]). Cardiovascular events of any type were also reduced (HR 0.51 [95% CI, 0.28 – 0.95] with an absolute risk reduction [ARR] of 2.5%) as was the development of hypertension (HR 0.66 [95% CI, 0.48 –0.89] with an ARR of 5.3%). ^159^ The number-needed-to-treat to prevent one cardiovascular event in persons with IGT was 40 over 3.3 years. This study was limited by an attrition rate of 24% overall, with a much higher rate in the treatment group.

A third trial presented cardiovascular outcomes. In the DREAM trial, ^82^ the primary composite outcome of cardiovascular events was not significantly different between the rosiglitazone and placebo groups (HR 1.37, 95% CI, 0.97 – 1.94). Rosiglitazone reduced the incidence of DM2 among persons with IFG and/or IGT when treated for a median of 3 years. ^165^ Ramipril was not effective in reducing the incidence of DM2, although 2-hour post load plasma glucose was significantly lower in the ramipril group (p=0.001). ^82^

The Finnish Diabetes study, ^138^ included in the prior review, provided longer-term follow-up of a lifestyle intervention and found that the cumulative incidence of DM2 was significantly reduced at a mean follow-up of 3.2 years (HR 0.4 [95 % CI, 0.3 to 0.7; p<0.001]). ^153^ This was maintained 3 years after completion of the intervention (HR 0.57 [95% CI, 0.43 – 0.76]). ^153^

In addition, two smaller trials were identified which examined the effect of lifestyle and pharmacotherapy interventions on incidence rates of DM2 among persons with prediabetes, and found a significant decrease in incidence compared to usual care. ^81,^ ^154^ On the other hand in a third study, Watanabe and colleagues found no difference in diabetes incidence at 1 year with a dietary intervention, although the study was not powered for that outcome. ^155^ Pharmacotherapy has also been demonstrated to decrease progression to DM2. In the Xenical in the Prevention of Diabetes in Obese Subjects (XENDOS) study (rated fair-to-poor quality), orlistat produced a relative risk reduction in the incidence of DM2 of 45% over 4 years (although attrition rates were high) ^161^ and a meta-analysis of three other orlistat studies produced similar results. ^80^ Acarbose ^156^ and metformin ^154^ have also been shown to in decrease diabetes incidence at up to 3-year follow-up.

A pooled estimate for the relative risk reduction in the incidence of DM2 was 0.48 (95% CI, 0.40, 0.58). Pharmacotherapeutic interventions were heterogeneous (p-value- 0.001, Chi-square test for heterogeneity), with a pooled estimate of 0.65 (95% CI, 0.51, 0.83). Removal of the rosiglitazone arm of the DREAM trial ^82^ produced a homogeneous data (p>0.05, Chi-square test for heterogeneity) (see Figure 3).

Figure 3. Diabetes Incidence

We identified two studies of interventions in persons with prediabetes that are currently in progress and for which no published results are available. The Canadian Normoglycaemia Outcomes Evaluation (CANOE) trial ^166,^ ^167^ focuses primary on whether treatment with metformin plus rosiglitazone, combined with a healthy lifestyle, will prevent the development of DM2 among persons 30 to 75 years of age with IGT over 4-year follow-up.

The National Type 2 Diabetes Prevention Program in Finland (Fin-D2D) ^168^ involves strategies to screen high-risk persons for prediabetes and diabetes followed by appropriate lifestyle and clinical interventions if they screen positive. The goals are to reduce the incidence of DM2 and to identify persons with undiagnosed DM2.

#### Are there different treatment targets for cardiovascular disease risk factors (hyperlipidemia, blood pressure) for persons with prediabetes compared to normoglycemic persons?

We did not identify any data to address this question.

#### Are there different medications for the treatment of hyperlipidemia, hypertension, and cardiovascular disease among persons with prediabetes compared to normoglycemia?

The only comparative effectiveness study involving persons with prediabetes was the ALLHAT trial, ^103^ which compared various antihypertensive therapies among persons with diabetes, IFG, and normoglycemia. Overall, the authors concluded that they failed to demonstrate superiority for an ACE-inhibitor or a calcium channel blocker compared with a thiazide-type diuretic across the three glycemic strata for the composite outcome of coronary heart disease death and nonfatal myocardial infarction. In the setting of multiple comparisons, the relative risk of fatal coronary heart disease or non-fatal myocardial infarction was 1.73 (95% CI, 1.10 – 2.72) for participants assigned to amlodipine compared to chlorthalidone among persons with IFG; these drugs did not produce significant effects on this outcome among persons with DM2 or normoglycemia.

#### Modeling studies of treatment of prediabetes

Modeling studies have also been used to examine the treatment of prediabetes (see Table 7 and Appendix B10). ^128,^ ^169^ – ^177^ The HTA ^13^ discussed in Key Question 1 systematically reviewed economic modeling studies of prediabetes treatment, and recommended screening for glucose intolerance because there are effective strategies for reducing cholesterol and blood pressure, and because DM2 can be prevented. These authors noted that although existing models were of variable quality, structure, and assumptions, all predicted that delaying the onset of diabetes would substantially reduce the incidence of vascular complications, improve quality of life, and avoid future medical costs. The authors concluded that if a screening program was implemented to target persons at risk for diabetes, subsequent treatment of persons with IGT with lifestyle or pharmacologic interventions was a good use of resources. Waugh and colleagues appear to assume that the effects of treating persons with screen-detected diabetes are the same as for treating clinically-detected populations, and that there are proven linkages between treating dysglycemia and final health outcomes. All modeling studies included in the HTA are reviewed herein.

Herman and colleagues ^172^ examined the life-time utility and cost-effectiveness of the DPP lifestyle intervention. ^79^ They noted the intervention to be relatively cost-effective (cost/QALY, $8,800 from a societal perspective), with gains in life expectancy of 0.5 years and a decrease in the incidence of diabetes by 20%. Results were somewhat less marked with metformin, but this treatment was still relatively cost-effective.

Eddy and colleagues ^169^ also examined the DPP interventions, using their Archimedes model. ^170^ Consistent with the model used by Herman and colleagues, ^172^ the Archimedes model predicted large absolute reductions in the proportion of persons developing DM2, a delay of 7 to 8 years in onset of DM2, and that the DPP lifestyle intervention leads to fewer complications and improved QALYs. ^175^ Eddy and colleagues, however, estimated much higher marginal cost-effectiveness ratios than did Herman et al. ^172^ For example, the cost per QALY of the lifestyle program compared to no intervention was $62,600 from a societal perspective in the Archimedes model and $8,800 in the CDC model. Differences between the two models included a longer time horizon for the CDC model, different assumptions about glycemic progression, and lower microvascular and macrovascular disease rates in the Archimedes model. ^175^

Four Markov models evaluated primary prevention of DM2 among persons with IGT. ^173,^ ^174,^ ^176,^ ^177^ All demonstrated relative cost-effectiveness of lifestyle interventions, and two models examining metformin also found cost savings under many conditions. ^174,^ ^176^ The models of Segal and colleagues ^173^ and Caro and colleagues ^174^ were criticized by the HTA authors ^13^ for lacking transparency of the model inputs and assumptions. The Palmer and colleagues' model ^176^ was relatively transparent, but did not model individual complications. ^13^

## Update Key Question 4. What adverse effects result from screening a person for type 2 diabetes or IFG/IGT?

### Summary of Findings

Data are sparse on the psychological effects of screening for DM2, and none of the available data suggested significant adverse effects at up to 1-year follow-up. In addition, no study reported serious, long-term, adverse effects of a new diagnosis of DM2 over a wide variety of outcomes including anxiety, depression, well-being, overall mental health, health-related quality of life, self efficacy, self care, and diabetes-related symptom distress.

### Study Details

The previous review ^40,^ ^76^ of the adverse effects of screening for DM2 identified no relevant studies, but suggested that labeling and false-positive diagnosis were potential effects that may lead to anxiety and other psychological distress, as well as changes in self-perception. In addition, the prior review suggested that false positive test results could lead to unnecessary treatment.

The negative psychological and physical effects of screening for, or receiving a new diagnosis of, DM2 or prediabetes was examined for this update (see Table 8 and Appendix B11 for further details). ^178^ – ^190^ Several studies were derived from the large observational study of the Dutch population (the Hoorn study) ^178^ – ^181^ The ADDITION trial, discussed previously, also contributed relevant data. ^189,^ ^190^

#### Effect of a false positive test for DM2 or prediabetes

We identified no studies that addressed the effects of a false positive result from any of the tests used to screen for dysglycemia. While false positive results can occur with a single fasting blood glucose test, the specificity of a single test is 95%. ^76^

#### Labeling of a person as having DM2 or prediabetes

We identified no studies that directly addressed labeling of persons with screen-detected diabetes.

#### Psychological effects of screening

In the ADDITION study, ^190^ step-wise screening had limited effects on anxiety levels at up to 1-year follow-up. Being required to return for additional tests after an initial positive random blood glucose had a small, negative psychological impact of doubtful clinical significance. After notification of a positive screening test, subjects reported poorer health, higher anxiety, more depression, and more diabetes-specific worry (p all ≤ 0.05) than those with a negative test.

In a cross-sectional study at the time of screening for DM2 with an OGTT, Skinner and colleagues did not find that screening high-risk patients was associated with significant anxiety. ^187^ In a small, qualitative study of a stepped approach to screening, ^181^ screening was generally perceived positive and not burdensome. A minority of subjects had concerns about privacy, completing the risk factor questionnaire, and the inconvenience of the OGTT.

Siblings of patients with DM2 who did not have diabetes had slightly elevated anxiety levels (compared to normative values) at the time of screening with a fasting plasma glucose. Anxiety levels decreased at one year but remained above normal levels. Subjects with normal and with elevated glucose levels had similar anxiety levels and measures of well-being at baseline and 1-year follow-up. ^183^

#### Psychological effects of the diagnosis of DM2

No study reported serious psychological or other adverse effects of a new diagnosis of DM2. ^178^ – ^182,^ ^185,^ ^186,^ ^188^ – ^190^ Several studies compared persons with screen-detected DM2 to persons without diabetes. Adriaanse and colleagues, ^180^ using Hoorn observational data, at 2-week follow-up found no significant differences in well-being and health-related quality of life (HRQoL) (measured with the Short Form-36 [SF-36]) between newly-diagnosed subjects and those at high risk that screened negative. Scores were lower (poorer quality of life) for several SF-36 subscales in the group with diabetes at 6 months. At 1-year follow-up, however, no significant differences were noted. Also using Hoorn observational data, persons with screen-detected DM2 reported significantly more hyperglycemic and fatigue symptoms in the first year following diagnosis of DM2 compared to screened-negative persons. ^179^ However, total symptom distress was low and not significantly different between the two groups at up to 1-year follow-up. Edelman and colleagues ^182^ also found no significant differences between persons screened positive for DM2 and those screened negative using the physical and mental component scales of the SF-36 at 1-year follow-up. Similar results were noted by Nichols and Brown ^185^ who compared subjects with a fasting blood glucose between 126 and 140 mg/dl, who became diabetic after the change in definition in 1997, ^191^ to persons without DM2. They found that physical function was already lower in persons who met the new diagnosis of DM2, but the mental health component score was not different between the groups. This study also compared persons who were told of their new diagnosis of DM2, and those who had the disease but were not yet informed of it. There was no difference between these groups in either the physical or mental health score at 1 year from the first questionnaire. Response rates were low, however, both at baseline (69% for both the DM2 and comparison groups) at 1-year follow-up (44%).

The ADDITION study of screen-detected DM2 in the Netherlands provides additional insight into the effect of screen-detected disease (based on stepped-screening using risk factor assessment, FPG, and OGTT) on various outcomes. ^188^ – ^190^ Thoolen and colleagues, ^188^ with response rates of 35% to 62%, found that persons with screen-detected diabetes generally reported low emotional distress and threat perceptions, high self-efficacy, but low self-care behavior. Intensively-treated patients reported more distress and less self-efficacy in the first year after diagnosis compared to usual-care patients, but the latter group experienced relatively more distress and less self-efficacy 2 to 3 years after diagnosis. In a qualitative study of reactions after a new diagnosis of DM2, patients tended to downplay the importance of the diagnosis and all had plans to control the disease. ^189^

In a pilot study of the Hoorn cohort, ^181^ Adriaanse and colleagues found that persons with newly screen-detected DM2 did not experience the disease as “severe,” although many perceived the need for a major change in their lifestyle.

One study compared newly-diagnosed persons with DM2 (76% of whom presented with clinical symptoms) identified in general practice with persons detected through a targeted population screening program. ^178^ The general practice group had significantly lower scores on mental health-related subscales of the SF-36 compared to the screen-detected group shortly after diagnosis; these differences persisted at 1-year follow-up. The general practice group, however, improved in perceived general health, and vitality scores improved over time, compared with the screen-detected group. This suggests improvements with treatment or adaptation to the disease. Perceived burden of diabetes-related symptoms improved significantly within the general practitioner group over the first year after diagnosis, (p<0.001) but did not improve in the screen-detected group (p=0.093). Symptom scores were higher (more symptoms) initially in the general practice group, but no differences were demonstrated at 1 year.

#### Psychological effects of a diagnosis of prediabetes

In the only study examining the effect of a diagnosis of prediabetes, ^189^ many study participants were confused by this diagnosis, and most were unconcerned and unaware of this diagnosis as a risk factor for DM2 or cardiovascular disease.

## Update Key Question 5. What adverse effects result from treating a person with type 2 diabetes, IFG, or IGT detected by screening?

### Summary of Findings

Recent systematic reviews of the adverse effects of drugs used in the treatment of DM2 and prediabetes reveal some significant new data related to the safety of thiazolidinediones. New information on an association between rosiglitazone and an increased risk of myocardial infarction was recently published. ^192^ For other drugs examined in studies included in Key Questions 2 and 3 in this review, we identified no new data on severe or idiosyncratic side effects in our systematic search when compared to data available at the time of the prior USPSTF review. ^40,^ ^76^ Relatively common side effects such as cough with ACE-inhibitor and gastrointestinal effects with acarbose are a consideration when prescribing these drugs, but are not associated with increased mortality or adverse cardiovascular outcomes.

### Study Details

We identified 24 recent systematic reviews ^193^ – ^218^ examining the adverse effects of drugs used in studies included in Key Questions 2 and 3 (see Table 9). For acarbose, a recent review noted no difference in mortality between treatment and placebo groups, however, there were significantly more side effects with acarbose than with than placebo (OR 3.37 [95% CI, 2.60 to 4.36]), ^194^ particularly gastrointestinal effects (OR 3.5, 95% CI, 2.7 – 4.4). ^193^ Pooled trial data for over 47,000 patients identified no cases of fatal or nonfatal lactic acidosis with metformin. ^206^ In another meta-analysis of metformin, there were no differences between the treatment group and a diet or placebo group for hypoglycemia or all-cause mortality. ^205^ Rates of hypoglycemia generally did not differ between treatment and control groups in a review of a broad spectrum of oral agents, except for sulfonylurea where rates were generally higher in the treatment group. ^203^ Gangji and colleagues found that glyburide caused more hypoglycemia than other sulfonylureas, but was not associated with an increased risk of cardiovascular events or death. ^204^

ACE-inhibitors did produce a significant increase in cough compared to placebo (RR 3.17 [95% CI, 2.29 – 4.38]); and angiotensin II receptor antagonists also produced an increase in cough (two studies, RR 4.93 [95% CI, 1.00, 24.35]). ^219^ Myocardial infarction rates did not differ significantly between angiotensin II receptor antagonists and placebo; and cardiovascular disease mortality was slightly decreased compared with placebo (OR 0.91, 95% CI 0.83 – 0.99). ^199^ Exposure to angiotensin II receptor antagonists during the first trimester of pregnancy appears to be associated with an increased risk for adverse fetal outcomes (p=0.04). ^198^ Beta-blockers were associated with more withdrawals due to adverse events compared to placebo (RR 2.34 [95% CI, 0.84–6.62]), but cardiovascular mortality and stroke were significantly lower in the treatment group, and there was no difference between treatment and comparisons groups in total mortality. ^202^ The risk of any adverse events is elevated for statins (OR 1.4, 95% CI, 1.09 – 1.80), however the rates of serious adverse events were similar between the statin and placebo groups. ^212^ Statin therapy was associated with a significant reduction in the risk of clinical cardiovascular events (OR 0.74, 95% CI, 0.69 – 0.80). ^212^ The incidence of rhabdomyalysis was low in persons taking statins (with the exception of ceruvistatin), and myopathy attributed to statins was also rare (11/100,000 person-years, excluding ceruvostatin). ^211^ The risk of cancer was not elevated with pravastatin (RR 1.06, 95% CI, 0.97 – 1.14). ^209^

Recently published data on thiazolidinediones raise concerns about the safety of these drugs. A meta-analysis ^192^ (which was not a systematic review) suggested an increased cardiovascular risk associated with rosiglitazone compared to alternative oral diabetes therapies. A subsequent interim analysis of a multi-center, open-label RCT was inconclusive regarding the effect of this drug on overall risk of hospitalization or cardiovascular death, and the data were insufficient to determine whether rosiglitazone was associated with an increase in the risk of myocardial infarction. ^220^ Recent Cochrane reviews suggest that rates of edema were significantly increased with both pioglitazone ^215^ and rosiglitazone. ^214^ Pioglitazone was associated with a significantly increased rate of heart failure compared to placebo in another recent systematic review. ^213^ In a systematic review published after our final searches were complete, Singh and colleagues ^216^ found that among persons with IGT or DM2, rosiglitazone use for 12 or more months was associated with a significantly increased risk of myocardial infarction and heart failure, although the risk of cardiovascular mortality was not increased. Analysis of individual time-to-event data obtained from the drug's manufacturer suggested a lower risk of death, myocardial infarction, or stroke with pioglitazatone than with placebo or active comparator. ^221^ Serious heart failure was increased, but associated mortality was not. In a Cochrane review of pioglitazone, ^215^ only one study examined all-cause mortality ^222^ which was not significantly different between the intervention and placebo groups. In a Cochrane review of rosiglitazone, no study included mortality as a primary or secondary endpoint. ^214^