# Methods

This report updates the prior evidence review of 2003 by Harris and colleagues,^40,^ ^76^ using the evidence that the prior authors synthesized, adding to it data from new trials and updates from previously included studies. The revised Key Questions and the work plan for the review were developed collaboratively by the review team, Agency for Healthcare Research and Quality (AHRQ) officers, and the USPSTF topic leads. This report will form the evidence base from which the USPSTF will formulate recommendations.

Using the methods of the USPSTF^77^ that are fully detailed in Appendix C, we modified the prior analytic framework and Key Questions to guide our literature search (Figure 2). The analytic framework depicts the relationship between screening a population at risk for diabetes complications and critical final health outcomes, and has been modified somewhat from the previous framework.^40^ The current framework focuses on both populations at high and average-risk of diabetes complications, as well as on asymptomatic adults. The framework also explicitly encompasses IFG and IGT. We have added two final outcomes (quality of life and symptomatic neuropathy) and we focus here on only one intermediate outcome - incidence of diabetes (for prediabetes interventions), as this report is based primarily on final health outcomes.

Figure 2. Analytic Framework and Key Questions

Abbreviation: KQ: key question.

We focus on the risk for complications from DM2 as the goal of screening is to improve health and well-being, which is contingent on decreasing the complications of DM2, and not primarily on decreasing the prevalence of the disease. We do not consider studies that exclusively enrolled persons with known cardiovascular disease (i.e., secondary prevention studies), as we consider those persons to have a complication from DM2. Because of the burden of cardiovascular disease in persons with diabetes and the overlap of risk factors for microvascular disease (i.e., hypertension), we consider persons with diabetes at risk for cardiovascular disease to be those at higher risk for DM2 complications. The risk factors identified as significant predictors of cardiovascular events amongst persons with DM2 include older age, smoking, hypertension, hyperlipidemia (specifically, an elevated total cholesterol/high-density lipoprotein [HDL] ratio), higher glycemic burden, and certain high-risk ethnic groups.^78^

We searched Medline and the Cochrane Library for systematic reviews and relevant studies published in English between March, 2001 (6 months prior to the cut-off for the prior search) and July 2007. Our search strategies are contained in Appendix C1. For large trials included in the prior report,^40^ we searched for related recent publications that presented additional data that fulfilled our inclusion criteria. We also examined the reference lists of key included studies and contacted experts for additional citations. We examined relevant systematic reviews retrieved from our searches, and for Key Questions, we evaluated all studies included in those reviews for potential inclusion in this report.

Titles and abstracts were screened (using inclusion criteria described in Appendix C2) by one author and a random sample of 1500 titles and abstracts were reviewed by two authors, giving a 5% margin of error on inter-rater reliability, assuming that both reviewers identified the same percentage of potentially relevant articles. Abstracts identified by one or both reviewers were retrieved in full-text format and reviewed in duplicate to determine inclusion status. Where there was disagreement between the two full-text reviewers, consensus was achieved through discussion.

Data were abstracted by one author and checked by a second. Key studies were reviewed and discussed by all authors. Quality assessment (internal validity) of individual randomized, controlled trials (RCTs) was performed by assessing factors that might introduce bias: adequate randomization, allocation concealment, baseline comparability of participants, blinding, and loss to follow-up (see Appendix C3). Studies were rated as good, fair, or poor quality. Potential applicability to widespread primary care practice was also assessed based on the approach to participant recruitment and selection in each study. The quality of cohort and case control studies was performed using the USPSTF approach,^77^ again grading studies as good, fair, or poor. Pilot and cross-sectional studies were not assessed for quality. Systematic evidence reviews were rated as good, fair, or poor, using the methodology described in Appendix C4.

Modeling studies were identified from a our main search as well as from a recent, high-quality systematic review of DM2 screening by the National Health Service Research and Development Health Technology Assessment (HTA) Programme.^13^ We independently abstracted the relevant studies included in their report and relied upon their extensive assessments of model quality.

A draft of the systematic review was reviewed by external peer reviewers (Appendix C5) from relevant professional organizations, federal agencies, and the private sector. Revisions were made based on these comments.

## Statistical Analysis

We performed a meta-analysis to provide combined estimates of drug and lifestyle modification the effect of drug and lifestyle modification on reducing diabetes incidence. Most studies reported a hazard ratio (HR) and its standard error (SE) from a Cox regression. When HR was not reported^79^–^81^ either a rate ratio standard error or risk ratio was calculated using reported data. Hazard ratio, rate ratio, and risk ratio could all be considered as a measure of relative risk (RR), and combined in the meta-analysis. For the Diabetes Reduction Assessment with Ramipril and Rosiglitazone Medication (DREAM) trial,^82^ a 2×2 factorial design was used, and HRs for both rosiglitazone and ramipril used data from all participants; therefore, the variance of the HR from each drug is multiplied by 2, so that result from each drug is down-weighted, and the DREAM trial receives appropriate weight as one study in the analysis.

Statistical heterogeneity was tested used the standard χ^2^ test. The overall estimates of RR were obtained by a random effects model.^83^ Estimates from the random effects model incorporate the variability among studies and represent a more conservative approach. When there is no heterogeneity among studies, both fixed and random effects model would yield same results.