# Appendix C Detailed Methods

## Appendix C1. Literature Search Strategies

Adverse Effects - Overall

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 1 or 2 or 3
5 (screen$ or diagnos$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6 4 and 5
7 (adverse effect$ or harm or harmed or harming or harms or iatrogen$ or nosocom$ or drug interaction$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
8 ((Diagnos$ adj5 (Error$ or mistak$)) or (false$ adj3 (positiv$ or negativ$)) or (observer$ adj variation$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9 (prejudic$ or bias$ or stigma$ or discriminat$ or unfair$ or illegal$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
10 ((Stress$ or tension$) adj5 (Psychologic$ or emotion$ or mental$ or family or families or interpersonal$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11 (((Life or living) adj3 (Chang$ or style$)) or lifestyl$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12 7 or 8 or 9 or 10 or 11
13 4 and 12

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

1 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, abstract, full text, keywords, caption text])
2 (prediabet$ or pre-diabet$).mp. [mp=title, abstract, full text, keywords, caption text]
3 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, abstract, full text, keywords, caption text]
4 1 or 2 or 3
5 (screen$ or diagnos$).mp. [mp=title, abstract, full text, keywords, caption text]
6 4 and 5
7 (adverse effect$ or harm or harmed or harming or harms or iatrogen$ or nosocom$ or drug interaction$).mp. [mp=title, abstract, full text, keywords, caption text]
8 ((Diagnos$ adj5 (Error$ or mistak$)) or (false$ adj3 (positiv$ or negativ$)) or (observer$ adj variation$)).mp. [mp=title, abstract, full text, keywords, caption text]
9 (prejudic$ or bias$ or stigma$ or discriminat$ or unfair$ or illegal$).mp. [mp=title, abstract, full text, keywords, caption text]
10 ((Stress$ or tension$) adj5 (Psychologic$ or emotion$ or mental$ or family or families or interpersonal$)).mp. [mp=title, abstract, full text, keywords, caption text]
11 (((Life or living) adj3 (Chang$ or style$)) or lifestyl$).mp. [mp=title, abstract, full text, keywords, caption text]
12 7 or 8 or 9 or 10 or 11
13 4 and 12

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

1 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, full text, keywords]
2 (prediabet$ or pre-diabet$).mp. [mp=title, full text, keywords]
3 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, full text, keywords]
4 1 or 2 or 3
5 (screen$ or diagnos$).mp. [mp=title, full text, keywords]
6 4 and 5
7 (adverse effect$ or harm or harmed or harming or harms or iatrogen$ or nosocom$ or drug interaction$).mp. [mp=title, full text, keywords])
8 ((Diagnos$ adj5 (Error$ or mistak$)) or (false$ adj3 (positiv$ or negativ$)) or (observer$ adj variation$)).mp. [mp=title, full text, keywords]
9 (prejudic$ or bias$ or stigma$ or discriminat$ or unfair$ or illegal$).mp. [mp=title, full text, keywords]
10 ((Stress$ or tension$) adj5 (Psychologic$ or emotion$ or mental$ or family or families or interpersonal$)).mp. [mp=title, full text, keywords]
11 (((Life or living) adj3 (Chang$ or style$)) or lifestyl$).mp. [mp=title, full text, keywords]
12 7 or 8 or 9 or 10 or 11
13 4 and 12

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Diabetes Mellitus, Type 2/
2 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
4 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
5 1 or 2 or 3 or 4
6 (screen$ or diagnos$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 5 and 6
8 (200109$ or 20011$ or 2002$ or 2003$ or 2004$ or 2005$ or 2006$ or 2007$).ed.
9 7 and 8
10 limit 9 to (humans and english language
11 (adverse effect$ or harm or iatrogen$ or nosocom$ or drug interaction$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
12 exp Diagnostic Errors/
13 (prejudic$ or stigma$ or discriminat$ or unfair$ or illegal$).mp. [mp=title, original title, abstract, name of substance word, subject heading word
14 exp Stress, Psychological/
15 exp Life Change Events/
16 11 or 12 or 13 or 14 or 15
17 5 and 16
18 8 and 17
19 limit 18 to english language
20 limit 19 to humans

Adverse Effects of Treatment - Systematic Reviews

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Hypoglycemic Agents/ae, po, ct, to [Adverse Effects, Poisoning, Contraindications, Toxicity]
2 exp Sulfonylurea Compounds/ae, po, ct, to [Adverse Effects, Poisoning, Contraindications, Toxicity]
3 exp Angiotensin-Converting Enzyme Inhibitors/ae, po, ct, to [Adverse Effects, Poisoning, Contraindications, Toxicity]
4 exp Receptors, Angiotensin/ai [Antagonists & Inhibitors]
5 (ae or po or to or ct).fs.
6 (adverse effect$ or poison$ or toxic$ or contraindicat$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 5 or 6
8 4 and 7
9 exp Angiotensin II Type 1 Receptor Blockers/ae, po, ct, to
10 8 or 9
11 exp Calcium Channel Blockers/ae, po, ct, to [Adverse Effects, Poisoning, Contraindications, Toxicity]
12 exp Thiazides/ae, ct [Adverse Effects, Contraindications]
13 exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/ae, po, ct, to [Adverse Effects, Poisoning, Contraindications, Toxicity]
14 orlistat.mp.
15 7 and 14
16 exp Insulin/ae, po, ct, to [Adverse Effects, Poisoning, Contraindications, Toxicity]
17 exp Aspirin/ae, po, ct, to [Adverse Effects, Poisoning, Contraindications, Toxicity]
18 1 or 2 or 3 or 10 or 11 or 12 or 13 or 15 or 16 or 17
19 (systematic$ adj review$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
20 (data adj synthesis).tw.
21 (published adj studies).ab.
22 (data adj extraction).ab.
23 meta-analysis/
24 (meta-analy$ or metaanaly$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
25 19 or 20 or 21 or 22 or 23 or 24
26 comment.pt.
27 letter.pt.
28 editorial.pt.
29 Animals/
30 Humans/
31 29 not (29 and 30)
32 18 not 31
33 32 and (19 or 20 or 21 or 22 or 23 or 24)
34 limit 33 to yr=“2001 - 2007”

Hemoglobin Alc

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1 ((Diabet$ adj3 (type II or type 2 or non-insulin depend$)) or NIDDM or MODY).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 1 or 2 or 3
5 exp Hemoglobin A, Glycosylated/
6 (hba 1c or a 1c or a1c).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7 ((glycat$ or glycosyl$) adj7 (hemoglobin$ or hgb or red blood cell$ or rbc$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
8 5 or 6 or 7
9 4 and 8
10 ((Diagnos$ adj5 (Error$ or mistake$)) or (false$ adj3 (positiv$ or negativ$)) or (observer$ adj3 variation$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11 (sensitivity adj2 specificity).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12 (Reproduc$ adj5 (Result$ or outcome$ or reading$ or value$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13 (accura$ or reliab$ or prevalen$ or yield$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
14 10 or 11 or 12 or 13
15 exp Mass Screening/
16 (screen$ or diagnos$ or test$ or detect$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
17 15 or 16
18 9 and 17

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

1 ((Diabet$ adj3 (type II or type 2 or non-insulin depend$)) or NIDDM or MODY).mp. [mp=title, abstract, full text, keywords, caption text]
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, abstract, full text, keywords, caption text]
3 (prediabet$ or pre-diabet$).mp. [mp=title, abstract, full text, keywords, caption text]
4 1 or 2 or 3
5 [exp Hemoglobin A, Glycosylated/]
6 (hba 1c or a 1c or a1c).mp. [mp=title, abstract, full text, keywords, caption text]
7 ((glycat$ or glycosyl$) adj7 (hemoglobin$ or hgb or red blood cell$ or rbc$)).mp. [mp=title, abstract, full text, keywords, caption text]
8 5 or 6 or 7
9 4 and 8
10 ((Diagnos$ adj5 (Error$ or mistake$)) or (false$ adj3 (positiv$ or negativ$)) or (observer$ adj3 variation$)).mp. [mp=title, abstract, full text, keywords, caption text]
11 (sensitivity adj2 specificity).mp. [mp=title, abstract, full text, keywords, caption text]
12 (Reproduc$ adj5 (Result$ or outcome$ or reading$ or value$)).mp. [mp=title, abstract, full text, keywords, caption text]
13 (accura$ or reliab$ or prevalen$ or yield$).mp. [mp=title, abstract, full text, keywords, caption text]
14 10 or 11 or 12 or 13
15 [exp Mass Screening/]
16 (screen$ or diagnos$ or test$ or detect$).mp. [mp=title, abstract, full text, keywords, caption text]
17 15 or 16
18 9 and 17

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Diabetes Mellitus, type II/
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
4 1 or 2 or 3
5 exp Hemoglobin A, Glycosylated/
6 a1c.mp.
7 (glycosyl$ adj7 (hemoglobin$ or hgb or red blood cell$ or rbc$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 5 or 6 or 7
9 4 and 8
10 (systematic adj review$).tw.
11 (data adj synthesis).tw.
12 (published adj studies).ab.
13 (data adj extraction).ab.
14 meta-analysis/
15 comment.pt.
16 letter.pt.
17 editorial.pt.
18 animal/
19 human/
20 18 not (18 and 19)
21 9 not (15 or 16 or 17 or 20)
22 21 and (10 or 11 or 12 or 13 or 14)
23 (200109$ or 2002$ or 2003$ or 2004$ or 2005$ or 2006$ or 2007$).ed.
24 22 and 23

Screening

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 1 or 2 or 3
5 (screen$ or diagnos$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6 4 and 5

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

1 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, abstract, full text, keywords, caption text]
2 (prediabet$ or pre-diabet$).mp. [mp=title, abstract, full text, keywords, caption text]
3 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, abstract, full text, keywords, caption text]
4 1 or 2 or 3
5 (screen$ or diagnos$).mp. [mp=title, abstract, full text, keywords, caption text]
6 4 and 5

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

1 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, full text, keywords]
2 (prediabet$ or pre-diabet$).mp. [mp=title, full text, keywords] (0)
3 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, full text, keywords]
4 1 or 2 or 3
5 (screen$ or diagnos$).mp. [mp=title, full text, keywords]
6 4 and 5

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Diabetes Mellitus, Type 2/
2 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
4 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word
5 1 or 2 or 3 or 4
6 (screen$ or diagnos$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 5 and 6
8 (200109$ or 20011$ or 2002$ or 2003$ or 2004$ or 2005$ or 2006$).ed.
9 7 and 8
10 limit 9 to (humans and english language
11 limit 10 to yr=“2004 - 2007”
12 (200109$ or 20011$ or 2002$ or 2003$).ed.
13 9 and 12

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Diabetes Mellitus, Type 2/
2 ((fasting glucose or glucose tolerance) adj3 impair$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
4 ((type 2 or type II or non-insulin dependent) adj3 diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
5 1 or 2 or 3 or 4
6 (screen$ or diagnos$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 5 and 6
8 (200109$ or 20011$ or 2002$ or 2003$ or 2004$ or 2005$ or 2006$).ed.
9 7 and 8
10 limit 9 to (humans and english language)
11 limit 10 to yr=“2004 - 2007”

Treatment

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1 ((Diabet$ adj3 (type II or type 2 or non-insulin depend$)) or MODY or NIDDM).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 1 or 2 or 3
5 Hypoglycemic Agent$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6 Glipizide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7 Glyburide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
8 Glimepiride.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9 Metformin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
10 Rosiglitazone.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11 Pioglitazone.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12 Repaglinide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13 Nateglinide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
14 Acarbose.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 5 or 15
17 4 and 16
18 (Angiotensin Converting Enzyme Inhibitor$ or ace inhibitor$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
19 (Angiotensin adj3 (block$ or antagon$ or receptor$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
20 (Calcium Channel$ adj3 (antagon$ or Block$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
21 (antihypertensi$ or anti-hypertensi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
22 18 or 19 or 20 or 21
23 4 and 22
24 Hydroxymethylglutaryl CoA Reductase$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
25 Lovastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
26 Pravastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
27 Fluvastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
28 Atorvastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
29 Rosuvastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
30 25 or 26 or 27 or 28 or 29
31 24 or 30
32 4 and 31
33 Antilipemic$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
34 Gemfibrozil.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
35 Fenofibrate.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
36 Nicotinic Acid.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
37 Cholestyramine.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword])
38 Colestipol.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
39 Colesevelam.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
40 Ezetimibe.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
41 34 or 35 or 36 or 37 or 38 or 39 or 40
42 33 or 41
43 4 and 42
44 Aspirin.mp.
45 4 and 44
46 (Life Style$ or lifestyle$ or ((living or live or lived) adj5 style$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
47 4 and 46
48 Exercis$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
49 (tai chi or tai ji or relaxation or walk$ or yoga or jog or jogging).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword
50 (Physical$ adj3 (Fitness or fit)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
51 48 or 49 or 50
52 4 and 51
53 ((Gastric or stomach) adj3 Bypass$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
54 gastroplast$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
55 ((obese or obesity) adj3 (surger$ or surgic$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
56 53 or 54 or 55
57 4 and 56
58 anti-obesity agent$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
59 ((obese or obesity) adj3 (drug$ or pharmaco$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
60 orlistat.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
61 sibutramine.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
62 fluoxetine.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
63 58 or 59 or 60 or 61 or 62
64 4 and 63
65 Counsel$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
66 4 and 65
67 (Patient$ adj3 (Educat$ or inform$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
68 4 and 67
69 footcare.mp.
70 ((foot or feet or toe or toes or heel or plantar) adj5 (care or cares or caring or cared)).mp.
71 ((foot or feet or toe or toes or heel or plantar) adj5 (disease$ or ulcer$ or sore$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
72 69 or 70 or 71
73 4 and 72
74 17 or 23 or 32 or 43 or 45 or 47 or 52 or 57 or 64 or 66 or 68 or 73
75 limit 74 to yr=“2001 - 2007”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1 ((Diabet$ adj3 (type II or type 2 or non-insulin depend$)) or MODY or NIDDM).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 1 or 2 or 3
5 Hypoglycemic Agent$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6 Glipizide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7 Glyburide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
8 Glimepiride.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9 Metformin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
10 Rosiglitazone.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11 Pioglitazone.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12 Repaglinide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13 Nateglinide.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
14 Acarbose.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 5 or 15
17 4 and 16
18 (Angiotensin Converting Enzyme Inhibitor$ or ace inhibitor$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
19 (Angiotensin adj3 (block$ or antagon$ or receptor$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
20 (Calcium Channel$ adj3 (antagon$ or Block$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
21 (antihypertensi$ or anti-hypertensi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
22 18 or 19 or 20 or 21
23 4 and 22
24 Hydroxymethylglutaryl CoA Reductase$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
25 Lovastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
26 Pravastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
27 Fluvastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
28 Atorvastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
29 Rosuvastatin.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
30 25 or 26 or 27 or 28 or 29
31 24 or 30
32 4 and 31
33 Antilipemic$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
34 Gemfibrozil.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
35 Fenofibrate.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
36 Nicotinic Acid.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
37 Cholestyramine.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
38 Colestipol.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
39 Colesevelam.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
40 Ezetimibe.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
41 34 or 35 or 36 or 37 or 38 or 39 or 40
42 33 or 41
43 4 and 42
44 Aspirin.mp.
45 4 and 44
46 (Life Style$ or lifestyle$ or ((living or live or lived) adj5 style$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
47 4 and 46
48 Exercis$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
49 (tai chi or tai ji or relaxation or walk$ or yoga or jog or jogging).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
50 (Physical$ adj3 (Fitness or fit)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword])
51 48 or 49 or 50
52 4 and 51
53 ((Gastric or stomach) adj3 Bypass$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
54 gastroplast$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
55 ((obese or obesity) adj3 (surger$ or surgic$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
56 53 or 54 or 55
57 4 and 56
58 anti-obesity agent$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
59 ((obese or obesity) adj3 (drug$ or pharmaco$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
60 orlistat.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
61 sibutramine.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
62 fluoxetine.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
63 58 or 59 or 60 or 61 or 62
64 4 and 63
65 Counsel$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
66 4 and 65
67 (Patient$ adj3 (Educat$ or inform$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
68 4 and 67
69 footcare.mp.
70 ((foot or feet or toe or toes or heel or plantar) adj5 (care or cares or caring or cared)).mp.
71 ((foot or feet or toe or toes or heel or plantar) adj5 (disease$ or ulcer$ or sore$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
72 69 or 70 or 71
73 4 and 72
74 17 or 23 or 32 or 43 or 45 or 47 or 52 or 57 or 64 or 66 or 68 or 73
75 limit 74 to yr=“2001 - 2007”

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

1 ((Diabet$ adj3 (type II or type 2 or non-insulin depend$)) or MODY or NIDDM).mp. [mp=title, abstract, full text, keywords, caption text]
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, abstract, full text, keywords, caption text]
3 (prediabet$ or pre-diabet$).mp. [mp=title, abstract, full text, keywords, caption text]
4 1 or 2 or 3
5 Hypoglycemic Agent$.mp. [mp=title, abstract, full text, keywords, caption text]
6 Glipizide.mp. [mp=title, abstract, full text, keywords, caption text]
7 Glyburide.mp. [mp=title, abstract, full text, keywords, caption text]
8 Glimepiride.mp. [mp=title, abstract, full text, keywords, caption text]
9 Metformin.mp. [mp=title, abstract, full text, keywords, caption text]
10 Rosiglitazone.mp. [mp=title, abstract, full text, keywords, caption text]
11 Pioglitazone.mp. [mp=title, abstract, full text, keywords, caption text]
12 Repaglinide.mp. [mp=title, abstract, full text, keywords, caption text]
13 Nateglinide.mp. [mp=title, abstract, full text, keywords, caption text]
14 Acarbose.mp. [mp=title, abstract, full text, keywords, caption text]
15 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 5 or 15
17 4 and 16
18 (Angiotensin Converting Enzyme Inhibitor$ or ace inhibitor$).mp. [mp=title, abstract, full text, keywords, caption text]
19 (Angiotensin adj3 (block$ or antagon$ or receptor$)).mp. [mp=title, abstract, full text, keywords, caption text]
20 (Calcium Channel$ adj3 (antagon$ or Block$)).mp. [mp=title, abstract, full text, keywords, caption text]
21 (antihypertensi$ or anti-hypertensi$).mp. [mp=title, abstract, full text, keywords, caption text]
22 18 or 19 or 20 or 21
23 4 and 22
24 Hydroxymethylglutaryl CoA Reductase$.mp. [mp=title, abstract, full text, keywords, caption text]
25 Lovastatin.mp. [mp=title, abstract, full text, keywords, caption text]
26 Pravastatin.mp. [mp=title, abstract, full text, keywords, caption text]
27 Fluvastatin.mp. [mp=title, abstract, full text, keywords, caption text]
28 Atorvastatin.mp. [mp=title, abstract, full text, keywords, caption text]
29 Rosuvastatin.mp. [mp=title, abstract, full text, keywords, caption text]
30 25 or 26 or 27 or 28 or 29
31 24 or 30
32 4 and 31
33 Antilipemic$.mp. [mp=title, abstract, full text, keywords, caption text]
34 Gemfibrozil.mp. [mp=title, abstract, full text, keywords, caption text]
35 Fenofibrate.mp. [mp=title, abstract, full text, keywords, caption text]
36 Nicotinic Acid.mp. [mp=title, abstract, full text, keywords, caption text]
37 Cholestyramine.mp. [mp=title, abstract, full text, keywords, caption text]
38 Colestipol.mp. [mp=title, abstract, full text, keywords, caption text]
39 Colesevelam.mp. [mp=title, abstract, full text, keywords, caption text]
40 Ezetimibe.mp. [mp=title, abstract, full text, keywords, caption text]
41 34 or 35 or 36 or 37 or 38 or 39 or 40
42 33 or 41
43 4 and 42
44 Aspirin.mp.
45 4 and 44
46 (Life Style$ or lifestyle$ or ((living or live or lived) adj5 style$)).mp. [mp=title, abstract, full text, keywords, caption text]
47 4 and 46
48 Exercis$.mp. [mp=title, abstract, full text, keywords, caption text]
49 (tai chi or tai ji or relaxation or walk$ or yoga or jog or jogging).mp. [mp=title, abstract, full text, keywords, caption text]
50 (Physical$ adj3 (Fitness or fit)).mp. [mp=title, abstract, full text, keywords, caption text]
51 48 or 49 or 50
52 4 and 51
53 ((Gastric or stomach) adj3 Bypass$).mp. [mp=title, abstract, full text, keywords, caption text]
54 gastroplast$.mp. [mp=title, abstract, full text, keywords, caption text]
55 ((obese or obesity) adj3 (surger$ or surgic$)).mp. [mp=title, abstract, full text, keywords, caption text]
56 53 or 54 or 55
57 4 and 56
58 anti-obesity agent$.mp. [mp=title, abstract, full text, keywords, caption text]
59 ((obese or obesity) adj3 (drug$ or pharmaco$)).mp. [mp=title, abstract, full text, keywords, caption text]
60 orlistat.mp. [mp=title, abstract, full text, keywords, caption text]
61 sibutramine.mp. [mp=title, abstract, full text, keywords, caption text]
62 fluoxetine.mp. [mp=title, abstract, full text, keywords, caption text]
63 58 or 59 or 60 or 61 or 62
64 4 and 63
65 Counsel$.mp. [mp=title, abstract, full text, keywords, caption text]
66 4 and 65
67 (Patient$ adj3 (Educat$ or inform$)).mp. [mp=title, abstract, full text, keywords, caption text]
68 4 and 67
69 footcare.mp.
70 ((foot or feet or toe or toes or heel or plantar) adj5 (care or cares or caring or cared)).mp.
71 ((foot or feet or toe or toes or heel or plantar) adj5 (disease$ or ulcer$ or sore$)).mp. [mp=title, abstract, full text, keywords, caption text]
72 69 or 70 or 71
73 4 and 72
74 17 or 23 or 32 or 43 or 45 or 47 or 52 or 57 or 64 or 66 or 68 or 73

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

1 ((Diabet$ adj3 (type II or type 2 or non-insulin depend$)) or MODY or NIDDM).mp. [mp=title, full text, keywords]
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, full text, keywords]
3 (prediabet$ or pre-diabet$).mp. [mp=title, full text, keywords]
4 1 or 2 or 3
5 Hypoglycemic Agent$.mp. [mp=title, full text, keywords]
6 Glipizide.mp. [mp=title, full text, keywords]
7 Glyburide.mp. [mp=title, full text, keywords]
8 Glimepiride.mp. [mp=title, full text, keywords]
9 Metformin.mp. [mp=title, full text, keywords]
10 Rosiglitazone.mp. [mp=title, full text, keywords]
11 Pioglitazone.mp. [mp=title, full text, keywords]
12 Repaglinide.mp. [mp=title, full text, keywords]
13 Nateglinide.mp. [mp=title, full text, keywords]
14 Acarbose.mp. [mp=title, full text, keywords]
15 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 5 or 15
17 4 and 16
18 (Angiotensin Converting Enzyme Inhibitor$ or ace inhibitor$).mp. [mp=title, full text, keywords]
19 (Angiotensin adj3 (block$ or antagon$ or receptor$)).mp. [mp=title, full text, keywords]
20 (Calcium Channel$ adj3 (antagon$ or Block$)).mp. [mp=title, full text, keywords)
21 (antihypertensi$ or anti-hypertensi$).mp. [mp=title, full text, keywords]
22 18 or 19 or 20 or 21
23 4 and 22
24 Hydroxymethylglutaryl CoA Reductase$.mp. [mp=title, full text, keywords]
25 Lovastatin.mp. [mp=title, full text, keywords]
26 Pravastatin.mp. [mp=title, full text, keywords]
27 Fluvastatin.mp. [mp=title, full text, keywords]
28 Atorvastatin.mp. [mp=title, full text, keywords]
29 Rosuvastatin.mp. [mp=title, full text, keywords]
30 25 or 26 or 27 or 28 or 29
31 24 or 30
32 4 and 31
33 Antilipemic$.mp. [mp=title, full text, keywords]
34 Gemfibrozil.mp. [mp=title, full text, keywords]
35 Fenofibrate.mp. [mp=title, full text, keywords]
36 Nicotinic Acid.mp. [mp=title, full text, keywords]
37 Cholestyramine.mp. [mp=title, full text, keywords]
38 Colestipol.mp. [mp=title, full text, keywords]
39 Colesevelam.mp. [mp=title, full text, keywords]
40 Ezetimibe.mp. [mp=title, full text, keywords]
41 34 or 35 or 36 or 37 or 38 or 39 or 40
42 33 or 41
43 4 and 42
44 Aspirin.mp.
45 4 and 44
46 (Life Style$ or lifestyle$ or ((living or live or lived) adj5 style$)).mp. [mp=title, full text, keywords]
47 4 and 46
48 Exercis$.mp. [mp=title, full text, keywords]
49 (tai chi or tai ji or relaxation or walk$ or yoga or jog or jogging).mp. [mp=title, full text, keywords]
50 (Physical$ adj3 (Fitness or fit)).mp. [mp=title, full text, keywords]
51 48 or 49 or 50
52 4 and 51
53 ((Gastric or stomach) adj3 Bypass$).mp. [mp=title, full text, keywords]
54 gastroplast$.mp. [mp=title, full text, keywords]
55 ((obese or obesity) adj3 (surger$ or surgic$)).mp. [mp=title, full text, keywords]
56 53 or 54 or 55
57 4 and 56
58 anti-obesity agent$.mp. [mp=title, full text, keywords]
59 ((obese or obesity) adj3 (drug$ or pharmaco$)).mp. [mp=title, full text, keywords]
60 orlistat.mp. [mp=title, full text, keywords]
61 sibutramine.mp. [mp=title, full text, keywords]
62 fluoxetine.mp. [mp=title, full text, keywords]
63 58 or 59 or 60 or 61 or 62
64 4 and 63
65 Counsel$.mp. [mp=title, full text, keywords]
66 4 and 65
67 (Patient$ adj3 (Educat$ or inform$)).mp. [mp=title, full text, keywords]
68 4 and 67
69 footcare.mp.
70 ((foot or feet or toe or toes or heel or plantar) adj5 (care or cares or caring or cared)).mp.
71 ((foot or feet or toe or toes or heel or plantar) adj5 (disease$ or ulcer$ or sore$)).mp. [mp=title, full text, keywords]
72 69 or 70 or 71
73 4 and 72
74 17 or 23 or 32 or 43 or 45 or 47 or 52 or 57 or 64 or 66 or 68 or 73

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Diabetes Mellitus, type II/
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
4 1 or 2 or 3
5 exp Hypoglycemic Agents/
6 Glipizide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 Glyburide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 Glimepiride.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
9 Metformin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
10 Rosiglitazone.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
11 Pioglitazone.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
12 Repaglinide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
13 Nateglinide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
14 Acarbose.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
15 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 5 or 15
17 4 and 16
18 exp Angiotensin-Converting Enzyme Inhibitors/
19 exp Angiotensin II/
20 exp Receptors, Angiotensin/ai [Antagonists & Inhibitors]
21 19 and 20
22 exp Angiotensin II Type 1 Receptor Block
23 21 or 22
24 exp Calcium Channel Blockers/
25 exp antihypertensive agents/
26 18 or 23 or 24 or 25
27 4 and 26
28 exp Hydroxymethylglutaryl CoA Reductases/
29 Lovastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
30 Pravastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
31 Fluvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
32 Atorvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
33 Rosuvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
34 29 or 30 or 31 or 32 or 33
35 28 or 34
36 4 and 35
37 exp Antilipemic Agents/
38 Gemfibrozil.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
39 Fenofibrate.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
40 Nicotinic Acid.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
41 Cholestyramine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
42 Colestipol.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
43 Colesevelam.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
44 Ezetimibe.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
45 38 or 39 or 40 or 41 or 42 or 43 or 44
46 37 or 45
47 4 and 46
48 exp Aspirin/
49 4 and 48
50 exp Life Style/
51 4 and 50
52 exp Exercise/ or exp Exercise Movement Techniques/
53 exp Physical Fitness/
54 52 or 53
55 4 and 54
56 exp Gastric Bypass/
57 exp gastroplasty/
58 exp obesity/su
59 56 or 57 or 58
60 4 and 59
61 exp anti-obesity agents/
62 exp obesity/dt
63 orlistat.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
64 sibutramine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
65 fluoxetine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
66 61 or 62 or 63 or 64 or 65
67 4 and 66
68 exp Counseling/
69 4 and 68
70 exp Patient Education/
71 4 and 70
72 exp Foot Diseases/nu, pc, dh, dt, rh, su, tu [Nursing, Prevention & Control, Diet Therapy, Drug Therapy, Rehabilitation, Surgery, Therapeutic Use]
73 footcare.mp.
74 ((foot or feet or toe or toes or heel or plantar) adj5 (care or cares or caring or cared)).mp.
75 72 or 73 or 74
76 4 and 75
77 (200109$ or 20011$ or 2002$ or 2003$ or 2004$ or 2005$ or 2006$).ed.
78 17 and 77
79 27 and 77
80 36 and 77
81 47 not 36
82 77 and 81
83 49 and 77
84 51 and 77
85 55 and 77
86 60 and 77
87 67 and 77
88 69 and 77
89 71 and 77
90 76 and 77
91 randomized controlled trial.pt.
92 controlled clinical trial.pt.
93 randomized controlled trials/
94 random allocation/
95 double-blind method/
96 single blind method/
97 91 or 92 or 93 or 94 or 95 or 96
98 animal/ not human/
99 97 not 98
100 clinical trial.pt.
101 (clinic$ adj25 trial$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
102 exp Clinical Trials/
103 ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
104 exp Placebos/
105 placebo$.mp.)
106 random$.mp.
107 Research Design/
108 (latin adj square).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
109 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108
110 109 not 98
111 110 not 99
112 99 or 111
113 78 and 112
114 79 and 112
115 80 and 112
116 82 and 112
117 83 and 112
118 84 and 112
119 85 and 112
120 86 and 112
121 87 and 112
122 88 and 112
123 89 and 112
124 90 and 112
125 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124
126 limit 125 to english language
127 limit 125 to abstracts
128 126 or 127
129 limit 128 to yr=“2001 - 2007”

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Diabetes Mellitus, type II/
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, original title, abstract, name of substance word, subject heading word])
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
4 1 or 2 or 3
5 exp Hypoglycemic Agents/
6 Glipizide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 Glyburide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 Glimepiride.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
9 Metformin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
10 Rosiglitazone.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
11 Pioglitazone.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
12 Repaglinide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
13 Nateglinide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
14 Acarbose.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
15 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 5 or 15
17 4 and 16
18 exp Angiotensin-Converting Enzyme Inhibitors/
19 exp Angiotensin II/
20 exp Receptors, Angiotensin/ai [Antagonists & Inhibitors]
21 19 and 20
22 exp Angiotensin II Type 1 Receptor Blockers/
23 21 or 22
24 exp Calcium Channel Blockers/
25 exp antihypertensive agents/
26 18 or 23 or 24 or 25
27 4 and 26
28 exp Hydroxymethylglutaryl CoA Reductases/
29 Lovastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
30 Pravastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
31 Fluvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
32 Atorvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
33 Rosuvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
34 29 or 30 or 31 or 32 or 33
35 28 or 34
36 4 and 35
37 exp Antilipemic Agents/
38 Gemfibrozil.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
39 Fenofibrate.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
40 Nicotinic Acid.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
41 Cholestyramine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
42 Colestipol.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
43 Colesevelam.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
44 Ezetimibe.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
45 38 or 39 or 40 or 41 or 42 or 43 or 44
46 37 or 45
47 4 and 46
48 exp Aspirin/
49 4 and 48
50 exp Life Style/
51 4 and 50
52 exp Exercise/ or exp Exercise Movement Techniques/
53 exp Physical Fitness/
54 52 or 53
55 4 and 54
56 exp Gastric Bypass/
57 exp gastroplasty/
58 exp obesity/su
59 56 or 57 or 58
60 4 and 59
61 exp anti-obesity agents/
62 exp obesity/dt
63 orlistat.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
64 sibutramine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
65 fluoxetine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
66 61 or 62 or 63 or 64 or 65
67 4 and 66
68 exp Counseling/
69 4 and 68
70 exp Patient Education/
71 4 and 70
72 exp Foot Diseases/nu, pc, dh, dt, rh, su, tu [Nursing, Prevention & Control, Diet Therapy, Drug Therapy, Rehabilitation, Surgery, Therapeutic Use]
73 footcare.mp.
74 ((foot or feet or toe or toes or heel or plantar) adj5 (care or cares or caring or cared)).mp.
75 72 or 73 or 74
76 4 and 75
77 (200109$ or 20011$ or 2002$ or 2003$ or 2004$ or 2005$ or 2006$).ed.
78 17 and 77
79 27 and 77
80 36 and 77
81 47 not 36
82 77 and 81
83 49 and 77
84 51 and 77
85 55 and 77
86 60 and 77
87 67 and 77
88 69 and 77
89 71 and 77
90 76 and 77
91 randomized controlled trial.pt.
92 controlled clinical trial.pt.
93 randomized controlled trials/
94 random allocation/
95 double-blind method/
96 single blind method/
97 91 or 92 or 93 or 94 or 95 or 96
98 animal/ not human/
99 97 not 98
100 clinical trial.pt.
101 (clinic$ adj25 trial$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
102 exp Clinical Trials/
103 ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word])
104 exp Placebos/
105 placebo$.mp.
106 random$.mp.
107 Research Design/
108 (latin adj square).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
109 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108
110 109 not 98
111 110 not 99
112 99 or 111
113 78 and 112
114 79 and 112
115 80 and 112
116 82 and 112
117 83 and 112
118 84 and 112
119 85 and 112
120 86 and 112
121 87 and 112
122 88 and 112
123 89 and 112
124 90 and 112
1 125 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 126 limit 125 to english language
127 limit 125 to abstracts
128 126 or 127
129 limit 128 to yr=“2001 - 2003”
130 limit 128 to yr=“2004 - 2007”

Database: Ovid MEDLINE(R)

Search Strategy:

1 exp Diabetes Mellitus, type II/
2 (impair$ adj3 (fasting glucose or glucose tolerance)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3 (prediabet$ or pre-diabet$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
4 1 or 2 or 3
5 exp Hypoglycemic Agents/
6 Glipizide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 Glyburide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 Glimepiride.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
9 Metformin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
10 Rosiglitazone.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
11 Pioglitazone.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
12 Repaglinide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
13 Nateglinide.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
14 Acarbose.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
15 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 5 or 15
17 4 and 16
18 exp Angiotensin-Converting Enzyme Inhibitors/
19 exp Angiotensin II/
20 exp Receptors, Angiotensin/ai [Antagonists & Inhibitors]
21 19 and 20
22 exp Angiotensin II Type 1 Receptor Blockers/
23 21 or 22
24 exp Calcium Channel Blockers/
25 exp antihypertensive agents/
26 18 or 23 or 24 or 25
27 4 and 26
28 exp Hydroxymethylglutaryl CoA Reductases/
29 Lovastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
30 Pravastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
31 Fluvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
32 Atorvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
33 Rosuvastatin.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
34 29 or 30 or 31 or 32 or 33
35 28 or 34
36 4 and 35
37 exp Antilipemic Agents/
38 Gemfibrozil.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
39 Fenofibrate.mp. [mp=title, original title, abstract, name of substance word, subject heading word] (
40 Nicotinic Acid.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
41 Cholestyramine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
42 Colestipol.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
43 Colesevelam.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
44 Ezetimibe.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
45 38 or 39 or 40 or 41 or 42 or 43 or 44
46 37 or 45
47 4 and 46
48 exp Aspirin/
49 4 and 48
50 exp Life Style/
51 4 and 50
52 exp Exercise/ or exp Exercise Movement Techniques/
53 exp Physical Fitness/
54 52 or 53
55 4 and 54
56 exp Gastric Bypass/
57 exp gastroplasty/
58 exp obesity/su
59 56 or 57 or 58
60 4 and 59
61 exp anti-obesity agents/
62 exp obesity/dt
63 orlistat.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
64 sibutramine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
65 fluoxetine.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
66 61 or 62 or 63 or 64 or 65
67 4 and 66
68 exp Counseling/
69 4 and 68
70 exp Patient Education/
71 4 and 70
72 exp Foot Diseases/nu, pc, dh, dt, rh, su, tu [Nursing, Prevention & Control, Diet Therapy, Drug Therapy, Rehabilitation, Surgery, Therapeutic Use]
73 footcare.mp.
74 ((foot or feet or toe or toes or heel or plantar) adj5 (care or cares or caring or cared)).mp.
75 72 or 73 or 74
76 4 and 75
77 (200109$ or 20011$ or 2002$ or 2003$ or 2004$ or 2005$ or 2006$).ed.
78 17 and 77
79 27 and 77
80 36 and 77
81 47 not 36
82 77 and 81
83 49 and 77
84 51 and 77
85 55 and 77
86 60 and 77
87 67 and 77
88 69 and 77
89 71 and 77
90 76 and 77
91 randomized controlled trial.pt.
92 controlled clinical trial.pt.
93 randomized controlled trials/
94 random allocation/
95 double-blind method/
96 single blind method/
97 91 or 92 or 93 or 94 or 95 or 96
98 animal/ not human/
99 97 not 98
100 clinical trial.pt.
101 (clinic$ adj25 trial$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
102 exp Clinical Trials/
103 ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
104 exp Placebos/
105 placebo$.mp.
106 random$.mp.
107 Research Design/
108 (latin adj square).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
109 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 10
110 109 not 98
111 110 not 99
112 99 or 111
113 78 and 112
114 79 and 112
115 80 and 112
116 82 and 112
117 83 and 112
118 84 and 112
119 85 and 112
120 86 and 112
121 87 and 112
122 88 and 112
123 89 and 112
124 90 and 112
125 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124
126 limit 125 to english language
127 limit 125 to abstracts
128 126 or 127
130 limit 128 to yr=“2004 - 2007”
131 128 not (129 or 130)

## Appendix C2. Inclusion And Exclusion Criteria For Key Questions

### Population

Study participants were aged 18 years or older with DM2 (type 2 diabetes) or prediabetes. Persons labeled as “non-insulin dependent diabetes” were assumed to have DM2. The acceptable diagnostic criteria for DM2 included those of the National Diabetes Data Group Standards, ^1^ the World Health Organization, ^2,^ ^3^ or the American Diabetes Association. ^4^ If the criteria for diagnosis of DM2 were not given in a study, the authors' statement of the diagnosis among participants was accepted.

Prediabetes was defined as either or both of IFG (impaired fasting glucose) or IGT (impaired glucose tolerance). ^5^ IFG is defined as a fasting plasma glucose ≥ 100 and <126 mg/dl and IGT as random glucose ≥ 140 and <200 mg/dl. ^5^ The lower threshold for IFG was changed in 2003 from 110 mg/dl to 100 mg/dl; ^6^ either definition was included in our review.

As the purpose of examining treatment interventions among persons with DM2 was to indirectly address the question of whether knowledge of the diagnosis of diabetes would change clinical management because effective interventions were available after diagnosis, we focused on intervention studies where the populations were either screen-detected or newly diagnosed (defined as a clinical diagnosis in the last 12 months). We felt that examination of persons with diabetes for short duration was important as the lower glycemic levels and rates of cardiovascular risk factors among these persons were more readily extrapolated to a screen-detected population. For intervention studies comparing DM2 to nondiabetic populations, we did not restrict duration of disease as we wanted to determine if there were any differences in treatment approaches between these two populations.

### Setting

As in most USPSTF (US Preventive Services Task Force reviews), ^7^ we focused on traditional primary care settings as well as other clinical settings where general populations obtain primary care (e.g., urgent care facilities, emergency rooms, nursing homes, work-site and school clinics, etc.). Interventions involved a variety of health care providers, including physicians, dieticians, nurses, and other ancillary staff. In-patient interventions and interventions delivered by specialty providers were, in general, excluded. However, large and important clinical trials that were delivered by specialists were included if we felt that the intervention could also be delivered in the primary care setting. We felt that such critical studies must be considered as part of the body of evidence upon which to make recommendations.

### Study Design

For Key Questions examining direct evidence for screening programs and the adverse effects of screening (Key Questions #1 and #4), we included studies of any design as we anticipated a paucity of trial evidence and we wanted to examine as broad a literature as possible. We confined our review of intervention effectiveness (Key Questions #2 and #3) to RCTs (randomized controlled trials) and controlled clinical trials, the latter defined as studies where the investigator assigned exposure to the intervention in a non-randomized fashion. There is a large volume of literature on the efficacy and effectiveness of diabetes treatments and we therefore chose to limit our review of treatment interventions to study designs with the lowest inherent risk of bias.

We focused generally on placebo or usual care comparators, rather than active-control or head-to-head trials. Studies comparing one treatment approach to another among persons with DM2 do not inform the question of whether it is beneficial to have knowledge of whether a person has diabetes or not. For example, studies were excluded that compared one insulin regime to another. Similarly, diet and physical activity counseling interventions were excluded if they compared one type of diet or counseling approach to another. However, for studies comparing diabetic to nondiabetic populations, we also included head-to-head trials as they inform the question of whether persons with diabetes should be treated with different drugs than persons without diabetes.

Adverse effects of treatment (Key Question #5) were reviewed using data from included studies. For interventions that were considered by the authors to be potentially critically important to the decision-making process of the USPSTF, we looked for recent, fair- or high-quality systematic reviews on the adverse effects of these interventions.

### Interventions

A variety of treatment interventions were examined in this review (Figure 2, the Analytic Framework) to address the question of whether knowledge of diabetes (either through screening or from clinical presentation) followed by appropriate treatment, would improve health outcomes. All interventions among persons with diabetes were subject to the inclusion criteria of disease duration (either screen-detected or duration ≤ 1 year), as discussed above. Person with prediabetes are, by definition, screen-detected, so no duration of disease was relevant for interventions among this population.

For populations with diabetes, we included interventions which focused on treatments for known risk factors for cardiovascular and cerebrovascular disease (hyperlipidemia and hypertension), treatments optimizing glycemic control, the management and prevention of progression of potential diabetes complications (foot care, counseling for improved diet and physical activity levels), and health care system interventions that manage diabetes and related complications and comorbidities (disease management and multicomponent interventions at the system level). We excluded general diabetes education interventions, interventions focused on self-monitoring of blood glucose, interventions focused on optimal medication usage (most commonly insulin), and complementary and alternative medicines and approaches. These interventions were felt to be beyond the scope of the review, they primarily report intermediate outcomes, and their relationship to distal health outcomes is unclear.

For prediabetes, we included interventions which potentially diminish or delay the progression to diabetes, as well as interventions which minimize cardiovascular and cerebrovascular risk factors, including both lifestyle interventions or pharmacotherapy.

Interventions focused on tight versus usual glycemic control in screen-detected DM2 populations or in persons with disease duration ≤ 1 year were included as these interventions indirectly inform the question of whether knowledge of diabetes will alter treatment and therefore improve outcomes. Therapy for different blood pressure and lipid targets were also included in screen-detected or recently diagnosed populations, for similar reasons.

Various comparisons were examined for DM2 treatment studies. We included studies which compared the treatment effect of an intervention in persons with screen-detected DM2 to the effect in persons with clinically-detected diabetes. Studies were also included which compared intervention effect or safety between persons with diabetes and normoglycemic populations. Such studies answer the question as to whether knowledge of diabetes will alter choice of treatment approach. Here we included studies where duration of diabetes was greater than one year or where duration was unknown, recognizing that some caution is needed in extrapolating from populations with longer duration diabetes to screen-detected persons. Comparisons of diabetic and nondiabetic populations across studies were not included in this review as it was considered too difficult to control for potential confounding across studies.

Combination therapy (where both the treatment and control groups received identical therapy [of one or more drugs] in addition to either the study drug or placebo) for glycemic control or for lipid and blood pressure management were also included if participants had diabetes for ≤ 1 year. When an additional drug for a new indication was added to an existing drug treatment regime (e.g., an antihypertensive drug for newly-diagnosed hypertension in a study population already using one or more hypoglycemic agents), these studies were also included, again subject to the inclusion criteria of diagnosis during the last 1 year.

Multicomponent health care system and clinical practice interventions aimed at the primary care setting were included, as long as they reported final health outcomes. In view of the large value of literature available, we used a recent, high-quality systematic review of quality improvement and disease management strategies, updating their literature search (dated April, 2006) using Shojania and colleagues' search strategy. ^8^

Studies of diabetes and prediabetes treatments as well as studies of screening interventions that are in progress (i.e., final health outcomes data have not yet been published) at the time of our final searches are presented in tabulated form with the anticipated date of completion. These studies will include persons with diabetes of any duration, as awareness of these studies may be useful to the reader and duration data (if not an inclusion criteria) may not yet be available.

### Outcomes

This review focuses primarily on final health outcomes (Figure 2, the Analytic Framework) as the USPSTF does not generally base recommendations on intermediate outcomes. For studies of persons with prediabetes, we examined the intermediate outcome of incidence of DM2, as this outcome is usually a primary one for these studies, and the important and emerging literature on treatment for prediabetes does not, for the most part, yet encompass long-term health outcomes.

The final health outcomes that we examined included cardiovascular morbidity, symptomatic neuropathy, non-healing ulcers, lower extremity amputations, stage IV (glomerular filtration rate 15–29 mg/min) and V (patients on renal replacement therapy or with a glomerular filtration rate of <15 ml/min) chronic kidney disease, severe visual impairment, mortality, and quality of life.

### Mathematical Modeling

In the absence of direct evidence on the effectiveness of screening or treatment of newly-diagnosed DM2, researchers have applied mathematical models to attempt to answer these questions. Such models are useful to assess effectiveness and efficiency when trials are infeasible or long-term outcomes are not available. ^9^ We searched systematically for publications examining the health outcomes of interest to us using models of either screening for DM2 or prediabetes, or treatment of newly-diagnosed DM2. We also consulted experts in the economics of diabetes screening to locate any additional studies.

### References for Appendix C2

1 National Diabetes Data Group. Classification and diagnosis of diabetes mellitus and other categories of glucose intolerance. Diabetes. 1979;28:1039-1057. [pmid: 510803].
2 World Health Organization. WHO Expert Committee on Diabetes Mellitus. World Health Organization Technical Report 1980.
3 Alberti K, Zimmet P. Definition, diagnosis and classification of diabetes mellitus and it complications. Part I: diagnosis and classification of diabetes mellitus. Diabetic Med. 1998;15:539-553. [pmid: 9686693].
4 American Diabetes Association. Screening for type 2 diabetes. Diabetes Care. 1998;21(Supp 1):S20-22.
5 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2007;30(Supp 1):S42-47. [pmid: 17192378].
6 Genuth S, Alberti KG, Bennett P, et al. Follow-up report on the diagnosis of diabetes mellitus. Diabetes Care. 2003;26(11):3160-3167. [pmid: 14578255].
7 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35.
8 Shojania KG, Ranji SR, McDonald KM, et al. Effects of quality improvement strategies for type 2 diabetes on glycemic control: a meta-regression analysis. JAMA. 2006;296(4):427-440. [pmid: 16868301].
9 Glumer C, Yuyun M, Griffin S, et al. What determines the cost-effectiveness of diabetes screening?. Diabetologia. 2006;49(7):1536-1544. [pmid: 16752172].

## Appendix C3. U.S. Preventive Services Task Force Quality Rating Criteria For Rcts And Observational Studies^*^ *Reference: Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001:20(3S);21–35.

DIAGNOSTIC ACCURACY STUDIES

Criteria:

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test

Definition of ratings based on above criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

RANDOMIZED CONTROLLED TRIALS (RCTS) AND COHORT STUDIES

Criteria:

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intension-to-treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.

Poor: Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

CASE CONTROL STUDIES

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

Definition of ratings based on criteria above:

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

## Appendix C4. Quality Rating Criteria For Systematic Reviews * *References: National Institute for Health and Clinical Excellence. The Guidelines Manual. London: Institute for Health and Clinical Excellence; 2006. Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271–8.

1 Comprehensiveness of sources/search strategy used:
  a Were search terms reported?
  b Was the search comprehensive (Medline, search reference lists and/ or experts)?
  c Were the search terms applicable?
2 Standard appraisal of included studies:
  a Were inclusion/exclusion criteria reported?
  b Are criteria valid?
3 Quality/validity assessment:
  a Were criteria for validity/quality assessment explicit and applied to all studies?
  b Were quality criteria appropriate (e.g. criteria appropriate for study design)?
4 Analysis/synthesis:
  a Were methods used to combine studies reported?
  b Were studies that were combined similar to one another (e.g. appropriate to combine, similar patient populations etc)?
5 Validity of conclusions:
  a Were conclusions supported by the data?
6 Recency and relevance:
  a Is the study recent and relevant to scope?
7 Application to practice:
  a Are your patients largely different from patients in this study?
  b Is this feasible in your setting?

## Appendix C5. Expert Reviewers

Ann Albright, PhD, RD

Director, Division of Diabetes Translation, Centers for Disease Control and Prevention

Alison Avenell, MD, MB BS, MSc, BSc

Career Scientist, Health Services Research Unit, University of Aberdeen, Foresterhill, Scotland

Michael M. Engelgau, MD, MS

Senior Public Health Specialist, South Asia Human Development Unit, World Bank

Richard Kahn, PhD

Chief Scientific and Medical Officer, American Diabetes Association

Linda Kinsinger, MD, MPH

Director, VA National Center for Health Promotion and Disease Prevention

Leonard Pogach, MD, MBA

National Program Director, Diabetes VA New Jersey Health Care System

Diabetes Treatment Studies with a Duration of Diabetes > 1 Year

## Appendix C6 Flow Diagram of Literature Evaluated for Inclusion

[image]

## Appendix C7. Excluded Studies

### Diabetes Treatment Studies with a Duration of Diabetes > 1 Year

Aas AM, Bergstad I, Thorsby PM, et al. An intensified lifestyle intervention programme may be superior to insulin treatment in poorly controlled Type 2 diabetic patients on oral hypoglycaemic agents: results of a feasibility study. Diabet Med. 2005;22(3):316-322. [pmid: 15717881].
Abraira C, Duckworth W, McCarren M, et al. Design of the cooperative study on glycemic control and complications in diabetes mellitus type 2: Veterans Affairs Diabetes Trial. J Diabetes Complications. 2003;17(6):314-322. [pmid: 14583175].
ADVANCE Collaborative Group. Rationale and design of the ADVANCE study: a randomised trial of blood pressure lowering and intensive glucose control in high-risk individuals with type 2 diabetes mellitus. Action in Diabetes and Vascular Disease: PreterAx and DiamicroN Modified-Release Controlled Evaluation. J Hypertens Suppl. 2001;19(4):S21-28.
ADVANCE Collaborative Group. ADVANCE—Action in Diabetes and Vascular Disease: patient recruitment and characteristics of the study population at baseline. Diabet Med. 2005;22(7):882-888. [pmid: 15975103].
ADVANCE Management Committee. Study rationale and design of ADVANCE: action in diabetes and vascular disease—preterax and diamicron MR controlled evaluation. Diabetologia. 2001;44(9):1118-1120. [pmid: 11596665].
Alexander CM, Lyle PA, Keane WF, et al. Losartan and the United States costs of end-stage renal disease by baseline albuminuria in patients with type 2 diabetes and nephropathy. Kidney Int Suppl. 2004(92):S115–117.
Andersen S, Brochner-Mortensen J, Parving HH, et al. Kidney function during and after withdrawal of long-term irbesartan treatment in patients with type 2 diabetes and microalbuminuria. Diabetes Care. 2003;26(12):3296-3302. [pmid: 14633817].
Ansquer JC, Foucher C, Rattier S, et al. Fenofibrate reduces progression to microalbuminuria over 3 years in a placebo-controlled study in type 2 diabetes: results from the Diabetes Atherosclerosis Intervention Study (DAIS). Am J Kidney Dis. 2005;45(3):485-493. [pmid: 15754270].
Appel GB, Radhakrishnan J, Avram MM, et al. Analysis of metabolic parameters as predictors of risk in the RENAAL study. Diabetes Care. 2003;26(5):1402-1407. [pmid: 12716796].
Arredondo A, Burke TA, Carides GW, et al. The impact of losartan on the lifetime incidence of ESRD and costs in Mexico. Rev Invest Clin. 2005;57(3):399-405. [pmid: 16187699].
Atkins RC, Briganti EM, Lewis JB, et al. Proteinuria reduction and progression to renal failure in patients with type 2 diabetes mellitus and overt nephropathy. Am J Kidney Dis. 2005;45(2):281-287. [pmid: 15685505].
Atli A, Dogra S. Zonisamide in the treatment of painful diabetic neuropathy: a randomized, double-blind, placebo-controlled pilot study. Pain Med. 2005;6(3):225-234. [pmid: 15972086].
Bailey CJ. Fenofibrate and cardiovascular risk: a synopsis and commentary on (FIELD). Diabet Med. 2006;23(2):109-112. [pmid: 16433706].
Bakris GL, Weir MR, Shanifar S, et al. Effects of blood pressure level on progression of diabetic nephropathy: results from the RENAAL study. Arch Intern Med. 2003;163(13):1555-1565. [pmid: 12860578].
Barnett AH, Grant PJ, Hitman GA, et al. Rosiglitazone in Type 2 diabetes mellitus: an evaluation in British Indo-Asian patients. Diabet Med. 2003;20(5):387-393. [pmid: 12752488].
Bech P, Moses R, Gomis R. The effect of prandial glucose regulation with repaglinide on treatment satisfaction, wellbeing and health status in patients with pharmacotherapy naive Type 2 diabetes: a placebo-controlled, multicentre study. Qual Life Res. 2003;12(4):413-425. [pmid: 12797714].
Beck RW, Moke PS, Turpin AH, et al. A computerized method of visual acuity testing: adaptation of the early treatment of diabetic retinopathy study testing protocol. Am J Ophthalmol. 2003;135(2):194-205. [pmid: 12566024].
Becker A, van der Does FE, van Hinsbergh VW, et al. Improvement of glycaemic control in type 2 diabetes: favourable changes in blood pressure, total cholesterol and triglycerides, but not in HDL cholesterol, fibrinogen, Von Willebrand factor and (pro)insulin. Neth J Med. 2003;61(4):129-136. [pmid: 12852722].
Beishuizen ED, Jukema JW, Tamsma JT, et al. No effect of statin therapy on silent myocardial ischemia in patients with type 2 diabetes without manifest cardiovascular disease. Diabetes Care. 2005;28(7):1675-1679. [pmid: 15983319].
BENEDICT Group. The BErgamo NEphrologic DIabetes Complications Trial (BENEDICT): design and baseline characteristics. Control Clin Trials. 2003;24(4):442-461. [pmid: 12865039].
Berl T, Hunsicker LG, Lewis JB, et al. Cardiovascular outcomes in the Irbesartan Diabetic Nephropathy Trial of patients with type 2 diabetes and overt nephropathy. Ann Intern Med. 2003;138(7):542-549. [pmid: 12667024].
Boner G, Cooper ME, McCarroll K, et al. Adverse effects of left ventricular hypertrophy in the reduction of endpoints in NIDDM with the angiotensin II antagonist losartan (RENAAL) study. Diabetologia. 2005;48(10):1980-1987. [pmid: 16082528].
Brenner BM, Cooper ME, de Zeeuw D, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. N Engl J Med. 2001;345(12):861-869. [pmid: 11565518].
Brenner BM, Cooper ME, de Zeeuw D, et al. The losartan renal protection study—rationale, study design and baseline characteristics of RENAAL (Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan). J Renin Angiotensin Aldosterone Syst. 2000;1(4):328-335. [pmid: 11967819].
Brocco E, Velussi M, Cernigoi AM, et al. Evidence of a threshold value of glycated hemoglobin to improve the course of renal function in type 2 diabetes with typical diabetic glomerulopathy. J Nephrol. 2001;14(6):461-471. [pmid: 11783602].
Burgess ED, Carides GW, Gerth WC, et al. Losartan reduces the costs associated with nephropathy and end-stage renal disease from type 2 diabetes: Economic evaluation of the RENAAL study from a Canadian perspective. Can J Cardiol. 2004;20(6):613-618. [pmid: 15152291].
California Medi-Cal Type 2 Diabetes Study Group. Closing the gap: effect of diabetes case management on glycemic control among low-income ethnic minority populations: the California Medi-Cal type 2 diabetes study. Diabetes care. 2004;27(1):95-103. [pmid: 14693973].
Carides GW, Shahinfar S, Dasbach EJ, et al. The impact of losartan on the lifetime incidence of end-stage renal disease and costs in patients with type 2 diabetes and nephropathy. Pharmacoeconomics. 2006;24(6):549-558. [pmid: 16761903].
Carr AA, Kowey PR, Devereux RB, et al. Hospitalizations for new heart failure among subjects with diabetes mellitus in the RENAAL and LIFE studies. Am J Cardiol. 2005;96(11):1530-1536. [pmid: 16310435].
Chalmers J, Perkovic V, Joshi R, et al. ADVANCE: breaking new ground in type 2 diabetes. J Hypertens Suppl. 2006;24(5):S22-28. [pmid: 16936533].
Chan JC, Wat NM, So WY, et al. Renin angiotensin aldosterone system blockade and renal disease in patients with type 2 diabetes. An Asian perspective from the RENAAL Study. Diabetes Care. 2004;27(4):874-879. [pmid: 15047641].
Charbonnel B, Dormandy J, Erdmann E, et al. The prospective pioglitazone clinical trial in macrovascular events (PROactive): can pioglitazone reduce cardiovascular events in diabetes? Study design and baseline characteristics of 5238 patients. Diabetes Care. 2004;27(7):1647-1653. [pmid: 15220241].
Chiasson JL, Josse RG, Hunt JA, et al. The efficacy of acarbose in the treatment of patients with non-insulin-dependent diabetes mellitus. A multicenter controlled clinical trial. Ann Intern Med. 1994;121(12):928-935. [pmid: 7734015].
Chiasson JL, Naditch L. The synergistic effect of miglitol plus metformin combination therapy in the treatment of type 2 diabetes. Diabetes care. 2001;24(6):989-994. [pmid: 11375358].
Choi D, Kim SK, Choi SH, et al. Preventative effects of rosiglitazone on restenosis after coronary stent implantation in patients with type 2 diabetes. Diabetes Care. 2004;27(11):2654-2660. [pmid: 15505001].
Colhoun HM, Betteridge DJ, Durrington PN, et al. Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet. 2004;364(9435):685-696. [pmid: 15325833].
Colhoun HM, Betteridge DJ, Durrington PN, et al. Rapid emergence of effect of atorvastatin on cardiovascular outcomes in the Collaborative Atorvastatin Diabetes Study (CARDS). Diabetologia. 2005;48(12):2482-2485. [pmid: 16284747].
Coyle JD, Gardner SF, White CM. The renal protective effects of angiotensin II receptor blockers in type 2 diabetes mellitus. Ann Pharmacother. 2004;38(10):1731-1738. [pmid: 15353571].
Cryer DR, Nicholas SP, Henry DH, et al. Comparative outcomes study of metformin intervention versus conventional approach the COSMIC Approach Study. Diabetes Care. 2005;28(3):539-543. [pmid: 15735184].
Cullen JF, Town SM, Campbell CJ. Double-blind trial of Atromid-S in exudative diabetic retinopathy. Trans Ophthalmol Soc U K. 1974;94(2):554-562. [pmid: 4619857].
Cusick M, Meleth AD, Agron E, et al. Associations of mortality and diabetes complications in patients with type 1 and type 2 diabetes: early treatment diabetic retinopathy study report no. 27. Diabetes care. 2005;28(3):617-625. [pmid: 15735198].
de Zeeuw D, Remuzzi G, Parving HH, et al. Proteinuria, a target for renoprotection in patients with type 2 diabetic nephropathy: lessons from RENAAL. Kidney Int. 2004;65(6):2309-2320. [pmid: 15149345].
Del Prato S, Heine RJ, Keilson L, et al. Treatment of patients over 64 years of age with type 2 diabetes: experience from nateglinide pooled database retrospective analysis. Diabetes Care. 2003;26(7):2075-2080. [pmid: 12832316].
Derosa G, Cicero AF, Bertone G, et al. Comparison of the effects of telmisartan and nifedipine gastrointestinal therapeutic system on blood pressure control, glucose metabolism, and the lipid profile in patients with type 2 diabetes mellitus and mild hypertension: a 12-month, randomized, double-blind study. Clin Ther. 2004;26(8):1228-1236. [pmid: 15476904].
Diabetes Atherosclerosis Intervention Study Investigators. Effect of fenofibrate on progression of coronary-artery disease in type 2 diabetes: the Diabetes Atherosclerosis Intervention Study, a randomised study. Lancet. 2001;357(9260):905-910. [pmid: 11289345].
Diabetes Atorvastin Lipid Intervention Study Group. The effect of aggressive versus standard lipid lowering by atorvastatin on diabetic dyslipidemia: the DALI study: a double-blind, randomized, placebo-controlled trial in patients with type 2 diabetes and diabetic dyslipidemia. Diabetes Care. 2001;24(8):1335-1341. [pmid: 11473066].
Didangelos TP, Thanopoulou AK, Bousboulas SH, et al. The ORLIstat and CArdiovascular risk profile in patients with metabolic syndrome and type 2 DIAbetes (ORLICARDIA) Study. Curr Med Res Opin. 2004;20(9):1393-1401. [pmid: 15383188].
Dormandy JA, Charbonnel B, Eckland DJ, et al. Secondary prevention of macrovascular events in patients with type 2 diabetes in the PROactive Study (PROspective pioglitAzone Clinical Trial In macroVascular Events): a randomised controlled trial. Lancet. 2005;366(9493):1279-1289. [pmid: 16214598].
Duckworth WC, McCarren M, Abraira C, et al. Control of cardiovascular risk factors in the Veterans Affairs Diabetes Trial in advanced type 2 diabetes. Endocr Pract. 2006;12(Suppl 1):85-88. [pmid: 16627388].
Elkeles RS, Diamond JR, Poulter C, et al. Cardiovascular outcomes in type 2 diabetes. A double-blind placebo-controlled study of bezafibrate: the St. Mary's, Ealing, Northwick Park Diabetes Cardiovascular Disease Prevention (SENDCAP) Study. Diabetes Care. 1998;21(4):641-648. [pmid: 9571357].
Endo K, Miyashita Y, Sasaki H, et al. Probucol delays progression of diabetic nephropathy. Diabetes Res Clin Pract. 2006;71(2):156-163. [pmid: 16009446].
Keech A, Simes RJ. FIELD Study Investigators, et al. Effects of long-term fenofibrate therapy on cardiovascular events in 9795 people with type 2 diabetes mellitus (the FIELD study): randomised controlled trial. Lancet. 2005;366(9500):1849-1861. [pmid: 16310551].
Scott R, Best J. FIELD Study Investigators, et al. Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study: baseline characteristics and short-term effects of fenofibrate. Cardiovascular Diabetology. 2005;4(0):13. [pmid: 16111499]. [pmcid: 1266033].
Gaede P, Beck M, Vedel P, et al. Limited impact of lifestyle education in patients with Type 2 diabetes mellitus and microalbuminuria: results from a randomized intervention study. Diabet Med. 2001;18(2):104-108. [pmid: 11251672].
Gaede P, Vedel P, Larsen N, et al. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003;348(5):383-393. [pmid: 12556541].
Gerth WC, Remuzzi G, Viberti G, et al. Losartan reduces the burden and cost of ESRD: Public health implications from the RENAAL Study for the European Union. Kidney Int Suppl. 2002;62(82):S68-S72.
Goldstein DJ, Lu Y, Detke MJ, et al. Duloxetine vs. placebo in patients with painful diabetic neuropathy. Pain. 2005;116(12):109-118. [pmid: 15927394].
Hanefeld M, Cagatay M, Petrowitsch T, et al. Acarbose reduces the risk for myocardial infarction in type 2 diabetic patients: meta-analysis of seven long-term studies. Eur Heart J. 2004;25(1):10-16. [pmid: 14683737].
Harmankaya O, Seber S, Yilmaz M. Combination of pentoxifylline with angiotensin converting enzyme inhibitors produces an additional reduction in microalbuminuria in hypertensive type 2 diabetic patients. Renal Failure. 2003;25(3):465-470. [pmid: 12803510].
Havranek EP, Esler A, Estacio RO, et al. Differential effects of antihypertensive agents on electrocardiographic voltage: results from the Appropriate Blood Pressure Control in Diabetes (ABCD) trial. Am Heart J. 2003;145(6):993-998. [pmid: 12796754].
Herman WH, Shahinfar S, Carides GW, et al. Losartan reduces the costs associated with diabetic end-stage renal disease: the RENAAL study economic evaluation. Diabetes Care. 2003;26(3):683-687. [pmid: 12610022].
Herz M, Johns D, Reviriego J, et al. A randomized, double-blind, placebo-controlled, clinical trial of the effects of pioglitazone on glycemic control and dyslipidemia in oral antihyperglycemic medication-naive patients with type 2 diabetes mellitus. Clin Ther. 2003;25(4):1074-1095. [pmid: 12809958].
Jerums G, Allen TJ, Campbell DJ, et al. Long-term renoprotection by perindopril or nifedipine in non-hypertensive patients with Type 2 diabetes and microalbuminuria. Diabet Med. 2004;21(11):1192-1199. [pmid: 15498085].
Johnson BF, Nesto RW, Pfeifer MA, et al. Cardiac abnormalities in diabetic patients with neuropathy: effects of aldose reductase inhibitor administration. Diabetes care. 2004;27(2):448-454. [pmid: 14747227].
Jones H, Edwards L, Vallis TM, et al. Changes in diabetes self-care behaviors make a difference in glycemic control: the Diabetes Stages of Change (DiSC) study. Diabetes Care. 2003;26(3):732-737. [pmid: 12610030].
Joss N, Ferguson C, Brown C, et al. Intensified treatment of patients with type 2 diabetes mellitus and overt nephropathy. Qjm. 2004;97(4):219-227. [pmid: 15028852].
Kaukua JK, Pekkarinen TA, Rissanen AM. Health-related quality of life in a randomised placebo-controlled trial of sibutramine in obese patients with type II diabetes. Int J Obes Relat Metab Disord. 2004;28(4):600-605. [pmid: 14770192].
Keane WF, Lyle PA. Reduction of Endpoints in NwtAIIRALs. Recent advances in management of type 2 diabetes and nephropathy: lessons from the RENAAL study. Am J Kidney Dis. 2003;41(3 Suppl 1):S22-25. [pmid: 12612946].
Kessler L, Bilbault P, Ortega F, et al. Hyperbaric oxygenation accelerates the healing rate of nonischemic chronic diabetic foot ulcers: a prospective randomized study. Diabetes care. 2003;26(8):2378-2382. [pmid: 12882865].
Knopp RH, d'Emden M, Smilde JG, et al. Efficacy and safety of atorvastatin in the prevention of cardiovascular end points in subjects with type 2 diabetes: the Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in non-insulin-dependent diabetes mellitus (ASPEN). Diabetes Care. 2006;29(7):1478-1485. [pmid: 16801565].
Kochar DK, Jain N, Agarwal RP, et al. Sodium valproate in the management of painful neuropathy in type 2 diabetes - a randomized placebo controlled study. Acta Neurol Scand. 2002;106(5):248-252. [pmid: 12371916].
Kochar DK, Rawat N, Agarwal RP, et al. Sodium valproate for painful neuropathy: a randomized double-bline placebo-controlled study. Q J Med. 2004;97(1):33-38.
Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. 2001;345(12):851-860. [pmid: 11565517].
Lewis EJ, Hunsicker LG, Rodby RA, et al. A clinical trial in type 2 diabetic nephropathy. Am J Kidney Dis. 2001;38(4 Suppl 1):S191-194. [pmid: 11576953].
Litzelman DK, Slemenda CW, Langefeld CD, et al. Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. Ann Intern Med. 1993;19(1):36-41.
Bray G, Gregg E. Look Ahead Research Group, et al. Baseline characteristics of the randomised cohort from the Look AHEAD (Action for Health in Diabetes) study. Diab Vasc Dis Res. 2006;3(3):202-215. [pmid: 17160917]. [pmcid: 2660200].
Look Ahead Research Group. The Look AHEAD study: a description of the lifestyle intervention and the evidence supporting it. Obesity. 2006;14(5):737-752. [pmid: 16855180]. [pmcid: 2613279].
Pi-Sunyer X, Blackburn G. Look Ahead Research Group, et al. Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the look AHEAD trial. Diabetes Care. 2007;30(6):1374-1383. [pmid: 17363746]. [pmcid: 2665929].
Ryan DH, Espeland MA. Look Ahead Research Group, et al. Look AHEAD (Action for Health in Diabetes): design and methods for a clinical trial of weight loss for the prevention of cardiovascular disease in type 2 diabetes. Control Clin Trials. 2003;24(5):610-628. [pmid: 14500058].
Makino H, Haneda M, Babazono T, et al. The telmisartan renoprotective study from incipient nephropathy to overt nephropathy—rationale, study design, treatment plan and baseline characteristics of the incipient to overt: angiotensin II receptor blocker, telmisartan, Investigation on Type 2 Diabetic Nephropathy (INNOVATION) Study. J Int Med Res. 2005;33(6):677-686. [pmid: 16372586].
Malmberg K, Ryden L, Wedel H, et al. Intense metabolic control by means of insulin in patients with diabetes mellitus and acute myocardial infarction (DIGAMI 2): effects on mortality and morbidity. Eur Heart J. 2005;26(7):650-661. [pmid: 15728645].
Marre M, Lievre M, Chatellier G, et al. Effects of low dose ramipril on cardiovascular and renal outcomes in patients with type 2 diabetes and raised excretion of urinary albumin: randomised, double blind, placebo controlled trial (the DIABHYCAR study). Bmj. 2004;328(7438):495. [pmid: 14960504]. [pmcid: 351842].
Mayer-Davis EJ, D'Antonio AM, Smith SM, et al. Pounds off with empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. 2004;94(10):1736-1742. [pmid: 15451743]. [pmcid: 1448527].
McCluskey D, Touger MS, Melis R, et al. Results of a randomized, double-blind, placebo-controlled study administering glimepiride to patients with type 2 diabetes mellitus inadequately controlled with rosiglitazone monotherapy. Clin Ther. 2004;26(11):1783-1790. [pmid: 15639690].
McMahon GT, Plutzky J, Daher E, et al. Effect of a peroxisome proliferator-activated receptor-gamma agonist on myocardial blood flow in type 2 diabetes. Diabetes Care. 2005;28(5):1145-1150. [pmid: 15855580].
McMurray SD, Johnson G, Davis S, et al. Diabetes education and care management significantly improve patient outcomes in the dialysis unit. Am J Kidney Dis. 2002;40(3):566-575. [pmid: 12200809].
McNulty SJ, Ur E, Williams G, et al. A randomized trial of sibutramine in the management of obese type 2 diabetic patients treated with metformin. Diabetes Care. 2003;26(1):125-131. [pmid: 12502668].
Mehler PS, Coll JR, Estacio R, et al. Intensive blood pressure control reduces the risk of cardiovascular events in patients with peripheral arterial disease and type 2 diabetes. Circulation. 2003;107(5):753-756. [pmid: 12578880].
Menard J, Payette H, Baillargeon JP, et al. Efficacy of intensive multitherapy for patients with type 2 diabetes mellitus: a randomized controlled trial. CMAJ. 2005;173(12):1457-1466. [pmid: 16293781]. [pmcid: 1316161].
Miller M, Dobs A, Yuan Z, et al. Effectiveness of simvastatin therapy in raising HDL-C in patients with type 2 diabetes and low HDL-C. Curr Med Res Opin. 2004;20(7):1087-1094. [pmid: 15265253].
Miller M, Dobs A, Yuan Z, et al. The effect of simvastatin on triglyceride-rich lipoproteins in patients with type 2 diabetic dyslipidemia: a SILHOUETTE trial sub-study. Curr Med Res Opin. 2006;22(2):343-350. [pmid: 16466606].
Mogensen CE, Viberti G, Halimi S, et al. Effect of low-dose perindopril/indapamide on albuminuria in diabetes: preterax in albuminuria regression: PREMIER. Hypertension. 2003;41(5):1063-1071. [pmid: 12654706].
Moses RG, Gomis R, Frandsen KB, et al. Flexible meal-related dosing with repaglinide facilitates glycemic control in therapy-naive type 2 diabetes. Diabetes care. 2001;24(1):11-15. [pmid: 11194214].
Nakamura T, Ushiyama C, Osada S, et al. Combination therapy of trandolapril and candesartan cilexetil reduces microalbuminuria and urinary endothelin-1 excretion in patients with type 2 diabetes. Clin Exp Nephrol. 2002;6(3):135-139.
Neil HA, DeMicco DA, Luo D, et al. Analysis of efficacy and safety in patients aged 65–75 years at randomization: Collaborative Atorvastatin Diabetes Study (CARDS). Diabetes Care. 2006;29(11):2378-2384. [pmid: 17065671].
Norinder A, Persson U, Nilsson P, et al. Costs for screening, intervention and hospital treatment generated by the Malmo Preventive Project: a large-scale community screening programme. J Intern Med. 2002;251(1):44-52. [pmid: 11851864].
Osman A, Otero J, Brizolara A, et al. Effect of rosiglitazone on restenosis after coronary stenting in patients with type 2 diabetes. Am Heart J. 2004;147(5):e23. [pmid: 14691414].
Palmer AJ, Annemans L, Roze S, et al. An economic evaluation of the Irbesartan in Diabetic Nephropathy Trial (IDNT) in a UK setting. J Hum Hypertens. 2004;18(10):733-738. [pmid: 15116142].
Parving HH, Lehnert H, Brochner-Mortensen J, et al. The effect of irbesartan on the development of diabetic nephropathy in patients with type 2 diabetes. N Engl J Med. 2001;345(12):870-878. [pmid: 11565519].
Patel A, Chalmers J, Poulter N. ADVANCE: action in diabetes and vascular disease. J Hum Hypertens. 2005;19(Suppl 1):S27-32. [pmid: 16075030].
Persson F, Rossing P, Hovind P, et al. Irbesartan treatment reduces biomarkers of inflammatory activity in patients with type 2 diabetes and microalbuminuria: an IRMA 2 substudy. Diabetes. 2006;55(12):3550-3555. [pmid: 17130503].
Pitale S, Kernan-Schroeder D, Emanuele N, et al. Health-related quality of life in the VA Feasibility Study on glycemic control and complications in type 2 diabetes mellitus. J Diabetes Complications. 2005;19(4):207-211. [pmid: 15993354].
Plank J, Haas W, Rakovac I, et al. Evaluation of the impact of chiropodist care in the secondary prevention of foot ulcerations in diabetic subjects. Diabetes Care. 2003;26(6):1691-1695. [pmid: 12766095].
Pohl MA, Blumenthal S, Cordonnier DJ, et al. Independent and additive impact of blood pressure control and angiotensin II receptor blockade on renal outcomes in the irbesartan diabetic nephropathy trial: clinical implications and limitations. J Am Soc Nephrol. 2005;16(10):3027-3037. [pmid: 16120823].
Pradhan R, Fong D, March C, et al. Angiotensin-converting enzyme inhibition for the treatment of moderate to severe diabetic retinopathy in normotensive Type 2 diabetic patients. A pilot study. J Diabetes Complications. 2002;16(6):377-381. [pmid: 12477620].
Raskin J, Pritchett YL, Wang F, et al. A double-blind, randomized multicenter trial comparing duloxetine with placebo in the management of diabetic peripheral neuropathic pain. Pain Med. 2005;6(5):346-356. [pmid: 16266355].
Remuzzi G, Macia M, Ruggenenti P. Prevention and treatment of diabetic renal disease in type 2 diabetes: the BENEDICT study. J Am Soc Nephrol. 2006;17(4 Suppl 2):S90-97. [pmid: 16565256].
Remuzzi G, Ruggenenti P. BENEDICT: Bergamo Nephrologic Diabetes Complications Trial. Control Clin Trials. 2003;24:442-461. [pmid: 12865039].
Remuzzi G, Ruggenenti P, Perna A, et al. Continuum of renoprotection with losartan at all stages of type 2 diabetic nephropathy: a post hoc analysis of the RENAAL trial results. J Am Soc Nephrol. 2004;15(12):3117-3125. [pmid: 15579515].
Reynolds LR, Konz EC, Frederich RC, et al. Rosiglitazone amplifies the benefits of lifestyle intervention measures in long-standing type 2 diabetes mellitus. Diabetes Obes Metab. 2002;4(4):270-275. [pmid: 12099976].
Ritzwoller DP, Toobert D, Sukhanova A, et al. Economic analysis of the Mediterranean Lifestyle Program for postmenopausal women with diabetes. Diabetes Educ. 2006;32(5):761-769. [pmid: 16971709].
Rodby RA, Rohde RD, Clarke WR, et al. The Irbesartan type II diabetic nephropathy trial: study design and baseline patient characteristics. Nephrol Dial Transplant. 2000;15(4):487-497. [pmid: 10727543].
Rosenstock J, Sugimoto D, Strange P, et al. Triple therapy in type 2 diabetes: insulin glargine or rosiglitazone added to combination therapy of sulfonylurea plus metformin in insulin-naive patients. Diabetes Care. 2006;29(3):554-559. [pmid: 16505505].
Rossing K, Christensen PK, Andersen S, et al. Comparative effects of Irbesartan on ambulatory and office blood pressure: a substudy of ambulatory blood pressure from the Irbesartan in Patients with Type 2 Diabetes and Microalbuminuria study. Diabetes Care. 2003;26(3):569-574. [pmid: 12610003].
Rossing K, Christensen PK, Jensen BR, et al. Dual blockade of the renin-angiotensin system in diabetic nephropathy: a randomized double-blind crossover study. Diabetes Care. 2002;25(1):95-100. [pmid: 11772908].
Ruggenenti P, Fassi A, Ilieva AP, et al. Preventing microalbuminuria in type 2 diabetes. N Engl J Med. 2004;351(19):1941-1951. [pmid: 15516697].
Sanchez-Reyes L, Fanghanel G, Yamamoto J, et al. Use of sibutramine in overweight adult hispanic patients with type 2 diabetes mellitus: a 12-month, randomized, double-blind, placebo-controlled clinical trial. Clin Ther. 2004;26(9):1427-1435. [pmid: 15531005].
Sasso FC, Carbonara O, Persico M, et al. Irbesartan reduces the albumin excretion rate in microalbuminuric type 2 diabetic patients independently of hypertension: a randomized double-blind placebo-controlled crossover study. Diabetes Care. 2002;25(11):1909-1913. [pmid: 12401731].
Sasso FC, De Nicola L, Carbonara O, et al. Cardiovascular risk factors and disease management in type 2 diabetic patients with diabetic nephropathy. Diabetes Care. 2006;29(3):498-503. [pmid: 16505495].
Schneider JG, von Eynatten M, Parhofer KG, et al. Atorvastatin improves diabetic dyslipidemia and increases lipoprotein lipase activity in vivo. Atherosclerosis. 2004;175(2):325-331. [pmid: 15262189].
Segal P, Eliahou HE, Petzinna D, et al. Long-term efficacy and tolerability of acarbose treatment in patients with type 2 diabetes mellitus. Clin Drug Investig. 2005;25(9):589-595.
Sen K, Misra A, Kumar A, et al. Simvastatin retards progression of retinopathy in diabetic patients with hypercholesterolemia. Diabetes Res Clin Pract. 2002;56(1):1-11. [pmid: 11879715].
Serrano-Rios M, Melchionda N, Moreno-Carretero E, et al. Role of sibutramine in the treatment of obese Type 2 diabetic patients receiving sulphonylurea therapy. Diabet Med. 2002;19(2):119-124. [pmid: 11874427].
Shichiri M, Kishikawa H, Ohkubo Y, et al. Long-term results of the Kumamoto Study on optimal diabetes control in type 2 diabetic patients. Diabetes Care. 2000;23(Supp 2):B21-29. [pmid: 10860187].
Soedamah-Muthu SS, Colhoun HM, Thomason MJ, et al. The effect of atorvastatin on serum lipids, lipoproteins and NMR spectroscopy defined lipoprotein subclasses in type 2 diabetic patients with ischaemic heart disease. Atherosclerosis. 2003;167(2):243-255. [pmid: 12818407].
Sommeijer DW, MacGillavry MR, Meijers JC, et al. Anti-inflammatory and anticoagulant effects of pravastatin in patients with type 2 diabetes. Diabetes Care. 2004;27(2):468-473. [pmid: 14747230].
Sone H, Katagiri A, Ishibashi S, et al. Effects of lifestyle modifications on patients with type 2 diabetes: the Japan Diabetes Complications Study (JDCS) study design, baseline analysis and three year-interim report. Horm Metab Res. 2002;34(9):509-515. [pmid: 12384828].
Tan KC, Chow WS, Ai VH, et al. Effects of angiotensin II receptor antagonist on endothelial vasomotor function and urinary albumin excretion in type 2 diabetic patients with microalbuminuria. Diabetes/Metabolism Research Reviews. 2002;18(1):71-76.
Tan KC, Chow WS, Tam SC, et al. Atorvastatin lowers C-reactive protein and improves endothelium-dependent vasodilation in type 2 diabetes mellitus. J Clin Endocrinol Metab. 2002;87(2):563-568. [pmid: 11836286].
Tanaka A, Yamada N, Saito Y, et al. A double-blind trial on the effects of atorvastatin on glycemic control in Japanese diabetic patients with hypercholesterolemia. Clin Chim Acta. 2001;312(12):41-47. [pmid: 11580908].
Taylor CB, Miller NH, Reilly KR, et al. Evaluation of a nurse-care management system to improve outcomes in patients with complicated diabetes. Diabetes Care. 2003;26(4):1058-1063. [pmid: 12663573].
Taylor KI, Oberle KM, Crutcher RA, et al. Promoting health in type 2 diabetes: nurse-physician collaboration in primary care. Biol Res Nurs. 2005;6(3):207-215. [pmid: 15583361].
Tessier D, Menard J, Fulop T, et al. Effects of aerobic physical exercise in the elderly with type 2 diabetes mellitus. Arch Gerontol Geriatr. 2000;31:121-132. [pmid: 11090907].
Sjolie AK, Porta M. The Direct Programme Study Group, et al. The DIabetic REtinopathy Candesartan Trials (DIRECT) Programme: baseline characteristics. J Renin Angiotensin Aldosterone Syst. 2005;6(1):25-32. [pmid: 16088848].
Thomas C, Hypponen E, Power C. Type 2 diabetes mellitus in midlife estimated from the Cambridge Risk Score and body mass index. Arch Intern Med. 2006;166(6):682-688. [pmid: 16567609].
Thomason MJ, Colhoun HM, Livingstone SJ, et al. Baseline characteristics in the Collaborative AtoRvastatin Diabetes Study (CARDS) in patients with Type 2 diabetes. Diabet Med. 2004;21(8):901-905. [pmid: 15270795].
Toobert DJ, Glasgow RE, Strycker LA, et al. Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: a randomized clinical trial. Diabetes care. 2003;26(8):2288-2293. [pmid: 12882850].
Toobert DJ, Strycker LA, Glasgow RE, et al. If you build it, will they come? Reach and Adoption associated with a comprehensive lifestyle management program for women with type 2 diabetes. Patient Educ Couns. 2002;48(2):99-105. [pmid: 12401412].
Toobert DJ, Strycker LA, Glasgow RE, et al. Effects of the mediterranean lifestyle program on multiple risk behaviors and psychosocial outcomes among women at risk for heart disease. Ann Behav Med. 2005;29(2):128-137. [pmid: 15823786]. [pmcid: 1557654].
Toobert DJ, Strycker LA, Glasgow RE, et al. Enhancing support for health behavior change among women at risk for heart disease: the Mediterranean Lifestyle Trial. Health Educ Res. 2002;17(5):574-585. [pmid: 12408202].
Tubbs CG, Safeek A, Mayo HG, et al. Clinical inquiries. Do routine eye exams reduce occurrence of blindness from type 2 diabetes? J Fam Pract. 2004;53(9):732-734.
Uehara MH, Kohlmann NE, Zanella MT, et al. Metabolic and haemodynamic effects of metformin in patients with type 2 diabetes mellitus and hypertension. Diabetes Obes Metab. 2001;3(5):319-325. [pmid: 11703421].
Vaur L, Gueret P, Lievre M, et al. Development of congestive heart failure in type 2 diabetic patients with microalbuminuria or proteinuria: observations from the DIABHYCAR (type 2 DIABetes, Hypertension, CArdiovascular Events and Ramipril) study. Diabetes Care. 2003;26(3):855-860. [pmid: 12610049].
Wanner C, Krane V, Marz W, et al. Atorvastatin in patients with type 2 diabetes mellitus undergoing hemodialysis. N Engl J Med. 2005;353(3):238-248. [pmid: 16034009].
Woollard J, Burke V, Beilin LJ. Effects of general practice-based nurse-counselling on ambulatory blood pressure and antihypertensive drug prescription in patients at increased risk of cardiovascular disease. J Hum Hypertens. 2003;17(10):689-695. [pmid: 14504627].

### Diabetes Treatment Studies with Unknown Duration

Joos S, Rosemann T, Heiderhoff M, et al. ELSID-Diabetes study-evaluation of a large scale implementation of disease management programmes for patients with type 2 diabetes. Rationale, design and conduct - a study protocol. BMC Public Health. Vol. 2005;5(99).
Owen OG. The collaborative atorvastatin diabetes study: preliminary results. Int J Clin Pract. 2005;59(1):121-123. [pmid: 15707477].
Souchet T, Durand Zaleski I, Hannedouche T, et al. An economic evaluation of Losartan therapy in type 2 diabetic patients with nephropathy: an analysis of the RENAAL study adapted to France. Diabetes Metab. 2003;29(1):29-35. [pmid: 12629445].
Tonelli M, Keech A, Shepherd J, et al. Effect of pravastatin in people with diabetes and chronic kidney disease. J Am Soc Nephrol. 2005;16(12):3748-3754. [pmid: 16251235].
Wolf AM, Conaway MR, Crowther JQ, et al. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. 2004;27(7):1570-1576. [pmid: 15220230].

### Wrong Population

Aberg AE, Jonsson EK, Eskilsson I, et al. Predictive factors of developing diabetes mellitus in women with gestational diabetes. Acta Obstet Gynecol Scand. 2002;81(1):11-16. [pmid: 11942881].
Abuissa H, Jones PG, Marso SP, et al. Angiotensin-converting enzyme inhibitors or angiotensin receptor blockers for prevention of type 2 diabetes: a meta-analysis of randomized clinical trials. J Am Coll Cardiol. 2005;46(5):821-826. [pmid: 16139131].
Adams TD, Avelar E, Cloward T, et al. Design and rationale of the Utah obesity study. A study to assess morbidity following gastric bypass surgery. Contemp Clin Trials. 2005;26(5):534-551. [pmid: 16046191].
Andraws R, Brown DL. Effect of inhibition of the renin-angiotensin system on development of type 2 diabetes mellitus (meta-analysis of randomized trials). Am J Cardiol. 2007;99(7):1006-1012. [pmid: 17398202].
Anonymous. A prospective, randomised, double-blind, double-dummy, forced-titration, multicentre, parallel group, one year treatment trial to compare telmisartan (MICARDIS) 80 mg versus losartan (COZAAR) 100 mg, in hypertensive type 2 diabetic patients with overt nephropathy (AMADEO Study). Clinical Trials.Available at:http://www.clinicaltrials.gov/ct2/show/NCT00168857?term=MICARDIS&rank=13. Assessed 2007.
Athyros VG, Papageorgiou AA, Mercouris BR, et al. Treatment with atorvastatin to the National Cholesterol Educational Program goal versus ‘usual’ care in secondary coronary heart disease prevention. The GREek Atorvastatin and Coronary-heart-disease Evaluation (GREACE) study. Curr Med Res Opin. 2002;18(4):220-228. [pmid: 12201623].
Barzilay JI, Davis BR, Cutler JA, et al. Fasting glucose levels and incident diabetes mellitus in older nondiabetic adults randomized to receive 3 different classes of antihypertensive treatment: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Arch Intern Med. 2006;166(20):2191-2201. [pmid: 17101936].
Ben-Haroush A, Yogev Y, Hod M. Epidemiology of gestational diabetes mellitus and its association with Type 2 diabetes. Diabet Med. 2004;21(2):103-113. [pmid: 14984444].
BIP Study Group. Secondary prevention by raising HDL cholesterol and reducing triglycerides in patients with coronary artery disease: the Bezafibrate Infarction Prevention (BIP) study. Circulation. 2000;102(1):21-27. [pmid: 10880410].
Braunwald E, Domanski MJ, Fowler SE, et al. Angiotensin-converting-enzyme inhibition in stable coronary artery disease. N Engl J Med. 2004;351(20):2058-2068. [pmid: 15531767]. [pmcid: 2556374].
Brekke HK, Lenner RA, Taskinen MR, et al. Lifestyle modification improves risk factors in type 2 diabetes relatives. Diabetes Res Clin Pract. 2005;68(1):18-28. [pmid: 15811562].
Broclain D, Jepson R, Moumjid Ferdjaoui N. Influence of comprehensive versus partial information on consumers' screening choices. Cochrane Database of Sys Rev. 2006(3).
Burger W, Chemnitius JM, Kneissl GD, et al. Low-dose aspirin for secondary cardiovascular prevention - cardiovascular risks after its perioperative withdrawal versus bleeding risks with its continuation - review and meta-analysis. J Intern Med. 2005;257(5):399-414. [pmid: 15836656].
Cannon CP, Braunwald E, McCabe CH, et al. Intensive versus moderate lipid lowering with statins after acute coronary syndromes. N Engl J Med. 2004;350(15):1495-1504. [pmid: 15007110].
Clark HD, van Walraven C, Code C, et al. Did publication of a clinical practice guideline recommendation to screen for type 2 diabetes in women with gestational diabetes change practice?. Diabetes Care. 2003;26(2):265-268. [pmid: 12547846].
Dargie HJ, Hildebrandt PR, Riegger GA, et al. A randomized, placebo-controlled trial assessing the effects of rosiglitazone on echocardiographic function and cardiac status in type 2 diabetic patients with New York Heart Association Functional Class I or II Heart Failure. J Am Coll Cardiol. 2007;49(16):1696-1704. [pmid: 17448371].
Davey Smith G, Bracha Y, Svendsen KH, et al. Incidence of type 2 diabetes in the randomized multiple risk factor intervention trial. Ann Intern Med. 2005;142(5):313-322. [pmid: 15738450].
Davidson MH, Maccubbin D, Stepanavage M, et al. Striated muscle safety of ezetimibe/simvastatin (Vytorin). Am J Cardiol. 2006;97(2):223-228. [pmid: 16442367].
Dayspring T, Pokrywka G. Fibrate therapy in patients with metabolic syndrome and diabetes mellitus. Curr Atheroscler Rep. 2006;8(5):356-364. [pmid: 16901405].
de Gaetano G. Project. CgotPP. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Lancet. 2001;357:89-95. [pmid: 11197445].
de Virgilio C, Toosie K, Lewis RJ, et al. Cardiac morbidity and operative mortality following lower-extremity amputation: the significance of multiple Eagle criteria. Ann Vasc Surg. 1999;13(2):204-208. [pmid: 10072463].
de Zeeuw D, Remuzzi G, Parving HH, et al. Albuminuria, a therapeutic target for cardiovascular protection in type 2 diabetic patients with nephropathy. Circulation. 2004;110(8):921-927. [pmid: 15302780].
Dens JA, Desmet WJ, Coussement P, et al. Usefulness of Nisoldipine for prevention of restenosis after percutaneous transluminal coronary angioplasty (results of the NICOLE study). NIsoldipine in COronary artery disease in LEuven. Am J Cardiol. 87(1):28–33. 2001;87(1):28–33.
Derosa G, Cicero AF, D'Angelo A, et al. Synergistic effect of doxazosin and acarbose in improving metabolic control in patients with impaired glucose tolerance. Clin Drug Investig. 2006;26(9):529-539.
Jacobson AM, Musen G. Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Study Research Group, et al. Long-term effect of diabetes and its treatment on cognitive function. N Engl J Med. 2007;356(18):1842-1852. [pmid: 17476010].
Dickstein K. The role of losartan in the management of patients with heart failure. Clin Ther. 2001;23(9):1456-1477. [pmid: 11589260].
Downs JR, Clearfield M, Weis S, et al. Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS. JAMA. 1998;279:1615-1622. [pmid: 9613910].
Fletcher A, Amery A, Birkenhager W, et al. Risks and benefits in the trial of the European Working Party on High Blood Pressure in the Elderly. J Hypertens. 1991;9(3):225-230. [pmid: 1851785].
Fletcher AE. Adverse treatment effects in the trial of the European Working Party on High Blood Pressure in the Elderly. Am J Med. 1991;90(3A):S42-44.
Ford ES. Risks for all-cause mortality, cardiovascular disease, and diabetes associated with the metabolic syndrome: a summary of the evidence. Diabetes Care. 2005;28(7):1769-1778. [pmid: 15983333].
Freeman DJ, Norrie J, Sattar N, et al. Pravastatin and the development of diabetes mellitus: evidence for a protective treatment effect in the West of Scotland Coronary Prevention Study. Circulation. 2001;103(3):357-362. [pmid: 11157685].
Gokcel A, Gumurdulu Y, Karakose H, et al. Evaluation of the safety and efficacy of sibutramine, orlistat and metformin in the treatment of obesity. Diabetes Obes Metab. 2002;4(1):49-55. [pmid: 11874442].
Goldberg RB, Mellies MJ, Sacks FM, et al. Cardiovascular events and their reduction with pravastatin in diabetic and glucose-intolerant myocardial infarction survivors with average cholesterol levels: subgroup analyses in the cholesterol and recurrent events (CARE) trial. Circulation. 1998;98:2513-2519. [pmid: 9843456].
Gutzin SJ, Kozer E, Magee LA, et al. The safety of oral hypoglycemic agents in the first trimester of pregnancy: a meta-analysis. Can J Clin Pharmacol. 2003;10(4):179-183. [pmid: 14712322].
Hansson L, Hedner T, Lund-Johansen P, et al. Randomised trial of effects of calcium antagonists compared with diuretics and beta-blockers on cardiovascular morbidity and mortality in hypertension: the Nordic Diltiazem (NORDIL) study. Lancet. 2000;356(9227):359-365. [pmid: 10972367].
Hayashino Y, Nagata-Kobayashi S, Morimoto T, et al. Cost-effectiveness of screening for coronary artery disease in asymptomatic patients with Type 2 diabetes and additional atherogenic risk factors. J Gen Intern Med. 2004;19(12):1181-1191. [pmid: 15610328]. [pmcid: 1492594].
Hoogwerf BJ, Waness A, Cressman M, et al. Effects of aggressive cholesterol lowering and low-dose anticoagulation on clinical and angiographic outcomes in patients with diabetes: the Post Coronary Artery Bypass Graft Trial. Diabetes. 1999;48(6):1289-1294. [pmid: 10342818].
Huang ES, Shook M, Jin L, et al. The impact of patient preferences on the cost-effectiveness of intensive glucose control in older patients with new-onset diabetes. Diabetes Care. 2006;29(2):259-264. [pmid: 16443870]. [pmcid: 2292131].
Jeon CY, Lokken RP, Hu FB, et al. Physical activity of moderate intensity and risk of type 2 diabetes: a systematic review. Diabetes Care. 2007;30(3):744-752. [pmid: 17327354].
Julius S, Kjeldsen SE, Weber M, et al. Outcomes in hypertensive patients at high cardiovascular risk treated with regimens based on valsartan or amlodipine: the VALUE randomised trial. Lancet. 2004;363(9426):2022-2031. [pmid: 15207952].
Keech A, Colquhoun D, Best J, et al. Secondary prevention of cardiovascular events with long-term pravastatin in patients with diabetes or impaired fasting glucose: results from the LIPID trial. Diabetes Care. 2003;26(10):2713-2721. [pmid: 14514569].
Kim C, Newton KM, Knopp RH. Gestational diabetes and the incidence of type 2 diabetes: a systematic review. Diabetes Care. 2002;25(10):1862-1868. [pmid: 12351492].
Kjeldsen SE, Hedner T, Syvertsen JO, et al. Influence of age, sex and blood pressure on the principal endpoints of the Nordic Diltiazem (NORDIL) Study. J Hypertens. 2002;20(6):1231-1237. [pmid: 12023696].
Kjeldsen SE, Julius S, Mancia G, et al. Effects of valsartan compared to amlodipine on preventing type 2 diabetes in high-risk hypertensive patients: the VALUE trial. J Hypertens. 2006;24(7):1405-1412. [pmid: 16794491].
Lee WJ, Huang MT, Wang W, et al. Effects of obesity surgery on the metabolic syndrome. Arch Surg. 2004;139(10):1088-1092. [pmid: 15492149].
Lindholm LH, Persson M, Alaupovic P, et al. Metabolic outcome during 1 year in newly detected hypertensives: results of the Antihypertensive Treatment and Lipid Profile in a North of Sweden Efficacy Evaluation (ALPINE study). J Hypertens. 2003;21(8):1563-1574. [pmid: 12872052].
LIPID Long-Term Intervention with Pravastatin in Ischaemic Disease Study Group. Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels. N Engl J Med. 1998;339:1349-1357. [pmid: 9841303].
Lithell H, Hansson L, Skoog I, et al. The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. J Hypertens. 21(5):875–86. 2003;21(5):875–886.
Lonn E, Yusuf S, Hoogwerf B, et al. Effects of vitamin E on cardiovascular and microvascular outcomes in high-risk patients with diabetes: results of the HOPE study and MICRO-HOPE substudy. Diabetes Care. 2002;25(11):1919-1927. [pmid: 12401733].
Majid A, Delanty N, Kantor J. Antiplatelet agents for secondary prevention of ischemic stroke. Ann Pharmacother. 2001;35(10):1241-1247. [pmid: 11675854].
Malmberg K, Ryden L, Efendic S, et al. Randomized trial of insulin-glucose infusion followed by subcutaneous insulin treatment in diabetic patients with acute myocardial infarction (DIGAMI study): effects on mortality at 1 year. J Am Coll Cardiol. 1995;26(1):57-65. [pmid: 7797776].
Mancia G, Brown B, Castaigne A, et al. Outcomes With Nifedipine GITS or Co-Amilozide in Hypertensive Diabetics and Nondiabetics in Intervention as a Goal in Hypertension (INSIGHT). Hypertension. 2003;41(3):431-436. [pmid: 12623939].
Mann JF, Gerstein HC, Yi QL, et al. Progression of renal insufficiency in type 2 diabetes with and without microalbuminuria: results of the Heart Outcomes and Prevention Evaluation (HOPE) randomized study. Am J Kidney Dis. 2003;42(5):936-942. [pmid: 14582037].
Margareta Eriksson K, Westborg CJ, Eliasson MC. A randomized trial of lifestyle intervention in primary healthcare for the modification of cardiovascular risk factors. Scand J Public Health. 2006;34(5):453-461. [pmid: 16990155].
Menard J, Payette H, Dubuc N, et al. Quality of life in type 2 diabetes patients under intensive multitherapy. Diabetes Metab. 2007;33(1):54-60. [pmid: 17258926].
Nakamura Y, Saitoh S, Takagi S, et al. Impact of abnormal glucose tolerance, hypertension and other risk factors on coronary artery disease. Circ J. 2007;71(1):20-25. [pmid: 17186973].
Nishio K, Sakurai M, Kusuyama T, et al. A randomized comparison of pioglitazone to inhibit restenosis after coronary stenting in patients with type 2 diabetes. Diabetes Care. 2006;29(1):101-106. [pmid: 16373904].
Parameswaran GI, Brand K, Dolan J. Pulse oximetry as a potential screening tool for lower extremity arterial disease in asymptomatic patients with diabetes mellitus. Arch Intern Med. 2005;165(4):442-446. [pmid: 15738375].
Pathan MF, Latif ZA, Nazneen NE, et al. Orlistat as an adjunct therapy in type 2 obese diabetic patients treated with sulphonylurea: a Bangladesh experience. Bangladesh Med Res Counc Bull. 2004;30(1):1-8. [pmid: 15376463].
Pavkov ME, Bennett PH, Knowler WC, et al. Effect of youth-onset type 2 diabetes mellitus on incidence of end-stage renal disease and mortality in young and middle-aged Pima Indians. JAMA. 2006;296(4):421-426. [pmid: 16868300].
Pedersen O, Gaede P. Intensified multifactorial intervention and cardiovascular outcome in type 2 diabetes: the Steno-2 study. Metabolism. 2003;52(8 Suppl 1):19-23.
Peter R, Luzio SD, Dunseath G, et al. Relationship between HbA1c and indices of glucose tolerance derived from a standardized meal test in newly diagnosed treatment naive subjects with Type 2 diabetes. Diabet Med. 2006;23(9):990-995. [pmid: 16922705].
Piechowski-Jozwiak B, Maulaz A, Bogousslavsky J. Secondary prevention of stroke with antiplatelet agents in patients with diabetes mellitus. Cerebrovasc Dis. 2005;20(Suppl 1):15-23. [pmid: 16276081].
Pierce M, Harding D, Ridout D, et al. Risk and prevention of type II diabetes: offspring's views. Br J Gen Pract. 2001;51(464):194-199. [pmid: 11255900]. [pmcid: 1313950].
Pitt B, Byington RP, Furberg CD, et al. Effect of amlodipine on the progression of atherosclerosis and the occurrence of clinical events. PREVENT Investigators. Circulation. 2000;102(13):1503-1510. [pmid: 11004140].
Pitt B, Waters D, Brown WV, et al. Aggressive lipid-lowering therapy compared with angioplasty in stable coronary artery disease. Atorvastatin versus Revascularization Treatment Investigators. N Engl J Med. 1999;341(2):70-76. [pmid: 10395630].
Post Coronary Artery Bypass Graft Trial Investigators. The effect of aggressive lowering of low-density lipoprotein cholesterol levels and low-dose anticoagulation on obstructive changes in saphenous-vein coronary-artery bypass grafts. N Engl J Med. 1997;336(3):153-162. [pmid: 8992351].
PROGRESS Collaborative Group. Randomised trial of a perindopril-based blood-pressure-lowering regimen among 6105 individuals with previous stroke or transient ischaemic attack. Lancet. 2001;358(9287):1033-1041. [pmid: 11589932].
Pyorala K, Ballantyne CM, Gumbiner B, et al. Reduction of cardiovascular events by simvastatin in nondiabetic coronary heart disease patients with and without the metabolic syndrome: subgroup analyses of the Scandinavian Simvastatin Survival Study (4S). Diabetes Care. 2004;27(7):1735-1740. [pmid: 15220255].
Pyorala K, Pedersen TR, Kjekshus J, et al. Cholesterol lowering with simvastatin improves prognosis of diabetic patients with coronary heart disease. Diabetes Care. 1997;20:614-620. [pmid: 9096989].
Richelsen B, Tonstad S, Rossner S, et al. Effect of orlistat on weight regain and cardiovascular risk factors following a very-low-energy diet in abdominally obese patients: a 3-year randomized, placebo-controlled study. Diabetes Care. 2007;30(1):27-32. [pmid: 17192328].
Rubins HB, Robins SJ, Collins D, et al. Gemfibrozil for the secondary prevention of coronary heart disease in men with low levels of high-density lipoprotein cholesterol. N Engl J Med. 1999;341:410-418. [pmid: 10438259].
Rubins HB, Robins SJ, Collins D, et al. Diabetes, plasma insulin, and cardiovascular disease: subgroup analysis from the Department of Veterans Affairs high-density lipoprotein intervention trial (VA-HIT). Arch Intern Med. 2002;162(22):2597-2604. [pmid: 12456232].
Sacks FM, Pfeffer MA, Moye LA, et al. The effect of pravastatin on coronary events after myocardial infarction in patients with average cholesterol levels. Cholesterol and Recurrent Events Trial investigators. N Engl J Med. 1996;335(14):1001-1009. [pmid: 8801446].
Skinner TC, Hampson SE, Fife-Schaw C, et al. Personality, personal model beliefs, and self-care in adolescents and young adults with Type 1 diabetes. Health Psychol. 2002;21(1):61-70. [pmid: 11846346].
Smith DG, Nguyen AB, Peak CN, et al. Markov modeling analysis of health and economic outcomes of therapy with valsartan versus amlodipine in patients with type 2 diabetes and microalbuminuria. J Manag Care Pharm. 2004;10(1):26-32. [pmid: 14720103].
Soja AM, Zwisler AD, Frederiksen M, et al. Use of intensified comprehensive cardiac rehabilitation to improve risk factor control in patients with type 2 diabetes mellitus or impaired glucose tolerance—the randomized DANish StUdy of impaired glucose metabolism in the settings of cardiac rehabilitation (DANSUK) study. Am Heart J. 2007;153(4):621-628. [pmid: 17383302].
Solomon SD, Rice MM, K AJ, et al. Renal function and effectiveness of angiotensin-converting enzyme inhibitor therapy in patients with chronic stable coronary disease in the Prevention of Events with ACE inhibition (PEACE) trial. Circulation. 2006;114(1):26-31. [pmid: 16801465].
Stern MP, Williams K, Gonzalez-Villalpando C, et al. Does the metabolic syndrome improve identification of individuals at risk of type 2 diabetes and/or cardiovascular disease. Diabetes Care. 2004;27(11):2676-2681. [pmid: 15505004].
Strippoli GF, Bonifati C, Craig M, et al. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression of diabetic kidney disease. Cochrane Database of Syst Rev. 2006(4):CD006257.
Strippoli GF, Craig M, Deeks JJ, et al. Effects of angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists on mortality and renal outcomes in diabetic nephropathy: systematic review. Bmj. 2004;329(7470):828. [pmid: 15459003]. [pmcid: 521570].
Suehiro T, Matsumata T, Shikada Y, et al. Hyperinsulinemia in patients with colorectal cancer. Hepatogastroenterology. 2005;52(61):76-78. [pmid: 15782998].
Tenenbaum A, Motro M, Fisman EZ, et al. Peroxisome proliferator-activated receptor ligand bezafibrate for prevention of type 2 diabetes mellitus in patients with coronary artery disease. Circulation. 2004;109(18):2197-2202. [pmid: 15123532].
Teo K, Yusuf S, Sleight P, et al. Rationale, design, and baseline characteristics of 2 large, simple, randomized trials evaluating telmisartan, ramipril, and their combination in high-risk patients: the Ongoing Telmisartan Alone and in Combination with Ramipril Global Endpoint Trial/Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease (ONTARGET/TRANSCEND) trials. Am Heart J. 2004;148(1):52-61. [pmid: 15215792].
Tong PC, Kong AP, So WY, et al. The usefulness of the International Diabetes Federation and the National Cholesterol Education Program's Adult Treatment Panel III definitions of the metabolic syndrome in predicting coronary heart disease in subjects with type 2 diabetes. Diabetes Care. 2007;30(5):1206-1211. [pmid: 17259472].
van Sluijs EM, van Poppel MN, Twisk JW, et al. Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95(10):1825-1831. [pmid: 16186461]. [pmcid: 1449443].
van Winkel R, De Hert M, Van Eyck D, et al. Screening for diabetes and other metabolic abnormalities in patients with schizophrenia and schizoaffective disorder: evaluation of incidence and screening methods. J Clin Psychiatry. 2006;67(10):1493-1500. [pmid: 17107239].
Wang G, Wei J, Guan Y, et al. Peroxisome proliferator-activated receptor-gamma agonist rosiglitazone reduces clinical inflammatory responses in type 2 diabetes with coronary artery disease after coronary angioplasty. Metabolism. 2005;54(5):590-597. [pmid: 15877288].
Yui Y, Sumiyoshi T, Kodama K, et al. Comparison of nifedipine retard with angiotensin converting enzyme inhibitors in Japanese hypertensive patients with coronary artery disease: the Japan Multicenter Investigation for Cardiovascular Diseases-B (JMIC-B) randomized trial. Hypertens Res. 2004;27(3):181-191. [pmid: 15080377].
Yusuf S, Gerstein H, Hoogwerf B, et al. Ramipril and the development of diabetes. JAMA. 2001;286(15):1882-1885. [pmid: 11597291].
Yusuf S, Ostergren JB, Gerstein HC, et al. Effects of candesartan on the development of a new diagnosis of diabetes mellitus in patients with heart failure. Circulation. 2005;112(1):48-53. [pmid: 15983242].
Zanchetti A, Bond MG, Hennig M, et al. Calcium antagonist lacidipine slows down progression of asymptomatic carotid atherosclerosis: principal results of the European Lacidipine Study on Atherosclerosis (ELSA), a randomized, double-blind, long-term trial. Circulation. 2002;106(19):2422-2427. [pmid: 12417537].

### Wrong Treatment/Intervention

Adam JM, Tarigan NP. Comparison of The World Health Organization (WHO) two-step strategy and OGTT for diabetes mellitus screening. Acta Med Indones. 2004;36(1):3-7. [pmid: 15931695].
Aziz I, Lewis RJ, Baker JD, et al. Cardiac morbidity and mortality following carotid endarterectomy: the importance of diabetes and multiple Eagle risk factors. Ann Vasc Surg. 2001;15(2):243-246. [pmid: 11265091].
Behan KJ. Screening for diabetes: sensitivity and positive predictive value of risk factor total. Clin Lab Sci. 2005;18(4):221-225. [pmid: 16315739].
Bergenstal RM, Anderson RL, Bina DM, et al. Impact of modem-transferred blood glucose data on clinician work efficiency and patient glycemic control. Diabetes Technol Ther. 2005;7(2):241-247. [pmid: 15857225].
Brown SA, Garcia AA, Kouzekanani K, et al. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. 2002;25(2):259-268. [pmid: 11815493]. [pmcid: 2134805].
Buchanan TA, Xiang AH, Peters RK, et al. Preservation of pancreatic beta-cell function and prevention of type 2 diabetes by pharmacological treatment of insulin resistance in high-risk hispanic women. Diabetes. 2002;51(9):2796-2803. [pmid: 12196473].
Choe HM, Mitrovich S, Dubay D, et al. Proactive case management of high-risk patients with type 2 diabetes mellitus by a clinical pharmacist: a randomized controlled trial. Am J Manag Care. 2005;11(4):253-260. [pmid: 15839185].
Christensen JO, Sandbaek A, Lauritzen T, et al. Population-based stepwise screening for unrecognised Type 2 diabetes is ineffective in general practice despite reliable algorithms. Diabetologia. 2004;47(9):1566-1573. [pmid: 15365615].
Christianson TJ, Bryant SC, Weymiller AJ, et al. A pen-and-paper coronary risk estimator for office use with patients with type 2 diabetes. Mayo Clin Proc. 2006;81(5):632-636. [pmid: 16706261].
Cox SL. Muraglitazar: an agent for the treatment of type 2 diabetes and associated dyslipidemia. Drugs Today. 2005;41(9):579-587. [pmid: 16341289].
Davies M, Dixon S, Currie CJ, et al. Evaluation of a hospital diabetes specialist nursing service: a randomized controlled trial. Diabet Med. 2001;18(4):301-307. [pmid: 11437861].
Doulton TW, He FJ, MacGregor GA. Systematic review of combined angiotensin-converting enzyme inhibition and angiotensin receptor blockade in hypertension. Hypertension. 2005;45(5):880-886. [pmid: 15809363].
Faglia E, Caravaggi C, Marchetti R, et al. Screening for peripheral arterial disease by means of the ankle-brachial index in newly diagnosed Type 2 diabetic patients. Diabet Med. 2005;22(10):1310-1314. [pmid: 16176188].
Gary TL, Genkinger JM, Guallar E, et al. Meta-analysis of randomized educational and behavioral interventions in type 2 diabetes. Diabetes Educ. 2003;29(3):488-501. [pmid: 12854339].
Gesler WM, Arcury TA, Skelly AH, et al. Identifying diabetes knowledge network nodes as sites for a diabetes prevention program. Health Place. 2006;12(4):449-464. [pmid: 16002320].
Hayashino Y, Shimbo T, Tsujii S, et al. Cost-effectiveness of coronary artery disease screening in asymptomatic patients with type 2 diabetes and other atherogenic risk factors in Japan: factors influencing on international application of evidence-based guidelines. Int J Cardiol. 2007;118(1):88-96. [pmid: 16949690].
Hersberger KE, Botomino A, Mancini M, et al. Sequential screening for diabetes—evaluation of a campaign in Swiss community pharmacies. Pharm World Sci. 2006;28(3):171-179. [pmid: 17004016].
Hsu WC, Chiu YH, Chiu HC, et al. Two-stage community-based screening model for estimating prevalence of diabetic polyneuropathy (KCIS no 6). Neuroepidemiology. 2005;25(1):1-7. [pmid: 15855798].
Ismail K, Winkley K, Rabe-Hesketh S. Systematic review and meta-analysis of randomised controlled trials of psychological interventions to improve glycaemic control in patients with type 2 diabetes. Lancet. 2004;363(9421):1589-1597. [pmid: 15145632].
Knowler WC, Hamman RF, Edelstein SL, et al. Prevention of type 2 diabetes with troglitazone in the Diabetes Prevention Program. Diabetes. 2005;54(4):1150-1156. [pmid: 15793255]. [pmcid: 1351025].
Ko GT, Li JK, Kan EC, et al. Effects of a structured health education programme by a diabetic education nurse on cardiovascular risk factors in Chinese Type 2 diabetic patients: a 1-year prospective randomized study. Diabet Med. 2004;21(12):1274-1279. [pmid: 15569128].
Krass I, Mitchell B, Clarke P, et al. Pharmacy diabetes care program: analysis of two screening methods for undiagnosed type 2 diabetes in Australian community pharmacy. Diabetes Res Clin Pract. 2007;75(3):339-347. [pmid: 16884811].
Lepore G, Maglio ML, Nosari I, et al. Cost-effectiveness of two screening programs for microalbuminuria in type 2 diabetes. Diabetes Care. 2002;25(11):2103-2104. author reply 2104. [pmid: 12401764].
Levien TL, Baker DE, White JR Jr, et al. Insulin glargine: a new basal insulin. Ann Pharmacother. 2002;36(6):1019-1027. [pmid: 12022906].
Lidfeldt J, Nerbrand C, Samsioe G, et al. A screening procedure detecting high-yield candidates for OGTT. The Women's Health in the Lund Area (WHILA) study: a population based study of middle-aged Swedish women. Eur J Epidemiol. 2001;17(10):943-951. [pmid: 12188015].
Maddigan SL, Majumdar SR, Guirguis LM, et al. Improvements in patient-reported outcomes associated with an intervention to enhance quality of care for rural patients with type 2 diabetes: results of a controlled trial. Diabetes care. 2004;27(6):1306-1312. [pmid: 15161780].
Madsen MM, Busk M, Sondergaard HM, et al. Does diabetes mellitus abolish the beneficial effect of primary coronary angioplasty on long-term risk of reinfarction after acute ST-segment elevation myocardial infarction compared with fibrinolysis? (A DANAMI-2 substudy). Am J Cardiol. 2005;96(11):1469-1475. [pmid: 16310424].
Martin S, Schneider B, Heinemann L, et al. Self-monitoring of blood glucose in type 2 diabetes and long-term outcome: an epidemiological cohort study. Diabetologia. 2006;49(2):271-278. [pmid: 16362814].
Matchar DB, McCrory DC, Orlando LA, et al. Comparative effectiveness of angiotensin-converting enzyme inhibitors (ACEIs) and angiotensin II receptor antagonists (ARBs) for treating essentail hypertension. Ann Intern Med. 2008;148(1):16-29. [pmid: 17984484].
McKay HG, King D, Eakin EG, et al. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care. 2001;24(8):1328-1334. [pmid: 11473065].
Miller TD, Redberg RF, Wackers FJT. Screening asymptomatic diabetic patients for coronary artery disease: why not?. J Am Coll Cardiol. 2006;48(4):761-764. [pmid: 16904546].
Mueller E, Maxion-Bergemann S, Gultyaev D, et al. Development and validation of the Economic Assessment of Glycemic Control and Long-Term Effects of diabetes (EAGLE) model. Diabetes Technol Ther. 2006;8(2):219-236. [pmid: 16734551].
Newman DJ, Mattock MB, Dawnay AB, et al. Systematic review on urine albumin testing for early detection of diabetic complications. Health Technol Assess. 2005;9(30):iii-vi.
Niklason A, Hedner T, Niskanen L, et al. Development of diabetes is retarded by ACE inhibition in hypertensive patients—a subanalysis of the Captopril Prevention Project (CAPPP). J Hypertens. 2004;22(3):645-652. [pmid: 15076172].
Park J, Edington DW. Application of a prediction model for identification of individuals at diabetic risk. Methods Inf Med. 2004;43(3):273-281. [pmid: 15227557].
Park PJ, Griffin SJ, Sargeant L, et al. The performance of a risk score in predicting undiagnosed hyperglycemia. Diabetes Care. 2002;25(6):984-988. [pmid: 12032103].
Qureshi N, Standen PJ, Hapgood R, et al. A randomized controlled trial to assess the psychological impact of a family history screening questionnaire in general practice. Family Practice. 2001;18(1):78-83. [pmid: 11145633].
Rakhit DJ, Downey M, Jeffries L, et al. Screening for coronary artery disease in patients with diabetes: a Bayesian strategy of clinical risk evaluation and exercise echocardiography. Am Heart J. 2005;150(5):1074-1080. [pmid: 16291001].
Ramachandran A, Snehalatha C, Vijay V, et al. Derivation and validation of diabetes risk score for urban Asian Indians. Diabetes Res Clin Pract. 2005;70(1):63-70. [pmid: 16126124].
Rathmann W, Martin S, Haastert B, et al. Performance of screening questionnaires and risk scores for undiagnosed diabetes: the KORA Survey 2000. Arch Intern Med. 2005;165(4):436-441. [pmid: 15738374].
Rubak S, Sandbaek A, Lauritzen T, et al. An education and training course in motivational interviewing influence: GPs' professional behaviour—ADDITION Denmark. Br J Gen Pract. 2006;56(527):429-436. [pmid: 16762124]. [pmcid: 1839017].
Schmidt MI, Duncan BB, Vigo A, et al. Detection of undiagnosed diabetes and other hyperglycemia states: the Atherosclerosis Risk in Communities Study. Diabetes Care. 2003;26(5):1338-1343. [pmid: 12716785].
Schwedes U, Siebolds M, Mertes G. Meal-related structured self-monitoring of blood glucose: effect on diabetes control in non-insulin-treated type 2 diabetic patients. Diabetes care. 2002;25(11):1928-1932. [pmid: 12401734].
Scognamiglio R, Negut C, Ramondo A, et al. Detection of coronary artery disease in asymptomatic patients with type 2 diabetes mellitus. J Am Coll Cardiol. 2006;47(1):65-71. [pmid: 16386666].
Shojania KG, Ranji SR, McDonald KM, et al. Effects of quality improvement strategies for type 2 diabetes on glycemic control: a meta-regression analysis. JAMA. 2006;296(4):427-440. [pmid: 16868301].
Spijkerman AM, Yuyun MF, Griffin SJ, et al. The performance of a risk score as a screening test for undiagnosed hyperglycemia in ethnic minority groups: data from the 1999 health survey for England. Diabetes Care. 2004;27(1):116-122. [pmid: 14693976].
Tabaei BP, Engelgau MM, Herman WH. A multivariate logistic regression equation to screen for dysglycaemia: development and validation. Diabet Med. 2005;22(5):599-605. [pmid: 15842515].
Treatment; Elliott WJ, Meyer PM. Incident diabetes in clinical trials of antihypertensive drugs: a network meta-analysis. Lancet. 2007;369(9557):201–207.
Verdecchia P, Angeli F, Gattobigio R, et al. Do angiotensin II receptor blockers increase the risk of myocardial infarction?. Eur Heart J. 2005;26(22):2381-2386. [pmid: 16081468].
Wang F, Carabino JM, Vergara CM. Insulin glargine: a systematic review of a long-acting insulin analogue. Clin Ther. 2003;25(6):1541-1577. [pmid: 12860485].
Wang XL, Lu JM, Pan CY, et al. A comparison of urinary albumin excretion rate and microalbuminuria in various glucose tolerance subjects. Diabet Med. 2005;22(3):332-335. [pmid: 15717883].
Warren E, Weatherley-Jones E, Chilcott J, et al. Systematic review and economic evaluation of a long-acting insulin analogue, insulin glargine. Health Technol Assess. 2004;8(45):iii.
Yoshioka K, Yoshida T, Yoshikawa T. Short-term intensive insulin therapy in newly diagnosed type 2 diabetes: response to Ryan, Imes, and Wallace. Diabetes Care. 2004;27(9):2281-2282. author reply 2282–2283. [pmid: 15333506].

### Wrong Outcome(s)

Adriaanse MC, Snoek FJ, Dekker JM, et al. Perceived risk for Type 2 diabetes in participants in a stepwise population-screening programme. Diabetic Med. 2003;20(3):210-215. [pmid: 12675665].
Anand SS. Quantifying effect of statins on low density lipoprotein cholesterol, ischaemic heart disease, and stroke: systematic review and meta-analysis. Vasc Med. 2003;8(4):289-290. [pmid: 15125495].
Areosa SA, Grimley EV. Effect of the treatment of Type II diabetes mellitus on the development of cognitive impairment and dementia. Cochrane Database of Syst Rev. 2002(4):CD003804.
Aronoff S, Rosenblatt S, Braithwaite S, et al. Pioglitazone hydrochloride monotherapy improves glycemic control in the treatment of patients with type 2 diabetes: a 6-month randomized placebo-controlled dose-response study. The Pioglitazone 001 Study Group. Diabetes Care. 2000;23:1605-1611. [pmid: 11092281].
Barnett AH, Anderson DM, Shelley S, et al. A placebo-controlled crossover study comparing the effects of nateglinide and glibenclamide on postprandial hyperglycaemia and hyperinsulinaemia in patients with type 2 diabetes. Diabetes Obes Metab. 2004;6(2):104-113. [pmid: 14746575].
Bennett SM, Agrawal A, Elasha H, et al. Rosiglitazone improves insulin sensitivity, glucose tolerance and ambulatory blood pressure in subjects with impaired glucose tolerance. Diabet Med. 2004;21(5):415-422. [pmid: 15089784].
Berne C. the Orlistat Swedish Type 2 diabetes Study Group. A randomized study of orlistat in combination with a weight management programme in obese patients with Type 2 diabetes treated with metformin. Diabet Med. 2005;22(5):612-618. [pmid: 15842517].
Boule NG, Haddad E, Kenny GP, et al. Effects of exercise on glycemic control and body mass in type 2 diabetes mellitus: a meta-analysis of Control Clin Trials. JAMA. 2001;286(10):1218-1227. [pmid: 11559268].
Boule NG, Kenny GP, Haddad E, et al. Meta-analysis of the effect of structured exercise training on cardiorespiratory fitness in Type 2 diabetes mellitus. Diabetologia. 2003;46(8):1071-1081. [pmid: 12856082].
Buse JB, Tan MH, Prince MJ, et al. The effects of oral anti-hyperglycaemic medications on serum lipid profiles in patients with type 2 diabetes. Diabetes Obes Metab. 2004;6(2):133-156. [pmid: 14746579].
Carnevale Schianca GP, Rossi A, Sainaghi PP, et al. The significance of impaired fasting glucose versus impaired glucose tolerance: importance of insulin secretion and resistance. Diabetes Care. 2003;26(5):1333-1337. [pmid: 12716784].
Chapin RB, Williams DC, Adair RF. Diabetes control improved when inner-city patients received graphic feedback about glycosylated hemoglobin levels. J Gen Intern Med. 2003;18(2):120-124. [pmid: 12542586]. [pmcid: 1494817].
Charbonnel B, Karasik A, Liu J, et al. Efficacy and safety of the dipeptidyl peptidase-4 inhibitor sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes inadequately controlled with metformin alone. Diabetes Care. 2006;29(12):2638-2643. [pmid: 17130197].
Chaturvedi N, Sjoelie AK, Svensson A. The DIabetic Retinopathy Candesartan Trials (DIRECT) Programme, rationale and study design. J Renin Angiotensin Aldosterone Syst. 2002;3(4):255-261. [pmid: 12584669].
Chilcott J, Tappenden P, Jones ML, et al. A systematic review of the clinical effectiveness of pioglitazone in the treatment of type 2 diabetes mellitus. Clin Ther. 2001;23(11):1792-1823. discussion 1791. [pmid: 11768834].
Chiquette E, Ramirez G, Defronzo R. A meta-analysis comparing the effect of thiazolidinediones on cardiovascular risk factors. Arch Intern Med. 2004;164(19):2097-2104. [pmid: 15505122].
Clancy DE, Huang P, Okonofua E, et al. Group visits: promoting adherence to diabetes guidelines. J Gen Intern Med. 2007;22(5):620-624. [pmid: 17443369]. [pmcid: 1852919].
Costa A, Casamitjana R, Casals E, et al. Effects of atorvastatin on glucose homeostasis, postprandial triglyceride response and C-reactive protein in subjects with impaired fasting glucose. Diabet Med. 2003;20(9):743-745. [pmid: 12925055].
Culy CR, Jarvis B. Repaglinide: a review of its therapeutic use in type 2 diabetes mellitus. Drugs. 2001;61(11):1625-1660. [pmid: 11577798].
Dallinga-Thie GM, Berk P II, Bootsma AH, et al. Atorvastatin decreases apolipoprotein C-III in apolipoprotein B-containing lipoprotein and HDL in type 2 diabetes: a potential mechanism to lower plasma triglycerides. Diabetes Care. 2004;27(6):1358-1364. [pmid: 15161788].
Davis-Smith M. Implementing a diabetes prevention program in a rural African-American church. J Natl Med Assoc. 2007;99(4):440-446. [pmid: 17444435]. [pmcid: 2569663].
Deakin T, McShane CE, Cade JE, et al. Group based training for self-management strategies in people with type 2 diabetes mellitus. Cochrane Database of Syst Rev.. 2005(2):CD003417.
Dejager S, Razac S, Foley JE, et al. Vildagliptin in drug-naive patients with type 2 diabetes: a 24-week, double-blind, randomized, placebo-controlled, multiple-dose study. Horm Metab Res. 2007;39(3):218-223. [pmid: 17373638].
Diabetes Prevention Program Research Group. The prevalence of retinopathy in impaired glucose tolerance and recent-onset diabetes in the Diabetes Prevention Program. Diabet Med. 2007;24(2):137-144. [pmid: 17257275]. [pmcid: 2267935].
Diamantopoulos EJ, Grigoriadou M, Ifanti G, et al. Clinical and hemorheological effects of buflomedil in diabetic subjects with intermittent claudication. Int Angiol. 2001;20(4):337-344. [pmid: 11782701].
Drent ML, Tollefsen AT, van Heusden FH, et al. Dose-dependent efficacy of miglitol, an alpha-glucosidase inhibitor, in type 2 diabetic patients on diet alone: results of a 24-week double-blind placebo-controlled study. Diabetes Nutr Metab Clin Exp. 2002;15(3):152-159.
Einhorn D, Rendell M, Rosenzweig J, et al. Pioglitazone hydrochloride in combination with metformin in the treatment of type 2 diabetes mellitus: a randomized, placebo-controlled study. The Pioglitazone 027 Study Group. Clin Ther. 2000;22(12):1395-1409. [pmid: 11192132].
Finer N, Ryan DH, Renz CL, et al. Prediction of response to sibutramine therapy in obese non-diabetic and diabetic patients. Diabetes Obes Metab. 2006;8(2):206-213. [pmid: 16448525].
Fujioka K, Brazg RL, Raz I, et al. Efficacy, dose-response relationship and safety of once-daily extended-release metformin (Glucophage XR) in type 2 diabetic patients with inadequate glycaemic control despite prior treatment with diet and exercise: results from two double-blind, placebo-controlled studies. Diabetes Obes Metab. 2005;7(1):28-39. [pmid: 15642073].
Glanz M, Garber AJ, Mancia G, et al. Meta-analysis of studies using selective alpha1-blockers in patients with hypertension and type 2 diabetes. Int J Clin Pract. 2001;55(10):694-701. [pmid: 11777296].
Gokcel A, Karakose H, Ertorer EM, et al. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes care. 2001;24(11):1957-1960. [pmid: 11679464].
Gress TW, Nieto FJ, Shahar E, et al. Hypertension and antihypertensive therapy as risk factors for type 2 diabetes mellitus. Atherosclerosis Risk in Communities Study. N Engl J Med. 2000;342(13):905-912. [pmid: 10738048].
Grossman E, Messerli FH. Are calcium antagonists beneficial in diabetic patients with hypertension?. Am J Med. 2004;116(1):44-49. [pmid: 14706665].
Grundy SM, Vega GL, McGovern ME, et al. Efficacy, safety, and tolerability of once-daily niacin for the treatment of dyslipidemia associated with type 2 diabetes: results of the assessment of diabetes control and evaluation of the efficacy of niaspan trial. Arch Intern Med. 2002;162(14):1568-1576. [pmid: 12123399].
Guy-Grand B, Drouin P, Eschwege E, et al. Effects of orlistat on obesity-related diseases - a six-month randomized trial. Diabetes Obes Metab. 2004;6(5):375-383. [pmid: 15287931].
Hallsten K, Virtanen KA, Lonnqvist F, et al. Rosiglitazone but not metformin enhances insulin- and exercise-stimulated skeletal muscle glucose uptake in patients with newly diagnosed type 2 diabetes. Diabetes. 2002;51(12):3479-3485. [pmid: 12453903].
Halpern A, Mancini MC, Suplicy H, et al. Latin-American trial of orlistat for weight loss and improvement in glycaemic profile in obese diabetic patients. Diabetes Obes Metab. 2003;5(3):180-188. [pmid: 12681025].
Hanefeld M, Chiasson JL, Koehler C, et al. Acarbose slows progression of intima-media thickness of the carotid arteries in subjects with impaired glucose tolerance. Stroke. 2004;35(5):1073-1078. [pmid: 15073402].
Hanefeld M, Sachse G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2002;4(6):415-423. [pmid: 12406041].
Harder H, Nielsen L, Tu DT, et al. The effect of liraglutide, a long-acting glucagon-like peptide 1 derivative, on glycemic control, body composition, and 24-h energy expenditure in patients with type 2 diabetes. Diabetes care. 2004;27(8):1915-1921. [pmid: 15277417].
Hasche H, Mertes G, Bruns C, et al. Effects of acarbose treatment in Type 2 diabetic patients under dietary training: a multicentre, double-blind, placebo-controlled, 2-year study. Diabetes Nutr Metab Clin Exp. 1999;12(4):277-285.
Herman WH, Brandle M, Zhang P, et al. Costs associated with the primary prevention of type 2 diabetes mellitus in the diabetes prevention program. Diabetes Care. 2003;26(1):36-47. [pmid: 12502656]. [pmcid: 1402339].
Himmelmann A, Hansson L, Hedner T. The Captopril Prevention Project, further analyses on left ventricular hypertrophy and diabetes. Blood Press. 2001;10(2):60-61. [pmid: 11467761].
Hollander P. Endocannabinoid blockade for improving glycemic control and lipids in patients with type 2 diabetes mellitus. Am J Med. 2007;120(2 Suppl 1):S18-28. discussion S29–32.
Hurwitz B, Goodman C, Yudkin J. Prompting the clinical care of non-insulin dependent (type II) diabetic patients in an inner city area: one model of community care. Bmj. 1993;306(6878):624-630. [pmid: 8461815]. [pmcid: 1676949].
Irons BK, Kroon LA. Lipid management with statins in type 2 diabetes mellitus. Ann Pharmacother. 2005;39(10):1714-1719. [pmid: 16118264].
Jain R, Osei K, Kupfer S, et al. Long-term safety of pioglitazone versus glyburide in patients with recently diagnosed type 2 diabetes mellitus. Pharmacotherapy. 2006;26(10):1388-1395. [pmid: 16999648].
Josse RG, Chiasson JL, Ryan EA, et al. Acarbose in the treatment of elderly patients with type 2 diabetes. Diabetes Res Clin Pract. 2003;59(1):37-42. [pmid: 12482640].
Kabadi MU, Kabadi UM. Effects of glimepiride on insulin secretion and sensitivity in patients with recently diagnosed type 2 diabetes mellitus. Clin Ther. 2004;26(1):63-69. [pmid: 14996518].
Kahn SE, Haffner SM, Heise MA, et al. Glycemic durability of rosiglitazone, metformin, or glyburide monotherapy. N Engl J Med. 2006;355(23):2427-2443. [pmid: 17145742].
Kelley DE, Bray GA, Pi-Sunyer FX, et al. Clinical efficacy of orlistat therapy in overweight and obese patients with insulin-treated type 2 diabetes: A 1-year randomized controlled trial. Diabetes Care. 2002;25(6):1033-1041. [pmid: 12032111].
Khajehdehi P, Roozbeh J, Mostafavi H. A comparative randomized and placebo-controlled short-term trial of aspirin and dipyridamole for overt type-2 diabetic nephropathy. Scand J Urol Nephrol. 2002;36(2):145-148. [pmid: 12028688].
Kipnes MS, Krosnick A, Rendell MS, et al. Pioglitazone hydrochloride in combination with sulfonylurea therapy improves glycemic control in patients with type 2 diabetes mellitus: a randomized, placebo-controlled study. The Am J Med. 2001;111(1):10-17.
Kirk A, Mutrie N, MacIntyre P, et al. Effects of a 12-month physical activity counselling intervention on glycaemic control and on the status of cardiovascular risk factors in people with Type 2 diabetes. Diabetologia. 2004;47(5):821-832. [pmid: 15138687].
Kirkman MS, Shankar RR, Shankar S, et al. Treating postprandial hyperglycemia does not appear to delay progression of early type 2 diabetes: the Early Diabetes Intervention Program. Diabetes Care. 2006;29(9):2095-2101. [pmid: 16936159].
Kohner EM, Stratton IM, Aldington SJ, et al. Relationship between the severity of retinopathy and progression to photocoagulation in patients with Type 2 diabetes mellitus in the UKPDS (UKPDS 52). Diabet Med. 2001;18(3):178-184. [pmid: 11318837].
Kuo SW, Pei D, Hung YJ, et al. Effect of indapamide SR in the treatment of hypertensive patients with type 2 diabetes. American J Hypertens. 2003;16(8):623-628.
Lebovitz HE, Dole JF, Patwardhan R, et al. Rosiglitazone monotherapy is effective in patients with type 2 diabetes. J Clin Endocrinol Metab. 2001;86(1):280-288. [pmid: 11232013].
Lehtovirta M, Forsen B, Gullstrom M, et al. Metabolic effects of metformin in patients with impaired glucose tolerance. Diabet Med. 2001;18(7):578-583. [pmid: 11553189].
Levin SR, Coburn JW, Abraira C, et al. Effect of intensive glycemic control on microalbuminaria in type 2 diabetes. Diabetes Care. 2000;23:1478-1485. [pmid: 11023140].
Lewin AJ, Kipnes MS, Meneghini LF, et al. Effects of simvastatin on the lipid profile and attainment of low-density lipoprotein cholesterol goals when added to thiazolidinedione therapy in patients with type 2 diabetes mellitus: A multicenter, randomized, double-blind, placebo-controlled trial. Clin Ther. 2004;26(3):379-389. [pmid: 15110130].
Li G, Hu Y, Yang W, et al. Effects of insulin resistance and insulin secretion on the efficacy of interventions to retard development of type 2 diabetes mellitus: the DA Qing IGT and Diabetes Study. Diabetes Res Clin Pract. 2002;58(3):193-200. [pmid: 12413779].
Li Z, Maglione M, Tu W, et al. Meta-analysis: pharmacologic treatment of obesity. Ann Intern Med. 2005;142(7):532-546. [pmid: 15809465].
Malmqvist K, Kahan T, Isaksson H, et al. Regression of left ventricular mass with captopril and metoprolol, and the effects on glucose and lipid metabolism. Blood Press. 2001;10(2):101-110. [pmid: 11467759].
Manzella D, Grella R, Esposito K, et al. Blood pressure and cardiac autonomic nervous system in obese type 2 diabetic patients: effect of metformin administration. American J Hypertens. 2004;17(3):223-227.
Mayer-Davis EJ, D'Antonio A, Martin M, et al. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds Off with Empowerment (POWER). Fam Community Health. 2001;24(2):27-35.
McKibbin CL, Patterson TL, Norman G, et al. A lifestyle intervention for older schizophrenia patients with diabetes mellitus: a randomized controlled trial. Schizophr Res. 2006;86(13):36-44. [pmid: 16842977].
Mensink M, Blaak EE, Corpeleijn E, et al. Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res. 2003;11(12):1588-1596. [pmid: 14694225].
Mensink M, Corpeleijn E, Feskens EJ, et al. Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61(1):49-58. [pmid: 12849923].
Mensink M, Feskens EJ, Saris WH, et al. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): preliminary results after one year. Int J Obes Relat Metab Disord. 2003;27(3):377-384. [pmid: 12629566].
Miles JM, Leiter L, Hollander P, et al. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002;25(7):1123-1128. [pmid: 12087008].
Miller CK, Edwards L, Kissling G, et al. Nutrition education improves metabolic outcomes among older adults with diabetes mellitus: results from a randomized controlled trial. Prev Med. 2002;34(2):252-259. [pmid: 11817922].
Moore H, Summerbell C, Hooper L, et al. Dietary advice for treatment of type 2 diabetes mellitus in adults. Cochrane Database of Syst Rev. 2006(3).
Moore H, Summerbell C, Hooper L, et al. Dietary advice for treatment of type 2 diabetes mellitus in adults. Cochrane Database of Syst Rev. 2004(3):CD004097.
Ng TW, Watts GF, Stuckey BG, et al. Does pravastatin increase chylomicron remnant catabolism in postmenopausal women with type 2 diabetes mellitus?. Clin Endocrinol (Oxf). 2005;63(6):650-656. [pmid: 16343099].
Nichols GA, Brown JB. The impact of cardiovascular disease on medical care costs in subjects with and without type 2 diabetes. Diabetes Care. 2002;25(3):482-486. [pmid: 11874934].
Norris SL, Zhang X, Avenell A, et al. Long-term effectiveness of lifestyle and behavioral weight loss interventions in adults with type 2 diabetes: a meta-analysis. Am J Med. 2004;117(10):762-774. [pmid: 15541326].
Norris SL, Zhang X, Avenell A, et al. Long-term non-pharmacological weight loss interventions for adults with type 2 diabetes mellitus. Cochrane Database of Syst Rev. 2006(3).
Norris SL, Zhang X, Avenell A, et al. Efficacy of pharmacotherapy for weight loss in adults with type 2 diabetes mellitus: a meta-analysis. Arch Intern Med. 2004;164(13):1395-1404. [pmid: 15249348].
Norris SL, Zhang X, Avenell A, et al. Pharmacotherapy for weight loss in adults with type 2 diabetes mellitus Cochrane Database of Syst Rev. 2006(3).
O'Brien JA, Patrick AR, Caro J. Estimates of direct medical costs for microvascular and macrovascular complications resulting from type 2 diabetes mellitus in the United States in 2000. Clin Ther. 2003;25(3):1017-1038. [pmid: 12852716].
Oldroyd JC, Unwin NC, White M, et al. Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001;52(1):29-43. [pmid: 11182214].
Parker B, Noakes M, Luscombe N, et al. Effect of a high-protein, high-monounsaturated fat weight loss diet on glycemic control and lipid levels in type 2 diabetes. Diabetes Care. 2002;25(3):425-430. [pmid: 11874925].
Pierce M, Ridout D, Harding D, et al. More good than harm: a randomised controlled trial of the effect of education about familial risk of diabetes on psychological outcomes. Br J Gen Pract. 2000;50(460):867-871. [pmid: 11141871]. [pmcid: 1313849].
Pistrosch F, Herbrig K, Kindel B, et al. Rosiglitazone improves glomerular hyperfiltration, renal endothelial dysfunction, and microalbuminuria of incipient diabetic nephropathy in patients. Diabetes. 2005;54(7):2206-2211. [pmid: 15983223].
Playford DA, Watts GF, Croft KD, et al. Combined effect of coenzyme Q10 and fenofibrate on forearm microcirculatory function in type 2 diabetes. Atherosclerosis. 2003;168(1):169-179. [pmid: 12732401].
Pontiroli AE, Pizzocri P, Librenti MC, et al. Laparoscopic adjustable gastric banding for the treatment of morbid (grade 3) obesity and its metabolic complications: a three-year study. J Clin Endocrinol Metab. 2002;87(8):3555-3561. [pmid: 12161474].
Pontrelli L, Parris W, Adeli K, et al. Atorvastatin treatment beneficially alters the lipoprotein profile and increases low-density lipoprotein particle diameter in patients with combined dyslipidemia and impaired fasting glucose/type 2 diabetes. Metabolism. 2002;51(3):334-342. [pmid: 11887170].
Redmon JB, Raatz SK, Reck KP, et al. One-year outcome of a combination of weight loss therapies for subjects with type 2 diabetes: a randomized trial. Diabetes Care. 2003;26(9):2505-2511. [pmid: 12941710].
Redmon JB, Reck KP, Raatz SK, et al. Two-year outcome of a combination of weight loss therapies for type 2 diabetes. Diabetes Care. 2005;28(6):1311-1315. [pmid: 15920044].
Robins SJ, Rubins HB, Faas FH, et al. Insulin resistance and cardiovascular events with low HDL cholesterol: the Veterans Affairs HDL Intervention Trial (VA-HIT). Diabetes Care. 2003;26(5):1513-1517. [pmid: 12716814].
Rosenstock J, Einhorn D, Hershon K, et al. Efficacy and safety of pioglitazone in type 2 diabetes: a randomised, placebo-controlled study in patients receiving stable insulin therapy. Int J Clin Pract. 2002;56(4):251-257. [pmid: 12074206].
Saloranta C, Guitard C, Pecher E, et al. Nateglinide improves early insulin secretion and controls postprandial glucose excursions in a prediabetic population. Diabetes Care. 2002;25(12):2141-2146. [pmid: 12453951].
Saloranta C, Hershon K, Ball M, et al. Efficacy and safety of nateglinide in type 2 diabetic patients with modest fasting hyperglycemia. J Clin Endocrinol Metab. 2002;87(9):4171-4176. [pmid: 12213867].
Satoh N, Shimatsu A, Yamada K, et al. An alpha-glucosidase inhibitor, voglibose, reduces oxidative stress markers and soluble intercellular adhesion molecule 1 in obese type 2 diabetic patients. Metabolism. 2006;55(6):786-793. [pmid: 16713439].
Scharnagl H, Winkler K, Mantz S, et al. Inhibition of HMG-CoA reductase with cerivastatin lowers dense low density lipoproteins in patients with elevated fasting glucose, impaired glucose tolerance and type 2 diabetes mellitus. Exp Clin Endocrinol Diabetes. 2004;112(5):269-277. [pmid: 15146374].
Shi YF, Pan CY, Hill J, et al. Orlistat in the treatment of overweight or obese Chinese patients with newly diagnosed Type 2 diabetes. Diabet Med. 2005;22(12):1737-1743. [pmid: 16401321].
Sidorov J, Shull R, Tomcavage J, et al. Does diabetes disease management save money and improve outcomes? A report of simultaneous short-term savings and quality improvement associated with a health maintenance organization-sponsored disease management program among patients fulfilling health employer data and information set criteria. Diabetes Care. 2002;25(4):684-689. [pmid: 11919125].
Smith SR, De Jonge L, Volaufova J, et al. Effect of pioglitazone on body composition and energy expenditure: a randomized controlled trial. Metabolism. 2005;54(1):24-32.
Snella KA, Canales AE, Irons BK, et al. Pharmacy- and community-based screenings for diabetes and cardiovascular conditions in high-risk individuals. J Am Pharm Assoc. 2006;46(3):370-377.
Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes care. 2001;24(4):619-624. [pmid: 11315819].
Swinburn BA, Woollard GA, Chang EC, et al. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. J Am Diet Assoc. 1999;99(11):1400-1405. [pmid: 10570677].
Tan MH, Johns D, Glazer NB. Pioglitazone reduces atherogenic index of plasma in patients with type 2 diabetes. Clin Chem. 2004;50(7):1184-1188. [pmid: 15117857].
Tate DF, Jackvony EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. JAMA. 2003;289(14):1833-1836. [pmid: 12684363].
Treatment; O'Meara S, Riemsma R, Shirran L, et al. A systematic review of the clinical effectiveness of orlistat used for the management of obesity. Obes Rev. 2004;5(1):51–68.
Tudor-Locke C, Bell RC, Myers AM, et al. Controlled outcome evaluation of the First Step Program: a daily physical activity intervention for individuals with type II diabetes. Int J Obes Relat Metab Disord. 2004;28(1):113-119. [pmid: 14569279].
van Wijk JP, de Koning EJ, Castro Cabezas M, et al. Rosiglitazone improves postprandial triglyceride and free fatty acid metabolism in type 2 diabetes. Diabetes Care. 2005;28(4):844-849. [pmid: 15793183].
van Wijk JP, de Koning EJ, Martens EP, et al. Thiazolidinediones and blood lipids in type 2 diabetes. Arterioscler Thromb Vasc Biol. 2003;23(10):1744-1749. [pmid: 12907465].
Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6(4):e44. [pmid: 15631968].
Vettor R, Serra R, Fabris R, et al. Effect of sibutramine on weight management and metabolic control in type 2 diabetes: a meta-analysis of clinical studies. Diabetes Care. 2005;28(4):942-949. [pmid: 15793204].
Viberti G, Wheeldon NM. MicroAlbuminuria Reduction With VSI. Microalbuminuria reduction with valsartan in patients with type 2 diabetes mellitus: a blood pressure-independent effect. Circulation. 2002;106(6):672-678. [pmid: 12163426].
Virtanen KA, Hallsten K, Parkkola R, et al. Differential effects of rosiglitazone and metformin on adipose tissue distribution and glucose uptake in type 2 diabetic subjects. Diabetes. 2003;52(2):283-290. [pmid: 12540598].
Viviani GL. Lercanidipine in type II diabetic patients with mild to moderate arterial hypertension. J Cardiovasc Pharmacol. 2002;40(1):133-139. [pmid: 12072586].
Wang TF, Pei D, Li JC, et al. Effects of sibutramine in overweight, poorly controlled Chinese female type 2 diabetic patients: a randomised, double-blind, placebo-controlled study. Int J Clin Pract. 2005;59(7):746-750. [pmid: 15963197].
Whitelaw DC, Smith JM, Nattrass M. Effects of gemfibrozil on insulin resistance to fat metabolism in subjects with type 2 diabetes and hypertriglyceridaemia. Diabetes Obes Metab. 2002;4(3):187-194. [pmid: 12047397].
Winkler K, Abletshauser C, Friedrich I, et al. Fluvastatin slow-release lowers platelet-activating factor acetyl hydrolase activity: a placebo-controlled trial in patients with type 2 diabetes. J Clin Endocrinol Metab. 2004;89(3):1153-1159. [pmid: 15001601].
Winkler K, Abletshauser C, Hoffmann MM, et al. Effect of fluvastatin slow-release on low density lipoprotein (LDL) subfractions in patients with type 2 diabetes mellitus: baseline LDL profile determines specific mode of action. J Clin Endocrinol Metab. 2002;87(12):5485-5490. [pmid: 12466341].
Wolever TM, Mehling C. High-carbohydrate-low-glycaemic index dietary advice improves glucose disposition index in subjects with impaired glucose tolerance. Br J Nutr. 2002;87(5):477-487. [pmid: 12010586].
Woollard J, Burke V, Beilin LJ, et al. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. J Cardiovasc Risk. 2003;10(1):31-40. [pmid: 12569235].
Wright AD, Cull CA, Macleod KM, et al. Hypoglycemia in Type 2 diabetic patients randomized to and maintained on monotherapy with diet, sulfonylurea, metformin, or insulin for 6 years from diagnosis: UKPDS73. J Diabetes Complications. 2006;20(6):395-401. [pmid: 17070446].
Wulffele MG, Kooy A, de Zeeuw D, et al. The effect of metformin on blood pressure, plasma cholesterol and triglycerides in type 2 diabetes mellitus: a systematic review. J Intern Med. 2004;256(1):1-14. [pmid: 15189360].
Wulffele MG, Kooy A, Lehert P, et al. Does metformin decrease blood pressure in patients with Type 2 diabetes intensively treated with insulin?. Diabet Med. 2005;22(7):907-913. [pmid: 15975107].
Xiang AH, Peters RK, Kjos SL, et al. Effect of pioglitazone on pancreatic beta-cell function and diabetes risk in Hispanic women with prior gestational diabetes. Diabetes. 2006;55(2):517-522. [pmid: 16443789]. [pmcid: 1389697].
Yoo BK, Triller DM, Yoo DJ. Exenatide: a new option for the treatment of type 2 diabetes. Ann Pharmacother. 2006;40(10):1777-1784. [pmid: 16985091].
Zanchetti A, Rosei EA, Dal Palu C, et al. The Verapamil in Hypertension and Atherosclerosis Study (VHAS): results of long-term randomized treatment with either verapamil or chlorthalidone on carotid intima-media thickness. J Hypertens. 1998;16(11):1667-1676. [pmid: 9856368].
Zandbergen AA, Lamberts SW, Baggen MG, et al. The IGF-I system and the renal and haemodynamic effects of losartan in normotensive patients with type 2 diabetes mellitus: a randomized clinical trial. Clin Endocrinol (Oxf). 2006;64(2):203-208. [pmid: 16430721].
Zeymer U, Schwarzmaier-D'assie A, Petzinna D, et al. Effect of acarbose treatment on the risk of silent myocardial infarctions in patients with impaired glucose tolerance: results of the randomised STOP-NIDDM trial electrocardiography substudy. Eur J Cardiovasc Prev Rehabil. 2004;11(5):412-415. [pmid: 15616415].

### Wrong Study Design or Publication Type or No Data Provided

Abdel-Gayoum AG. The effect of glycemic control in type 2 diabetic patients with diabetes-related dyslipidemia. Saudi Med J. 2004;25(2):207-211. [pmid: 14968220].
Abramson J. Comments on the MRC/BHF Heart Protection Study. Lancet. 2003;362(9385):745-746. [pmid: 12957104].
Adam FMS, Adam JMF, Pandeleki N, et al. Asymptomatic diabetes: the difference between population-based and office-based screening. Acta Med Indones. 2006;38(2):67-71. [pmid: 16799205].
Adler AI, Stevens RJ, Manley SE, et al. Development and progression of nephropathy in type 2 diabetes: the United Kingdom Prospective Diabetes Study (UKPDS 64). Kidney Int. 2003;63(1):225-232. [pmid: 12472787].
Adler AI, Stevens RJ, Neil A, et al. UKPDS 59: hyperglycemia and other potentially modifiable risk factors for peripheral vascular disease in type 2 diabetes. Diabetes Care. 2002;25(5):894-899. [pmid: 11978687].
Agaba EI, Agaba PA, Puepet FH. Prevalence of microalbuminuria in newly diagnosed type 2 diabetic patients in Jos Nigeria. Afr J Med Med Sci. 2004;33(1):19-22. [pmid: 15490788].
Ahmad J, Singh M, Kumar S. Kidney functions in newly diagnosed type 2 diabetic subjects: role of glycemic control. J Assoc Physicians India. 2002;50:882-886. [pmid: 12126340].
Airey M, Bennett C, Nicolucci A, et al. Aldose reductase inhibitors for the prevention and treatment of diabetic peripheral neuropathy. Cochrane Database of Syst Rev. 2006(3).
Albert S. Cost-effective management of recalcitrant diabetic foot ulcers. Clin Podiatr Med Surg. 2002;19(4):483-491. [pmid: 12471856].
Alberti KG, Zimmet PZ, Alberti KG, et al. Definition, diagnosis and classification of diabetes mellitus and its complications. Part 1: diagnosis and classification of diabetes mellitus provisional report of a WHO consultation. Diabet Med. 1998;15(7):539-553. [pmid: 9686693].
Al-Delaimy WK, Willett WC, Manson JE, et al. Smoking and mortality among women with type 2 diabetes: The Nurses' Health Study cohort. Diabetes Care. 2001;24(12):2043-2048. [pmid: 11723080].
Alvarsson M, Sundkvist G, Lager I, et al. Beneficial effects of insulin versus sulphonylurea on insulin secretion and metabolic control in recently diagnosed type 2 diabetic patients. Diabetes Care. 2003;26(8):2231-2237. [pmid: 12882841].
American Diabetes Association. Implications of the United Kingdom Prospective Diabetes Study. Diabetes Care. 2000;23(Suppl 1):S27-31. [pmid: 12017673].
American Diabetes Association. Screening for type 2 diabetes. Diabetes Care. 2003;26(Suppl 1):S21-24. [pmid: 12502615].
American Diabetes Association. Screening for type 2 diabetes. Diabetes Care. 1998;21(Supp 1):S20-22.
Grundy SM. American Heart Association, National Heart LaBI, et al. Diagnosis and management of the metabolic syndrome. An American Heart Association/National Heart, Lung, and Blood Institute Scientific Statement. Executive summary. Cardiol Rev. 2005;13(6):322-327. [pmid: 16708441].
Andersen HR, Nielsen TT, Vesterlund T, et al. Danish multicenter randomized study on fibrinolytic therapy versus acute coronary angioplasty in acute myocardial infarction: rationale and design of the DANish trial in Acute Myocardial Infarction-2 (DANAMI-2). Am Heart J. 2003;146(2):234-241. [pmid: 12891190].
Andersson DK, Svardsudd K. Long-term glycemic control relates to mortality in type II diabetes. Diabetes Care. 1995;18:1534-1543. [pmid: 8722048].
Ando M, Ando S, Takeuchi T. Preliminary study of psychological factors affecting clinic attendance and glycemic control of Japanese patients with type 2 diabetes mellitus. Psychol Rep. 2005;96(1):129-132. [pmid: 15825915].
Anonymous. Fish oil supplements. Med Lett Drugs Ther. 2006;48(1239):59–60.
Anonymous. Insulin detemir (levemir), a new long-acting insulin. Med Lett Drugs Ther. 2006;48(1238):54–55.
Anonymous. Insuline glusine (Apidra): a new rapid-acting insulin. Med Lett Drugs Ther. 2006;48(1233):33–34.
Anonymous. Statins for high-risk patients without heart disease or high cholesterol. Med Lett Drugs Ther. 2006;48(1225):1–3.
Anonymous. Screening for type 2 diabetes mellitus. HSTAT. 2003.
Arab D, Lewis B, Cho L, et al. Antiplatelet therapy in anticoagulated patients requiring coronary intervention. J Invasive Cardiol. 2005;17(10):549-554. [pmid: 16204751].
Aronow WS. Oral sulfonylureas and CV mortality. Geriatrics. 2004;59(9):45-46.
Ashraf R, Amir K, Shaikh AR. Comparison between duration dependent effects of Simvastatin and Gemfibrozil on dyslipidemia in patients with type 2 diabetes. J Pak Med Assoc. 2005;55(8):324-327. [pmid: 16164158].
Avenell A, Broom J, Brown TJ, et al. Systematic review of the long-term effects and economic consequences of treatments for obesity and implications for health improvement. Health Technol Assess. 2004;8(21):iii-iv.
Baba S. Pioglitazone: a review of Japanese clinical studies. Curr Med Res Opin. 2001;17(3):166-189. [pmid: 11900311].
Bagust A, Hopkinson PK, Maslove L, et al. The projected health care burden of Type 2 diabetes in the UK from 2000 to 2060. Diabet Med. 2002;19(Suppl 4):1-5.
Bailey CJ, Del Prato S, Eddy D, et al. Earlier intervention in type 2 diabetes: the case for achieving early and sustained glycaemic control. Int J Clin Pract. 2005;59(11):1309-1316. [pmid: 16236086].
Bakris GL, Fonseca V, Katholi RE, et al. Differential effects of beta-blockers on albuminuria in patients with type 2 diabetes. Hypertension. 2005;46(6):1309-1315. [pmid: 16286578].
Bakris GL, Smith AC, Richardson DJ, et al. Impact of an ACE inhibitor and calcium antagonist on microalbuminuria and lipid subfractions in type 2 diabetes: a randomised, multi-centre pilot study. J Hum Hypertens. 2002;16(3):185-191. [pmid: 11896508].
Bakris GL, Weir M. ACE inhibitors and protection against kidney disease progression in patients with type 2 diabetes: what's the evidence. J Clin Hypertens (Greenwich). 2002;4(6):420-423. [pmid: 12461306].
Bakris GL, Weir MR. Study of Hypertension and the Efficacy of Lotrel in Diabetes I. Achieving goal blood pressure in patients with type 2 diabetes: conventional versus fixed-dose combination approaches. J Clin Hypertens (Greenwich). 2003;5(3):202-209. [pmid: 12826783].
Balducci S, Leonetti F, Di Mario U, et al. Is a long-term aerobic plus resistance training program feasible for and effective on metabolic profiles in type 2 diabetic patients?. Diabetes Care. 2004;27(3):841-842. [pmid: 14988317].
Balkau B, Eschwege E. Epidemiological data on postprandial glycaemia. Diabetes Metab. 2006;32(Spec No2):2S5-9. [pmid: 17375400].
Balkau B, Hillier T, Vierron E, et al. Creating a pandemic of prediabetes: the proposed new diagnostic criteria for impaired fasting glycaemia. Diabetologia. 2005;48(4):801-802. [pmid: 15747107].
Barnett A. Preventing renal complications in type 2 diabetes: results of the diabetics exposed to telmisartan and enalapril trial. J Am Soc Nephrol. 2006;17(4 Suppl 2):S132-135. [pmid: 16565237].
Barr RG, Nathan DM, Meigs JB, et al. Tests of glycemia for the diagnosis of type 2 diabetes mellitus. Ann Intern Med. 2002;137(4):263-272. [pmid: 12186517].
Barrett-Connor E, Ferrara A. Isolated postchallenge hyperglycemia and the risk of fatal cardiovascular disease in older women and men. The Rancho Bernardo Study. Diabetes Care. 1998;21(8):1236-1239. [pmid: 9702426].
Bartoli E, Castello L, Sainaghi PP, et al. Progression from hidden to overt type 2 diabetes mellitus: significance of screening and importance of the laboratory. Clin Lab. 2005;51(1112):613-624. [pmid: 16329619].
Barzilay JI, Davis BR, Bettencourt J, et al. Cardiovascular outcomes using doxazosin vs. chlorthalidone for the treatment of hypertension in older adults with and without glucose disorders: a report from the ALLHAT study. J Clin Hypertens. 2004;6(3):116-125.
Barzilay JI, Kronmal RA, Gottdiener JS, et al. The association of fasting glucose levels with congestive heart failure in diabetic adults > or =65 years: the Cardiovascular Health Study. J Am Coll Cardiol. 2004;43(12):2236-2241. [pmid: 15193686].
Barzilay JI, Peterson D, Cushman M, et al. The relationship of cardiovascular risk factors to microalbuminuria in older adults with or without diabetes mellitus or hypertension: the cardiovascular health study. Am J Kidney Dis. 2004;44(1):25-34. [pmid: 15211434].
Bates M, Carmody P, Haba S, et al. Screening for diabetes in general practice. Workload studies as well as clinical trials should be considered when drawing up guidelines. Bmj. 2002;324(7334):426.
Benny S, Beaven DW. Screening for type 2 diabetes. N Z Med J. 2002;115(1158):U112. [pmid: 12362187].
Berecek KH, Farag A, Bahtiyar G, et al. The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack (ALLHAT) Trial: focus on the diabetic patient. Curr Hypertens Rep. 2004;6(3):212-214. [pmid: 15128474].
Berger M. Screening for type 2 diabetes. Population screening was not effective in former East Germany. Bmj. 2001;323(7310):454. author reply 455.
Bethel MA, Sloan FA, Belsky D, et al. Longitudinal incidence and prevalence of adverse outcomes of diabetes mellitus in elderly patients. Arch Intern Med. 2007;167(9):921-927. [pmid: 17502533].
Betteridge J. Benefits of lipid-lowering therapy in patients with type 2 diabetes mellitus. Am J Med. 2005;118(Suppl 12A):10-15. [pmid: 16356802].
Black HR, Elliott WJ, Neaton JD, et al. Rationale and design for the Controlled ONset Verapamil INvestigation of Cardiovascular Endpoints (CONVINCE) Trial. Control Clin Trials. 1998;19(4):370-390. [pmid: 9683312].
Blake DR, Meigs JB, Muller DC, et al. Impaired glucose tolerance, but not impaired fasting glucose, is associated with increased levels of coronary heart disease risk factors: results from the Baltimore Longitudinal Study on Aging. Diabetes. 2004;53(8):2095-2100. [pmid: 15277391].
Bo S, Ciccone G, Gancia R, et al. Mortality within the first 10 years of the disease in type 2 diabetic patients. Nutr Metab Cardiovasc Dis. 2006;16(1):8-12. [pmid: 16399486].
Bock G, Dalla Man C, Campioni M, et al. Pathogenesis of pre-diabetes: mechanisms of fasting and postprandial hyperglycemia in people with impaired fasting glucose and/or impaired glucose tolerance. Diabetes. 2006;55(12):3536-3549. [pmid: 17130502].
Boersma C, Atthobari J, Gansevoort RT, et al. Pharmacoeconomics of angiotensin II antagonists in type 2 diabetic patients with nephropathy: implications for decision making. Pharmacoeconomics. 2006;24(6):523-535. [pmid: 16761901].
Bonds DE, Larson JC, Schwartz AV, et al. Risk of fracture in women with type 2 diabetes: the Women's Health Initiative Observational Study. J Clin Endocrinol Metab. 2006;91(9):3404-3410. [pmid: 16804043].
Borch-Johnsen K, Lauritzen T, Glmer C, et al. Screening for Type 2 diabetesshould it be now?. Diabetic Med. 2003;20(3):175-181. [pmid: 12675659].
Bourn D, Mann J. Screening for noninsulin dependent diabetes mellitus and impaired glucose tolerance. N Z Med J. 1992;105(943):207-210.
Bramlage P, Pittrow D, Kirch W. The effect of irbesartan in reducing cardiovascular risk in hypertensive type 2 diabetic patients: an observational study in 16,600 patients in primary care. Curr Med Res Opin. 2004;20(10):1625-1631. [pmid: 15462695].
Brandle M, Davidson MB, Schriger DL, et al. Cost effectiveness of statin therapy for the primary prevention of major coronary events in individuals with type 2 diabetes. Diabetes Care. 2003;26(6):1796-1801. [pmid: 12766112].
Breuer HW. Review of acarbose therapeutic strategies in the long-term treatment and in the prevention of type 2 diabetes. Int J Clin Pharmacol Ther. 2003;41(10):421-440. [pmid: 14703948].
Brown MJ, Palmer CR, Castaigne A, et al. Morbidity and mortality in patients randomised to double-blind treatment with a long-acting calcium-channel blocker or diuretic in the International Nifedipine GITS study: Intervention as a Goal in Hypertension Treatment (INSIGHT). Lancet. 2000;356(9227):366-372. [pmid: 10972368].
Brown SA, Blozis SA, Kouzekanani K, et al. Dosage effects of diabetes self-management education for Mexican Americans: the Starr County Border Health Initiative. Diabetes Care. 2005;28(3):527-532. [pmid: 15735182]. [pmcid: 1994143].
Brownlee M. A radical explanation for glucose-induced cell dysfunction. J Clin Invest. 2003;112(12):1788-1790. [pmid: 14679173]. [pmcid: 297003].
Buchanan TA. Prevention of type 2 diabetes: what is it really?. Diabetes Care. 2003;26(4):1306-1308. [pmid: 12663614].
Burnet DL, Elliott LD, Quinn MT, et al. Preventing diabetes in the clinical setting. J Gen Intern Med. 2006;21(1):84-93. [pmid: 16423130]. [pmcid: 1484626].
Bursztyn M. Losartan for cardiovascular disease in patient's with and without diabetes in the LIFE study. Lancet. 2002;359(9324):2201. author reply 2203–2204.
Campbell I, Robertson-Mackay F, Streets E, et al. Maintenance of glycaemic control with acarbose in diet treated type 2 diabetic patients. Diabetic Med. 1998;15(Suppl 2):S29-30. [pmid: 9829766].
Campbell IW. Long-term glycaemic control with pioglitazone in patients with type 2 diabetes. Int J Clin Pract. 2004;58(2):192-200. [pmid: 15055868].
Cao JJ, Barzilay JI, Peterson D, et al. The association of microalbuminuria with clinical cardiovascular disease and subclinical atherosclerosis in the elderly: the Cardiovascular Health Study. Atherosclerosis. 2006;187(2):372-377. [pmid: 16242696].
Cefalu WT, Schneider DJ, Carlson HE, et al. Effect of combination glipizide GITS/metformin on fibrinolytic and metabolic parameters in poorly controlled type 2 diabetic subjects. Diabetes Care. 2002;25(12):2123-2128. [pmid: 12453948].
Centers for Disease Control and Prevention. Prevalence of diabetes and impaired fasting glucose in adults—United States, 1999-2000. MMWR Morb Mortal Wkly Rep. 2003;52(35):833-837. [pmid: 12966357].
Chaturvedi N, Stephenson JM, Fuller JH, et al. The relationship between socioeconomic status and diabetes control and complications in the EURODIAB IDDM Complications Study. Diabetes Care. 1996;19(5):423-430. [pmid: 8732703].
Chiasson JL. Acarbose for the prevention of diabetes, hypertension, and cardiovascular disease in subjects with impaired glucose tolerance: the Study to Prevent Non-Insulin-Dependent Diabetes Mellitus (STOP-NIDDM) Trial. Endocr Pract. 2006;12(Suppl 1):25-30. [pmid: 16627376].
Chiasson JL, Brindisi MC, Rabasa-Lhoret R. The prevention of type 2 diabetes: what is the evidence?. Minerva Endocrinol. 2005;30(3):179-191. [pmid: 16208307].
Chiasson JL, Josse RG, Gomis R, et al. Acarbose for the prevention of Type 2 diabetes, hypertension and cardiovascular disease in subjects with impaired glucose tolerance: facts and interpretations concerning the critical analysis of the STOP-NIDDM Trial data. Diabetologia. 2004;47(6):969-975. discussion 976–967. [pmid: 15164169].
Chiasson JL, Rabasa-Lhoret R. Prevention of type 2 diabetes: insulin resistance and beta-cell function. Diabetes. 2004;53(Suppl 3):S34-38. [pmid: 15561919].
Chittleborough CR, Baldock KL, Taylor AW, et al. Health status assessed by the SF-36 along the diabetes continuum in an Australian population. Qual Life Res. 2006;15(4):687-694. [pmid: 16688501].
Colagiuri RK, Chen XM, Thomas M. Individual patient education for people with type 2 diabetes mellitus. Cochrane Database of Syst Rev. 2006(3).
Colhoun H. After FIELD: should fibrates be used to prevent cardiovascular disease in diabetes?. Lancet. 2005;366(9500):1829-1831. [pmid: 16310536].
Colhoun HM, Betteridge DJ, Durrington PN. Atorvastatin delays first MI for patients with diabetes. J Fam Pract. 2004;53(12):956.
Cook D, Giacomini M. The trials and tribulations of lcinical practice guidelines. JAMA. 1999;281:1950-1951. [pmid: 10349901].
Corsetti JP, Zareba W, Moss AJ, et al. Serum glucose and triglyceride determine high-risk subgroups in non-diabetic postinfarction patients. Atherosclerosis. 2005;183(2):293-300. [pmid: 15925371].
Coyle D, Lee KM, O'Brien BJ. The role of models within economic analysis: focus on type 2 diabetes mellitus. Pharmacoeconomics. 2002;20(Suppl 1):11-19.
Coyle D, Palmer AJ, Tam R. Economic evaluation of pioglitazone hydrochloride in the management of type 2 diabetes mellitus in Canada. Pharmacoeconomics. 2002;20(Suppl 1):31-42.
Coyne T, Ibiebele TI, Baade PD, et al. Diabetes mellitus and serum carotenoids: findings of a population-based study in Queensland, Australia. Am J Clin Nutr. 2005;82(3):685-693. [pmid: 16155284].
Crespin SR. What does the future hold for diabetic dyslipidaemia?. Acta Diabetologica. 2001;38(Suppl 1):S21-26. [pmid: 11829450].
Cruickshank JM. Renoprotection with antihypertensive agents. Lancet. 2002;359(9318):1693. author reply 1693–1694.
Curran MP, Scott LJ. Orlistat: a review of its use in the management of patients with obesity. Drugs. 2004;64(24):2845-2864. [pmid: 15563254].
Czoski-Murray C, Warren E, Chilcott J, et al. Clinical effectiveness and cost-effectiveness of pioglitazone and rosiglitazone in the treatment of type 2 diabetes: a systematic review and economic evaluation. Health Technol Assess. 2004;8(13):iii.
Dagenais GR, Pogue J, Fox K, et al. Angiotensin-converting-enzyme inhibitors in stable vascular disease without left ventricular systolic dysfunction or heart failure: a combined analysis of three trials. Lancet. 2006;368(9535):581-589. [pmid: 16905022].
Dahlof B, Devereux R, de Faire U, et al. The Losartan Intervention For Endpoint reduction (LIFE) in Hypertension study: rationale, design, and methods. The LIFE Study Group. American J Hypertens. 1997;10(7 Pt 1):705-713.
Dailey GE 3rd, Mohideen P, Fiedorek FT. Lipid effects of glyburide/metformin tablets in patients with type 2 diabetes mellitus with poor glycemic control and dyslipidemia in an open-label extension study. Clin Ther. 2002;24(9):1426-1438. [pmid: 12380634].
Dalla Vestra M, Pozza G, Mosca A, et al. Effect of lercanidipine compared with ramipril on albumin excretion rate in hypertensive Type 2 diabetic patients with microalbuminuria: DIAL study (diabete, ipertensione, albuminuria, lercanidipina). Diabetes Nutr Metab. 2004;17(5):259-266. [pmid: 16295047].
Daly ME, Paisey R, Paisey R, et al. Short-term effects of severe dietary carbohydrate-restriction advice in Type 2 diabetes—a randomized controlled trial. Diabet Med. 2006;23(1):15-20. [pmid: 16409560].
Davidson MB, Schriger DL, Peters AL, et al. Relationship between fasting plasma glucose and glycosylated hemoglobin: potential for false-positive diagnoses of type 2 diabetes using new diagnostic criteria. JAMA. 1999;281(13):1203-1210. [pmid: 10199430].
Davidson MR. Establishing prevention, education and community awareness through a comprehensive diabetes, hypertension and hypercholesterolaemia screening programme: The Smith Island, Maryland, USA experience. Int J Nurs Pract. 2004;10(5):242-246. [pmid: 15461694].
Davies M, Storms F, Shutler S, et al. Improvement of glycemic control in subjects with poorly controlled type 2 diabetes: comparison of two treatment algorithms using insulin glargine. Diabetes Care. 2005;28(6):1282-1288. [pmid: 15920040].
Davis BR, Cutler JA, Furberg CD, et al. Relationship of antihypertensive treatment regimens and change in blood pressure to risk for heart failure in hypertensive patients randomly assigned to doxazosin or chlorthalidone: further analyses from the Antihypertensive and Lipid-Lowering treatment to prevent Heart Attack Trial. 2002 Sep 3;137(5 Part 1):I38; PMID: 12204046]. Ann Intern Med. 2002;137(5 Part 1):313-320. [pmid: 12204014].
Davis BR, Cutler JA, Gordon DJ, et al. Rationale and design for the Antihypertensive and Lipid Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). ALLHAT Research Group. Am J Hypertens. 1996;9(4 Pt 1):342-360. [pmid: 8722437].
Davis TM, Cull CA, Holman RR, et al. Relationship between ethnicity and glycemic control, lipid profiles, and blood pressure during the first 9 years of type 2 diabetes: U.K. Prospective Diabetes Study (UKPDS 55). Diabetes Care. 2001;24(7):1167-1174. [pmid: 11423497].
De Jager J, Kooy A, Lehert P, et al. Effects of short-term treatment with metformin on markers of endothelial function and inflammatory activity in type 2 diabetes mellitus: a randomized, placebo-controlled trial. J Intern Med. 2005;257(1):100-109. [pmid: 15606381].
de Vegt F, Dekker JM, Ruhe HG, et al. Hyperglycaemia is associated with all-cause and cardiovascular mortality in the Hoorn population: the Hoorn Study. Diabetologia. 1999;42(8):926-931. [pmid: 10491751].
de Vegt F, Dekker JM, Stehouwer CD, et al. Similar 9-year mortality risks and reproducibility for the World Health Organization and American Diabetes Association glucose tolerance categories: the Hoorn Study. Diabetes Care. 2000;23(1):40-44. [pmid: 10857966].
DECODA study group. Age- and sex-specific prevalence of diabetes and impaired glucose regulation in 11 Asian cohorts. Diabetes Care. 2003;26(6):1770–80(6):1770–1780.
DECODE Study Group. Age- and sex-specific prevalences of diabetes and impaired glucose regulation in 13 European cohorts. Diabetes Care. 2003;26(1):61-69. [pmid: 12502659].
DECODE Study Group. Will new diagnostic criteria for diabetes mellitus change phenotype of patients with diabetes? Reanalysis of European epidemiological data. Br Med J. 1998;317(7155):371-375. [pmid: 9694750]. [pmcid: 28629].
DECODE Study Group. Is the current definition for diabetes relevant to mortality risk from all causes and cardiovascular and noncardiovascular diseases?. Diabetes Care. 2003;26(3):688-696. [pmid: 12610023].
DECODE Study Group tEDEG. Glucose tolerance and cardiovascular mortality: comparison of fasting and 2-hour diagnostic criteria. Arch Intern Med. 2001;161(3):397-405. [pmid: 11176766].
Deedwania PC, Fonseca VA. Diabetes, prediabetes, and cardiovascular risk: shifting the paradigm. Am J Med. 2005;118(9):939-947. [pmid: 16164876].
Delorme S, Chiasson JL. Acarbose in the prevention of cardiovascular disease in subjects with impaired glucose tolerance and type 2 diabetes mellitus. Curr Opin Pharmacol. 2005;5(2):184-189. [pmid: 15780829].
Dentali F, Douketis JD, Lim W, et al. Combined aspirin-oral anticoagulant therapy compared with oral anticoagulant therapy alone among patients at risk for cardiovascular disease: a meta-analysis of randomized trials. Arch Intern Med. 2007;167(2):117-124. [pmid: 17242311].
Derosa G, Cicero AF, Dangelo A, et al. Thiazolidinedione effects on blood pressure in diabetic patients with metabolic syndrome treated with glimepiride. Hypertens Res Clin Exp. 2005;28(11):917-924.
Derosa G, Cicero AF, Murdolo G, et al. Comparison of metabolic effects of orlistat and sibutramine treatment in Type 2 diabetic obese patients. Diabetes Nutr Metab. 2004;17(4):222-229. [pmid: 15575343].
Derosa G, Franzetti I, Gadaleta G, et al. Metabolic variations with oral antidiabetic drugs in patients with Type 2 diabetes: comparison between glimepiride and metformin. Diabetes Nutr Metab. 2004;17(3):143-150. [pmid: 15334791].
Derosa G, Gaddi AV, Piccinni MN, et al. Differential effect of glimepiride and rosiglitazone on metabolic control of type 2 diabetic patients treated with metformin: a randomized, double-blind, clinical trial. Diabetes Obes Metab. 2006;8(2):197-205. [pmid: 16448524].
DeWitt DE, Hirsch IB. Outpatient insulin therapy in type 1 and type 2 diabetes mellitus: scientific review. JAMA. 2003;289(17):2254-2264. [pmid: 12734137].
Diabetes Australia. Part 3. Evidence based guideline for case detection and diagnosis of type 2 diabetes. National Evidence Based Guidelinehttp://www.diabetesaustralia.com.au/education_info/nebg.html. Accessed September, 2007.
Diabetes Prevention Program Research Group. The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22(4):623-634. [pmid: 10189543]. [pmcid: 1351026].
Diabetes Prevention Program Research Group. Association of demographic, anthropometric and metabolic factors with baseline cardiovascular disease (CVD) risk factors in the Diabetes Prevention Program (Abstract). Diabetes. 2003;52(Suppl 1):A168.
Diabetes UK. Position statement 2006. Early identification of people with type 2 diabetes. www.diabetes.org.uk. Accessed September, 2007.
Diamantopoulos EJ, Andreadis EA, Tsourous GI, et al. Metabolic syndrome and prediabetes identify overlapping but not identical populations. Exp Clin Endocrinol Diabetes. 2006;114(7):377-383. [pmid: 16915541].
Diamantopoulos EJ, Andreadis EA, Tsourous GI, et al. Early vascular lesions in subjects with metabolic syndrome and prediabetes. Int Angiol. 2006;25(2):179-183. [pmid: 16763536].
Didangelos TP, Arsos GA, Karamitsos DT, et al. Effect of quinapril or losartan alone and in combination on left ventricular systolic and diastolic functions in asymptomatic patients with diabetic autonomic neuropathy. J Diabetes Complications. 2006;20(1):1-7. [pmid: 16389160].
Donnan PT, Donnelly L, New JP, et al. Derivation and validation of a prediction score for major coronary heart disease events in a U.K. type 2 diabetic population. Diabetes Care. 2006;29(6):1231-1236. [pmid: 16732001].
Doust J, Mannes P, Bastian H, et al. Interventions for improving understanding and minimising the psychological impact of screening. Cochrane Database of Syst Rev. 2006(3).
Drivsholm T, Olivarius Nde F. Routine diagnosis of Type 2 diabetes mellitus in general practice and hospitals: how do patients differ?. Diabet Med. 2005;22(3):336-339. [pmid: 15717884].
Earnshaw SR, Richter A, Sorensen SW, et al. Optimal allocation of resources across four interventions for type 2 diabetes. Med Decis Making. 2002;22(5 Suppl):S80-91. [pmid: 12369234].
Ebbesson SO, Ebbesson LO, Swenson M, et al. A successful diabetes prevention study in Eskimos: the Alaska Siberia project. Int J Circumpolar Health. 2005;64(4):409-424. [pmid: 16277124].
Eddy D. Clinical Decision Making: from theory to practice. A collection of essays from JAMA.: Boston: Jones and Barlett Publishers; 1995.
Eddy D. Bringing health economic modeling to the 21st century. Value Health. 2006;9(3):168-178. [pmid: 16689710].
Eddy DM. Accuracy versus transparency in pharmacoeconomic modelling: finding the right balance. Pharmacoeconomics. 2006;24(9):837-844. [pmid: 16942119].
Egan B, Gleim G, Panish J. Use of losartan in diabetic patients in the primary care setting: review of the results in LIFE and RENAAL. Curr Med Res Opin. 2004;20(12):1909-1917. [pmid: 15701209].
Eidelman A, Samueloff A. The pathophysiology of the fetus of the diabetic mother. Semin Perinatol. 2002;26(3):232-236. [pmid: 12099314].
Elliott WJ. Differential effects of antihypertensive drugs on new-onset diabetes?. Current Hypertension Reports. 2005;7(4):249-256. [pmid: 16061042].
Engelgau M, Narayan K, Herman W. Screening for type 2 diabetes. Diabetes Care. 2000;23(10):1563-1580. [pmid: 11023153].
Engelgau MM, Narayan KM. Finding undiagnosed type 2 diabetes: is it worth the effort?. Effective Clinical Practice. 2001;4(6):281-283. [pmid: 11769302].
Erenus M, Gurler AD, Elter K. Should we consider performing oral glucose tolerance tests more frequently in postmenopausal women for optimal screening of impaired glucose tolerance?. Menopause. 2002;9(4):296-301. [pmid: 12082367].
Eschwège E, Charles MA, Simon D, et al. Reproducibility of the Diagnosis of Diabetes Over a 30-Month Follow-Up. Diabetes Care. 2001;24(11):1941-1944. [pmid: 11679461].
Estacio RO, Jeffers BW, Hiatt WR, et al. The effect of nisoldipine as compared with enalapril on cardiovascular outcomes in patients with non-insulin-dependent diabetes and hypertension. N Engl J Med. 1998;338(10):645-652. [pmid: 9486993].
Expert Committee on the Diagnosis and Classification of Diabetes M. Report of the expert committee on the diagnosis and classification of diabetes mellitus. Diabetes Care. 2003;26(Suppl 1):S5-20. [pmid: 12502614].
Ferrannini E, Nannipieri M, Williams K, et al. Mode of onset type 2 diabetes from normal or impaired glucose tolerance. Diabetes. 2004;53:160-165. [pmid: 14693710].
Forouhi NG, Balkau B, Borch-Johnsen K, et al. The threshold for diagnosing impaired fasting glucose: a position statement by the European Diabetes Epidemiology Group. Diabetologia. 2006;49(5):822-827. [pmid: 16525842].
Fournier A, Presne C, Makdassi R, et al. Renoprotection with antihypertensive agents. Lancet. 2002;359(9318):1694-1695. [pmid: 12020553].
Franse LV, Di Bari M, Shorr RI, et al. Type 2 diabetes in older well-functioning people: who is undiagnosed? Data from the Health, Aging, and Body Composition study. Diabetes Care. 2001;24(12):2065-2070. [pmid: 11723084].
Fujimoto WY. Background and recruitment data for the U.S. Diabetes Prevention Program. Diabetes care. Vol. 2000;23(2).
Gaede P, Pedersen O. Intensive integrated therapy of type 2 diabetes: implications for long-term prognosis. Diabetes. 2004;53(Suppl 3):S39-47. [pmid: 15561920].
Garber AJ, Larsen J, Schneider SH, et al. Simultaneous glyburide/metformin therapy is superior to component monotherapy as an initial pharmacological treatment for type 2 diabetes. Diabetes Obes Metab. 2002;4(3):201-208. [pmid: 12047399].
Genuth S, Alberti KG, Bennett P, et al. Follow-up report on the diagnosis of diabetes mellitus. Diabetes Care. 2003;26(11):3160-3167. [pmid: 14578255].
George PM, Valabhji J, Dawood M, et al. Screening for Type 2 diabetes in the accident and emergency department. Diabet Med. 2005;22(12):1766-1769. [pmid: 16401327].
Gerstein HC. Is glucose a continuous risk factor for cardiovascular mortality?. Diabetes Care. 1999;22(5):659-660. [pmid: 10332661].
Gerstein HC, Rosenstock J. Insulin therapy in people who have dysglycemia and type 2 diabetes mellitus: can it offer both cardiovascular protection and beta-cell preservation?. Endocrinol Metab Clin North Am. 2005;34(1):137-154. [pmid: 15752926].
Gillespie EL, White CM, Kardas M, et al. The impact of ACE inhibitors or angiotensin II type 1 receptor blockers on the development of new-onset type 2 diabetes. Diabetes Care. 2005;28(9):2261-2266. [pmid: 16123505].
Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. 2005;28(1):33-39. [pmid: 15616230].
Glasgow RE, Nutting PA, King DK, et al. A practical randomized trial to improve diabetes care. J Gen Intern Med. 2004;19(12):1167-1174. [pmid: 15610326]. [pmcid: 1492587].
Glumer C, Borch-Johnsen K, Colagiuri S. Can a screening programme for diabetes be applied to another population?. Diabet Med. 2005;22(9):1234-1238. [pmid: 16108854].
Glumer C, Jorgensen T, Borch-Johnsen K. It is possible to reduce the number of OGTT by 60% using a stepwise screening strategy combining HbA1c and fasting plasma glucose compared to WHO's screening strategy. Diabetologia. 2001;44(Supp 1):A7, 20.
Goderis G, Boland B. Cardiovascular prevention in type 2 diabetic patients: review of efficacious treatments. Acta Clin Belg. 2004;59(6):329-339. [pmid: 15819377].
Goldberg RB, Kendall DM, Deeg MA, et al. A comparison of lipid and glycemic effects of pioglitazone and rosiglitazone in patients with type 2 diabetes and dyslipidemia. Diabetes Care. 2005;28(7):1547-1554. [pmid: 15983299].
Gosavi A, Flaker G, Gardner D. Lipid management reduces cardiovascular complications in individuals with diabetes and prediabetes. Prev Cardiol. 2006;9(2):102-107. quiz 108–109. [pmid: 16603829].
Govindarajan R, Ratnasinghe L, Simmons DL, et al. Thiazolidinediones and the risk of lung, prostate, and colon cancer in patients with diabetes. J Clin Oncol. 2007;25(12):1476-1481. [pmid: 17442990].
Gozzoli V, Palmer AJ, Brandt A, et al. Economic and clinical impact of alternative disease management strategies for secondary prevention in type 2 diabetes in the Swiss setting. Swiss Med Wkly. 2001;131(2122):303-310. [pmid: 11584692].
Griffin S, Kinmonth AL. Systems for routine surveillance for people with diabetes mellitus Cochrane Database of Syst Rev. 2006(3).
Grundy SM, Cleeman JI, Daniels SR, et al. Diagnosis and management of the metabolic syndrome: an American Heart Association/National Heart, Lung, and Blood Institute Scientific Statement. Circulation. 2005;112(17):2735-2752. [pmid: 16157765].
Guizar JM, Kornhauser C, Malacara JM, et al. Renal functional reserve in patients with recently diagnosed Type 2 diabetes mellitus with and without microalbuminuria. Nephron. 2001;87(3):223-230. [pmid: 11287757].
Guzder RN, Gatling W, Mullee MA, et al. Impact of metabolic syndrome criteria on cardiovascular disease risk in people with newly diagnosed type 2 diabetes. Diabetologia. 2006;49(1):49-55. [pmid: 16341841].
Haffner SJ, Cassells H. Hyperglycemia as a cardiovascular risk factor. Am J Med. 2003;115(Suppl 8A):6S-11S. [pmid: 14678859].
Haffner SM. Can reducing peaks prevent type 2 diabetes: implication from recent diabetes prevention trials. Int J Clin Pract. 2002;Supplement.(129):33–39.
Haffner SM, Lehto S, Ronnemaa T, et al. Mortality from coronary heart disease in subjects with type 2 diabetes and in nondiabetic subjects with and without prior myocardial infarction. N Engl J Med. 1998;339(4):229-234. [pmid: 9673301].
Hagstrom B, Mattsson B. Screening for diabetes in general practice. Opportunistic screening for diabetes in general practice is better than nothing. Bmj. 2002;324(7334):425-426.
Haller H, Viberti GC, Mimran A, et al. Preventing microalbuminuria in patients with diabetes: rationale and design of the Randomised Olmesartan and Diabetes Microalbuminuria Prevention (ROADMAP) study. J Hypertens. 2006;24(2):403-408. [pmid: 16508590].
Halpern A, Mancini MC. Diabesity: are weight loss medications effective?. Treat Endocrinol. 2005;4(2):65-74. [pmid: 15783244].
Hamilton RA, Kane MP, Demers J. Angiotensin-converting enzyme inhibitors and type 2 diabetic nephropathy: a meta-analysis. Pharmacotherapy. 2003;23(7):909-915. [pmid: 12885103].
Hanefeld M, Temelkova-Kurktschiev T. Control of post-prandial hyperglycemia—an essential part of good diabetes treatment and prevention of cardiovascular complications. Nutr Metab Cardiovasc Dis. 2002;12(2):98-107. [pmid: 12189909].
Harris MI, Flegal KM, Cowie CC, et al. Prevalence of diabetes, impaired fasting glucose, and impaired glucose tolerance in U.S. adults. The Third National Health and Nutrition Examination Survey, 1988-1994. Diabetes Care. 1998;21(4):518-524. [pmid: 9571335].
Hauptman J, Lucas C, Boldrin MN, et al. Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9(2):160-167. [pmid: 10693734].
Heise T, Sawicki PT. Does insulin preserve beta-cell function in type 2 diabetes?. J Intern Med. 2002;251(4):283-285. [pmid: 11952878].
Hennekens CH, Sechenova O, Hollar D, et al. Dose of aspirin in the treatment and prevention of cardiovascular disease: current and future directions. J Cardiovasc Pharmacol Ther. 2006;11(3):170-176. [pmid: 17056829].
Herman W, Wareham N. The diagnosis and classification of diabetes mellitus in nonpregnant adults. Prim Care. 1999;26(4).
Hernandez-Diaz S, Garcia Rodriguez LA. Cardioprotective aspirin users and their excess risk of upper gastrointestinal complications. BMC Med. 2006;4:22. [pmid: 16987411]. [pmcid: 1590044].
Higashi K, Shige H, Ito T, et al. Effect of a low-fat diet enriched with oleic acid on postprandial lipemia in patients with type 2 diabetes mellitus. Lipids. 2001;36(1):1-6. [pmid: 11214722].
Higson N. Screening for diabetes in general practice. Population screening for diabetes is cost effective. Bmj. 2002;324(7334):426.
Hilgers KF, Mann JF. Renoprotection with antihypertensive agents. Lancet. 2002;359(9318):1693. author reply 1693–1694.
Hiralal R, Koo KK, Gerstein HC. Does pioglitazone prevent macrovascular events in patients with type 2 diabetes?. CMAJ. 2006;174(8):1090-1091. [pmid: 16606956]. [pmcid: 1421458].
Holton DR, Colberg SR, Nunnold T, et al. The effect of an aerobic exercise training program on quality of life in type 2 diabetes. Diabetes Educ. 2003;29(5):837-846. [pmid: 14603872].
Home PD, Pocock SJ, Beck-Nielsen H, et al. Rosiglitazone Evaluated for Cardiac Outcomes and Regulation of Glycaemia in Diabetes (RECORD): study design and protocol. Diabetologia. 2005;48(9):1726-1735. [pmid: 16025252].
Hovens MMC, Van de Laar FA, Cannegieter SC, et al. Acetylsalicylic acid (Aspirin) for primary prevention of cardiovascular disease in type 2 diabetes mellitus Cochrane Database of Syst Rev. 2006(3).
Hurni CA, Perret S, Monbaron D, et al. Coronary artery disease screening in diabetic patients: how good is guideline adherence?. Swiss Med Wkly. 2007;137(1314):199-204. [pmid: 17525872].
Icks A, Haastert B, Gandjour A, et al. Costeffectiveness analysis of different screening procedures for type 2 diabetes: the KORA Survey 2000. Diabetes Care. 2004;27(9):2120-2128. [pmid: 15333472].
Iltz JL, Baker DE, Setter SM, et al. Exenatide: an incretin mimetic for the treatment of type 2 diabetes mellitus. Clin Ther. 2006;28(5):652-665. [pmid: 16861088].
Jamal u D, Qureshi MB, Khan AJ, et al. Prevalence of diabetic retinopathy among individuals screened positive for diabetes in five community-based eye camps in northern Karachi, Pakistan. J Ayub Med Coll Abbottabad. 2006;18(3):40-43.
Jandeleit-Dahm KA, Tikellis C, Reid CM, et al. Why blockade of the renin-angiotensin system reduces the incidence of new-onset diabetes. J Hypertens. 2005;23(3):463-473. [pmid: 15716683].
Jong P, Yusuf S, Rousseau MF, et al. Effect of enalapril on 12-year survival and life expectancy in patients with left ventricular systolic dysfunction: a follow-up study. Lancet. 2003;361:1843-1848. [pmid: 12788569].
Kaiser T, Sawicki PT, Stop I. Acarbose for prevention of diabetes, hypertension and cardiovascular events? A critical analysis of the STOP-NIDDM data. Diabetologia. 2004;47(3):575-580. [pmid: 14727025].
Kalus JS, White CM. Amlodipine versus Angiotensin-receptor blockers for nonhypertension indications. Ann Pharmacother. 2002;36(11):1759-1766. [pmid: 12398574].
Kazi D. Rosiglitazone and implications for pharmacovigilance. Bmj. 2007;334(7606):1233-1234. [pmid: 17569897]. [pmcid: 1892466].
Keating GM, Jarvis B. Orlistat: in the prevention and treatment of type 2 diabetes mellitus. Drugs. 2001;61(14):2107-2119. discussion 2120–2101. [pmid: 11735640].
Kenealy T, Braatvedt G, Scragg R. Screening for type 2 diabetes in non-pregnant adults in New Zealand: practice recommendations. N Z Med J. 2002;115(1152):194-196. [pmid: 12044005].
Khaw KT, Wareham N, Bingham S, et al. Association of hemoglobin A1c with cardiovascular disease and mortality in adults: the European prospective investigation into cancer in Norfolk. Ann Intern Med. 2004;141(6):413-420. [pmid: 15381514].
Khouri AS, Szirth BC, Bhagat N, et al. Screening and diabetes mellitus. Ophthalmology. 2007;114(2):398-399. author reply 399–400. [pmid: 17270698].
Kimchi NA, Broide E, Scapa E, et al. Antiplatelet therapy and the risk of bleeding induced by gastrointestinal endoscopic procedures. A systematic review of the literature and recommendations. Digestion. 2007;75(1):36-45. [pmid: 17429206].
Kirkman MS, McCarren M, Shah J, et al. The association between metabolic control and prevalent macrovascular disease in Type 2 diabetes: the VA Cooperative Study in diabetes. J Diabetes Complications. 2006;20(2):75-80. [pmid: 16504835].
Kitabchi AE, Temprosa M, Knowler WC, et al. Role of insulin secretion and sensitivity in the evolution of type 2 diabetes in the diabetes prevention program: effects of lifestyle intervention and metformin. Diabetes. 2005;54(8):2404-2414. [pmid: 16046308]. [pmcid: 1360738].
Kleppinger EL, Helms K. The role of vildagliptin in the management of type 2 diabetes mellitus. Ann Pharmacother. 2007;41(5):824-832. [pmid: 17456545].
Kleppinger EL, Vivian EM. Pramlintide for the treatment of diabetes mellitus. Ann Pharmacother. 2003;37(78):1082-1089. [pmid: 12841822].
Koro CE, Bowlin SJ, Weiss SR. Antidiabetic therapy and the risk of heart failure in type 2 diabetic patients: an independent effect or confounding by indication. Pharmacoepidemiol Drug Saf. 2005;14(10):697-703. [pmid: 15654719].
Krentz AJ. Comparative safety of newer oral antidiabetic drugs. Expert Opin Drug Saf. 2006;5(6):827-834. [pmid: 17044809].
Kvapil M, Swatko A, Hilberg C, et al. Biphasic insulin aspart 30 plus metformin: an effective combination in type 2 diabetes. Diabetes Obes Metab. 2006;8(1):39-48. [pmid: 16367881].
Lawrence J, Robinson A. Screening for diabetes in general practice. Prev Cardiol. 2003;6(2):78-84. [pmid: 12732793].
Lawrence JM, Bennett P, Young A, et al. Screening for diabetes in general practice: cross sectional population study. Bmj. 2001;323(7312):548-551. [pmid: 11546702]. [pmcid: 48161].
Lebovitz HE. Insulin resistance: definition and consequences. Exp Clin Endocrinol Diabetes. 2001;109(Suppl 2):S135-148. [pmid: 11460565].
Lebovitz HE, Kreider M, Freed MI. Evaluation of liver function in type 2 diabetic patients during clinical trials: evidence that rosiglitazone does not cause hepatic dysfunction. Diabetes Care. 2002;25(5):815-821. [pmid: 11978674].
Lecomte P, Vol S, Caces E, et al. Impaired fasting glycaemia and undiagnosed diabetes: prevalence, cardiovascular and behavioural risk factors. Diabetes Metab. 2002;28(4 Pt 1):311-320. [pmid: 12442069].
Lecube A, Hernandez C, Genesca J, et al. High prevalence of glucose abnormalities in patients with hepatitis C virus infection: a multivariate analysis considering the liver injury. Diabetes Care. 2004;27(5):1171-1175. [pmid: 15111540].
Leiter LA, Ceriello A, Davidson JA, et al. Postprandial glucose regulation: new data and new implications. Clin Ther. 2005;27(Suppl B):S42-56. [pmid: 16519037].
Levenson D. Diabetes screening strategy holds potential for early treatment, savings. Rep Med Guidel Outcomes Res. 2002;13(3):9-10.
Levien TL, Baker DE, Campbell RK, et al. Nateglinide therapy for type 2 diabetes mellitus. Ann Pharmacother. 2001;35(11):1426-1434. [pmid: 11724096].
Liao D, Asberry PJ, Shofer JB, et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2002;25(9):1504-1510. [pmid: 12196418].
Liebl A, Neiss A, Spannheimer A, et al. Complications, co-morbidity, and blood glucose control in type 2 diabetes mellitus patients in Germany—results from the CODE-2 study. Exp Clin Endocrinol Diabetes. 2002;110(1):10-16. [pmid: 11835119].
Linzer M, Pierce C, Lincoln E, et al. Preliminary validation of a patient-based self-assessment measure of severity of illness in type 2 diabetes: results from the pilot phase of the Veterans Health Study. J Ambul Care Manage. 2005;28(2):167-176. [pmid: 15923949].
Liu DP, Molyneaux L, Chua E, et al. Retinopathy in a Chinese population with type 2 diabetes: factors affecting the presence of this complication at diagnosis of diabetes. Diabetes Res Clin Pract. 2002;56(2):125-131. [pmid: 11891020].
Loimaala A, Groundstroem K, Majahalme S, et al. Impaired myocardial function in newly onset type 2 diabetes associates with arterial stiffness. Eur J Echocardiogr. 2006;7(5):341-347. [pmid: 16154806].
Lopez-Candales A. Metabolic syndrome X: a comprehensive review of the pathophysiology and recommended therapy. J Med. 2001;32(56):283-300. [pmid: 11958275].
Lovell HG. Angiotensin converting enzyme inhibitors in normotensive diabetic patients with microalbuminuria Cochrane Database of Syst Rev. 2006(3).
Lucas KH, Kaplan-Machlis B. Orlistat—a novel weight loss therapy. Ann Pharmacother. 2001;35(3):314-328. [pmid: 11261530].
Luders S, Hammersen F, Kulschewski A, et al. Diagnosis of impaired glucose tolerance in hypertensive patients in daily clinical practice. Int J Clin Pract. 2005;59(6):632-638. [pmid: 15924589].
Ludvigsson J, Gustafsson-Stolt U, Liss PE, et al. Mothers of children in ABIS, a population-based screening for prediabetes, experience few ethical conflicts and have a positive attitude. Ann N Y Acad Sci. 2002;958:376-381. [pmid: 12021144].
Macfarlane DP, Fisher M. Thiazolidinediones in patients with diabetes mellitus and heart failure : implications of emerging data. Am J Cardiovasc Drugs. 2006;6(5):297-304. [pmid: 17083264].
Macisaac RJ, Jerums G. Albuminuric and non-albuminuric pathways to renal impairment in diabetes. Minerva Endocrinol. 2005;30(3):161-177. [pmid: 16208306].
Mancia G, Grassi G, Zanchetti A. New-onset diabetes and antihypertensive drugs. J Hypertens. 2006;24(1):3-10. [pmid: 16331092].
Manning PJ, Mann J, Kalter-Leibovici O, et al. Pharmacologic lipid-modifying interventions for preventing cardiovascular complications in people with diabetes mellitus. Cochrane Database of Syst Rev. 2007(1).
Mannucci E, Bardini G, Rotella CM. Effect of lower diagnostic thresholds on estimates of prevalence of impaired fasting glucose (IFG). Diabet Med. 2005;22(3):353-354.
Marceille JR, Goins JA, Soni R, et al. Chronic heart failure-related interventions after starting rosiglitazone in patients receiving insulin. Pharmacotherapy. 2004;24(10):1317-1322. [pmid: 15628829].
Marshall KG. The folly of population screening for type 2 diabetes. CMAJ. 1999;160(11):1592-1593. [pmid: 10374003]. [pmcid: 1230366].
Marteau TM, Kinmonth AL. Screening for cardiovascular risk: public health imperative or matter for individual informed choice?. Bmj. 2002;325(7355):78-80. [pmid: 12114238]. [pmcid: 117128].
McCullough PA. Cardiovascular risk reduction and preservation of renal function in the early nephropathy patient. Adv Chronic Kidney Dis. 2004;11(2):184-191. [pmid: 15216489].
McLaughlin T, Abbasi F, Cheal K, et al. Use of metabolic markers to identify overweight individuals who are insulin resistant. Ann Intern Med. 2003;139(10):802-809. [pmid: 14623617].
McNeely MJ, Boyko EJ. Type 2 diabetes prevalence in Asian Americans: results of a national health survey. Diabetes Care. 2004;27(1):66-69. [pmid: 14693968].
McQueen MJ. Screening for the early detection of disease, the need for evidence. Clin Chim Acta. 2002;315(12):5-15. [pmid: 11728406].
Meigs JB, Larson MG, D'Agostino RB, et al. Coronary artery calcification in type 2 diabetes and insulin resistance: the Framingham Offspring Study. Diabetes Care. 2002;25(8):1313-1319. [pmid: 12145227].
Meigs JB, Nathan DM, D'Agostino RB Sr, et al. Fasting and postchallenge glycemia and cardiovascular disease risk: the Framingham Offspring Study. Diabetes Care. 2002;25(10):1845-1850. [pmid: 12351489].
Melchionda N, Forlani G, Marchesini G, et al. WHO and ADA criteria for the diagnosis of diabetes mellitus in relation to body mass index. Insulin sensitivity and secretion in resulting subcategories of glucose tolerance. Int J Obes Relat Metab Disord. 2002;26(1):90-96. [pmid: 11791152].
Meriden T. Progress with thiazolidinediones in the management of type 2 diabetes mellitus. Clin Ther. 2004;26(2):177-190. [pmid: 15038941].
Miki E, Lu M, Lee ET, et al. The incidence of visual impairment and its determinants in the WHO Multinational Study of Vascular Disease in Diabetes. Diabetologia. 2001;44(Suppl 2):S31-36. [pmid: 11587048].
Mokdad AH, Bowman BA, Ford ES, et al. The Continuing Epidemics of Obesity and Diabetes in the United States. JAMA. 2001;286(10):1195-1200. [pmid: 11559264].
Mshunqane N, Cohen D, Kalk JK. Effects of an exercise programme on non-insulin dependant diabetes mellitus. S African J Physiotherapy. 2004;60(4):26-30.
Mukhopadhyay B, Forouhi NG, Fisher BM, et al. A comparison of glycaemic and metabolic control over time among South Asian and European patients with Type 2 diabetes: results from follow-up in a routine diabetes clinic. Diabet Med. 2006;23(1):94-98. [pmid: 16409573].
Nakagami T, Qiao Q, Tuomilehto J, et al. The fasting plasma glucose cut-point predicting a diabetic 2-h OGTT glucose level depends on the phenotype. Diabetes Res Clin Pract. 2002;55(1):35-43. [pmid: 11755477].
Narayan KM, Boyle JP, Thompson TJ, et al. Lifetime risk for diabetes mellitus in the United States. JAMA. 2003;290(14):1884-1890. [pmid: 14532317].
Nathan DM, Herman WH. Screening for diabetes: can we afford not to screen?. Ann Intern Med. 2004;140(9):756-758. [pmid: 15126261].
National Intervention Cooperative Study in Elderly Hypertensives Study Group. Randomized double-blind comparison of a calcium antagonist and a diuretic in elderly hypertensives. Hypertension. 1999;34(5):1129-1133. [pmid: 10567194].
Nazimek-Siewniak B, Moczulski D, Grzeszczak W. Risk of macrovascular and microvascular complications in Type 2 diabetes: results of longitudinal study design. J Diabetes Complications. 2002;16(4):271-276. [pmid: 12126785].
Neal B, MacMahon S, Chapman N. Effects of ACE inhibitors, calcium antagonists, and other blood-pressure-lowering drugs: results of prospectively designed overviews of randomised trials. Lancet. 2000;356:1955. [pmid: 11130523].
Nelson KM, Reiber G, Boyko EJ, et al. Diet and exercise among adults with type 2 diabetes: findings from the third national health and nutrition examination survey (NHANES III). Diabetes Care. 2002;25(10):1722-1728. [pmid: 12351468].
Nesto RW. Correlation between cardiovascular disease and diabetes mellitus: current concepts. Am J Med. 2004;116(Suppl 5A):11S-22S.
Nesto RW. Beyond low-density lipoprotein: addressing the atherogenic lipid triad in type 2 diabetes mellitus and the metabolic syndrome. Am J Cardiovasc Drugs. 2005;5(6):379-387. [pmid: 16259526].
Neumann P. Why don't Americans use cost-effectiveness analysis?. Am J Manag Care. 2004;10:208-212.
Newman C, Tsai J, Szarek M, et al. Comparative safety of atorvastatin 80 mg versus 10 mg derived from analysis of 49 completed trials in 14,236 patients. Am J Cardiol. 2006;97(1):61-67. [pmid: 16377285].
National Institute for Clinical Excellence (NICE). Technology Appraisal No. 63: Glitazones for the Treatment of Type 2 Diabetes. London; 2003.
Nichols GA, Hillier TA, Erbey JR, et al. Congestive heart failure in type 2 diabetes: prevalence, incidence, and risk factors. Diabetes Care. 2001;24(9):1614-1619. [pmid: 11522708].
Nordone DS, Westerberg D, Wolf D, et al. Clinical inquiries. Does screening for diabetes in at-risk patients improve long-term outcomes?. J Fam Pract. 2004;53(5):401-403. [pmid: 15125826].
Norris SL, Nichols PJ, Caspersen CJ, et al. The effectiveness of disease and case management for people with diabetes. A systematic review. Am J Prev Med. 2002;22(4 Suppl):15-38.
Nowak SN, Jaber LA. Aspirin dose for prevention of cardiovascular disease in diabetics. Ann Pharmacother. 2003;37(1):116-121. [pmid: 12503945].
Ortegon MM, Redekop WK, Niessen LW. Cost-effectiveness of prevention and treatment of the diabetic foot: a Markov analysis. Diabetes Care. 2004;27(4):901-907. [pmid: 15047646].
Otero ML, Claros NM. Study Investigators Group. Manidipine versus enalapril monotherapy in patients with hypertension and type 2 diabetes mellitus: a multicenter, randomized, double-blind, 24-week study. Clin Ther. 2005;27(2):166-173. [pmid: 15811479].
Padwal R, Laupacis A. Antihypertensive therapy and incidence of type 2 diabetes: a systematic review. Diabetes Care. 2004;27(1):247-255. [pmid: 14693997].
Pahor M, Psaty BM, Alderman MH, et al. Health outcomes associated with calcium antagonists compared with first-line antihypertensive therapies: a meta-analysis of randomised controlled trials. Lancet. 2000;356:1949-1954. [pmid: 11130522].
Pahor M, Psaty BM, Alderman MH, et al. Therapeutic benefits of ACE inhibitors and other antihypertensive druges in patients with type 2 diabetes. Diabetes Care. 2000;23:888-892. [pmid: 10895836].
Palmer AJ, Annemans L, Roze S, et al. An economic evaluation of irbesartan in the treatment of patients with type 2 diabetes, hypertension and nephropathy: cost-effectiveness of Irbesartan in Diabetic Nephropathy Trial (IDNT) in the Belgian and French settings. Nephrol Dial Transplant. 2003;18(10):2059-2066. [pmid: 13679481].
Parry O, Peel E, Douglas M, et al. Patients in waiting: a qualitative study of type 2 diabetes patients' perceptions of diagnosis. Family Practice. 2004;21(2):131-136. [pmid: 15020378].
Paterson KR. Population screening for diabetes mellitus. Diabet Med. 1993;10(8):777-781. [pmid: 8261763].
Pedersen BK, Saltin B. Evidence for prescribing exercise as therapy in chronic disease. Scand J Med Sci Sports. 2006;16(Suppl 1):3-63. [pmid: 16451303].
Pfeffer MA, Keech A, Sacks FM, et al. Safety and tolerability of pravastatin in long-term clinical trials: prospective Pravastatin Pooling (PPP) Project. Circulation. 2002;105(20):2341-2346. [pmid: 12021218].
Phillips LS, Weintraub WS, Ziemer DC, et al. All pre-diabetes is not the same: metabolic and vascular risks of impaired fasting glucose at 100 versus 110 mg/dl: the Screening for Impaired Glucose Tolerance study 1 (SIGT 1). Diabetes Care. 2006;29(6):1405-1407. [pmid: 16732034].
Pitt B. ACE inhibitors for patients with vascular disease without left ventricular dysfunction—may they rest in PEACE?. N Engl J Med. 2004;351(20):2115-2117. [pmid: 15531768].
Plank J, Siebenhofer A, Berghold A, et al. Systematic review and meta-analysis of short-acting insulin analogues in patients with diabetes mellitus. Arch Intern Med. 2005;165(12):1337-1344. [pmid: 15983281].
Poirier L, Cleroux J, Nadeau A, et al. Effects of nebivolol and atenolol on insulin sensitivity and haemodynamics in hypertensive patients. J Hypertens. 2001;19(8):1429-1435. [pmid: 11518851].
Ponce J, Haynes B, Paynter S, et al. Effect of Lap-Band-induced weight loss on type 2 diabetes mellitus and hypertension. Obes Surg. 2004;14(10):1335-1342. [pmid: 15603648].
Pontiroli AE, Folli F, Paganelli M, et al. Laparoscopic gastric banding prevents type 2 diabetes and arterial hypertension and induces their remission in morbid obesity: a 4-year case-controlled study. Diabetes Care. 2005;28(11):2703-2709. [pmid: 16249543].
Porta M, Trento M, Committee RW. ROMEO: rethink organization to improve education and outcomes. Diabet Med. 2004;21(6):644-645. [pmid: 15154956].
Pradhan AD, Manson JE, Rifai N, et al. C-reactive protein, interleukin 6, and risk of developing type 2 diabetes mellitus. JAMA. 2001;286(3):327-334. [pmid: 11466099].
Punzi HA, Punzi CF. Antihypertensive and Lipid-Lowering Heart Attack Trial Study. Metabolic issues in the Antihypertensive and Lipid-Lowering Heart Attack Trial Study. Curr Hypertens Rep. 2004;6(2):106-110. [pmid: 15010012].
Qiao Q, Nakagami T, Tuomilehto J, et al. Comparison of the fasting and the 2-h glucose criteria for diabetes in different Asian cohorts. Diabetologia. 2000;43(12):1470-1475. [pmid: 11151755].
Qiao Q, Tuomilehto J, Borch-Johnsen K. Post-challenge hyperglycaemia is associated with premature death and macrovascular complications. Diabetologia. 2003;46(Suppl 1):M17-21. [pmid: 12652354].
Raheja BS, Kapur A, Bhoraskar A, et al. DiabCare Asia—India Study: diabetes care in India—current status. J Assoc Physicians India. 2001;49:717-722. [pmid: 11573557].
Rajagopalan R, Iyer S, Perez A. Comparison of pioglitazone with other antidiabetic drugs for associated incidence of liver failure: no evidence of increased risk of liver failure with pioglitazone. Diabetes Obes Metab. 2005;7(2):161-169. [pmid: 15715889].
Rajagopalan R, Rosenson RS, Fernandes AW, et al. Association between congestive heart failure and hospitalization in patients with type 2 diabetes mellitus receiving treatment with insulin or pioglitazone: a retrospective data analysis. Clin Ther. 2004;26(9):1400-1410. [pmid: 15531002].
Ramsdell JW, Braunstein SN, Stephens JM, et al. Economic model of first-line drug strategies to achieve recommended glycaemic control in newly diagnosed type 2 diabetes mellitus. Pharmacoeconomics. 2003;21(11):819-837. [pmid: 12859222].
Rao G. Diagnostic yeild of screening for type 2 diabetes in high-risk patients: a systematic review. J Fam Prac. 1999;48(10):805-810.
Rashid HU, Hassan MN, Ali L. Effects of angiotensin converting enzyme inhibitor on proteinuria and renal function in patients with type 2 diabetes with or without renal failure. Nephrol Dial Transplant. 2003;18(Suppl 4):105.
Rathmann W, Haastert B, Icks A, et al. High prevalence of undiagnosed diabetes mellitus in Southern Germany: target populations for efficient screening. The KORA survey 2000. Diabetologia. 2003;46(2):182-189. [pmid: 12627316].
Ray JA, Boye KS, Yurgin N, et al. Exenatide versus insulin glargine in patients with type 2 diabetes in the UK: a model of long-term clinical and cost outcomes. Curr Med Res Opin. 2007;23(3):609-622. [pmid: 17355742].
Reddy SS. Health outcomes in type 2 diabetes. Int J Clin Pract. 2000;Supplement.(113):46–53.
Reinhard W, Holmer SR, Fischer M, et al. Association of the metabolic syndrome with early coronary disease in families with frequent myocardial infarction. Am J Cardiol. 2006;97(7):964-967. [pmid: 16563895].
Roberts F, Ryan GJ. The safety of metformin in heart failure. Ann Pharmacother. 2007;41(4):642-646. [pmid: 17374622].
Rodriguez CJ, Miyake Y, Grahame-Clarke C, et al. Relation of plasma glucose and endothelial function in a population-based multiethnic sample of subjects without diabetes mellitus. Am J Cardiol. 2005;96(9):1273-1277. [pmid: 16253596].
Rodriguez-Moran M, Guerrero-Romero F. Pentoxifylline is as effective as captopril in the reduction of microalbuminuria in non-hypertensive type 2 diabetic patients—a randomized, equivalent trial. Clin Nephrol. 2005;64(2):91-97. [pmid: 16114784].
Rodriguez-Moran M, Guerrero-Romero F. Elevated concentrations of C-reactive protein in subjects with type 2 diabetes mellitus are moderately influenced by glycemic control. J Endocrinol Invest. 2003;26(3):216-221. [pmid: 12809171].
Rolla A. The pathophysiological basis for intensive insulin replacement. Int J Obes Relat Metab Disord. 2004;28(Suppl 2):S3-7.
Rosei EA, Rizzoni D, Muiesan ML, et al. Effects of candesartan cilexetil and enalapril on inflammatory markers of atherosclerosis in hypertensive patients with non-insulin-dependent diabetes mellitus. J Hypertens. 2005;23(2):435-444. [pmid: 15662233].
Ross CE, Wu C. The links between education and health. Am Sociol Rev. 1995;60(5):719-745.
Rossert J, Fouqueray B. Screening and management of patients with early chronic kidney disease. Acta Diabetologica. 2004;41(Suppl 1):S6-12. [pmid: 15103542].
Rubin RR, Fujimoto WY, Marrero DG, et al. The Diabetes Prevention Program: recruitment methods and results. Control Clin Trials. 2002;23(2):157-171. [pmid: 11943442].
Ruilope LM, Segura J. Losartan and other angiotensin II antagonists for nephropathy in type 2 diabetes mellitus: a review of the clinical trial evidence. Clin Ther. 2003;25(12):3044-3064. [pmid: 14749145].
Russell JC. Reduction and prevention of the cardiovascular sequelae of the insulin resistance syndrome. Curr Drug Targets Cardiovasc Haematol Disord. 2001;1(2):107-120. [pmid: 12769660].
Ryan EA, Imes S, Wallace C. Short-term intensive insulin therapy in newly diagnosed type 2 diabetes. Diabetes Care. 2004;27(5):1028-1032. [pmid: 15111515].
Salmasi AM, Alimo A, Dancy M. Prevalence of unrecognized abnormal glucose tolerance in patients attending a hospital hypertension clinic. American J Hypertens. 2004;17(6):483-488.
Samuels TA, Cohen D, Brancati FL, et al. Delayed diagnosis of incident type 2 diabetes mellitus in the ARIC study. Am J Manag Care. 2006;12(12):717-724. [pmid: 17149994].
Sarafidis PA, Lasaridis AN, Nilsson PM, et al. The effect of rosiglitazone on novel atherosclerotic risk factors in patients with type 2 diabetes mellitus and hypertension. An open-label observational study. Metabolism. 2005;54(9):1236-1242. [pmid: 16125536].
Saudek C, Derr R, Kalyani R. Assessing glycemia in diabetes using self-monitoring blood glucose and hemoglobin A1c. JAMA. 2006;295(14).
Saydah SH, Miret M, Sung J, et al. Postchallenge hyperglycemia and mortality in a national sample of U.S. adults. Diabetes Care. 2001;24(8):1397-1402. [pmid: 11473076].
Scheen AJ. Renin-angiotensin system inhibition prevents type 2 diabetes mellitus. Part 2. Overview of physiological and biochemical mechanisms. Diabetes Metab. 2004;30(6):498-505. [pmid: 15671919].
Scheid DC, McCarthy LH, Lawler FH, et al. Screening for microalbuminuria to prevent nephropathy in patients with diabetes: a systematic review of the evidence. J Fam Pract. 2001;50(8):661-668. [pmid: 11509158].
Schnell O. The links between diabetes and cardiovascular disease. J Interv Cardiol. 2005;18(6):413-416. [pmid: 16336420].
Selvin E, Coresh J, Golden SH, et al. Glycemic control and coronary heart disease risk in persons with and without diabetes: the atherosclerosis risk in communities study. Arch Intern Med. 2005;165(16):1910-1916. [pmid: 16157837].
Selvin E, Coresh J, Shahar E, et al. Glycaemia (haemoglobin A1c) and incident ischaemic stroke: the Atherosclerosis Risk in Communities (ARIC) Study. Lancet Neurol. 2005;4(12):821-826. [pmid: 16297840].
Selvin E, Marinopoulos S, Berkenblit G, et al. Meta-analysis: glycosylated hemoglobin and cardiovascular disease in diabetes mellitus. Ann Intern Med. 2004;141(6):421-431. [pmid: 15381515].
Setter SM, Iltz JL, Thams J, et al. Metformin hydrochloride in the treatment of type 2 diabetes mellitus: a clinical review with a focus on dual therapy. Clin Ther. 2003;25(12):2991-3026. [pmid: 14749143].
Sever PS, Dahlof B, Poulter NR, et al. Rationale, design, methods and baseline demography of participants of the Anglo-Scandinavian Cardiac Outcomes Trial. ASCOT investigators. J Hypertens. 2001;19(6):1139-1147. [pmid: 11403364].
Shahinfar S, Brenner BM, Mogensen CE, et al. Losartan treatment effect on renal outcomes in type 2 diabetic patients with nephropathy after adjusting for an imbalance in baseline proteinuria. Nephrol Dial Transplant. 2003;18(Suppl 4):105.
Shahinfar S, Lyle PA, Zhang Z, et al. Losartan: lessons learned from the RENAAL study. Expert Opin Pharmacother. 2006;7(5):623-630. [pmid: 16553578].
Shepherd J, Blauw GJ, Murphy MB, et al. The design of a prospective study of Pravastatin in the Elderly at Risk (PROSPER). PROSPER Study Group. PROspective Study of Pravastatin in the Elderly at Risk. Am J Cardiol. 1999;84(10):1192-1197. [pmid: 10569329].
Sherwin RS, Anderson RM, Buse JB, et al. The prevention or delay of type 2 diabetes. Diabetes Care. 2003;26(Suppl 1):S62-69. [pmid: 12502620].
Uzu T, Sawaguchi M. Shiga Microalbuminuria Reduction Trial Group, et al. Reduction of microalbuminuria in patients with type 2 diabetes: the Shiga Microalbuminuria Reduction Trial (SMART). Diabetes Care. 2007;30(6):1581-1583. [pmid: 17363751].
Shotliff K, Moore D, Dimock J, et al. Screening for diabetic retinopathy—false positives do occur (it could be Shagreene). Diabet Med. 2004;21(6):651. [pmid: 15154964].
Sica DA, Bakris GL. Type 2 diabetes: RENAAL and IDNT—the emergence of new treatment options. J Clin Hypertens (Greenwich). 2002;4(1):52-57. [pmid: 11821641].
Singleton JR, Smith AG, Bromberg MB. Painful sensory polyneuropathy associated with impaired glucose tolerance. Muscle Nerve. 2001;24(9):1225-1228. [pmid: 11494277].
Singleton JR, Smith AG, Bromberg MB. Increased prevalence of impaired glucose tolerance in patients with painful sensory neuropathy. Diabetes Care. 2001;24(8):1448-1453. [pmid: 11473085].
Sjostrom L. Analysis of the XENDOS study (Xenical in the Prevention of Diabetes in Obese Subjects). Endocr Pract. 2006;12(Suppl 1):31-33. [pmid: 16627377].
Smith NL, Barzilay JI, Kronmal R, et al. New-onset diabetes and risk of all-cause and cardiovascular mortality: the Cardiovascular Health Study. Diabetes Care. 2006;29(9):2012-2017. [pmid: 16936145].
Smith NL, Barzilay JI, Shaffer D, et al. Fasting and 2-hour postchallenge serum glucose measures and risk of incident cardiovascular events in the elderly: the Cardiovascular Health Study. Arch Intern Med. 2002;162(2):209-216. [pmid: 11802755].
Smith NL, Savage PJ, Heckbert SR, et al. Glucose, blood pressure, and lipid control in older people with and without diabetes mellitus: the Cardiovascular Health Study. J Am Geriatr Soc. 2002;50(3):416-423. [pmid: 11943034].
Sorkin JD, Muller DC, Fleg JL, et al. The relation of fasting and 2-h postchallenge plasma glucose concentrations to mortality: data from the Baltimore Longitudinal Study of Aging with a critical review of the literature. Diabetes Care. 2005;28(11):2626-2632. [pmid: 16249530].
Spann S, Nutting P, Galliher J, et al. Managment of type 2 diabetes in the primary care seting: a practice-based research network study. Ann Fam Med. 2006;4(1):23-31. [pmid: 16449393]. [pmcid: 1466989].
Spencer S. Pressure relieving interventions for preventing and treating diabetic foot ulcers. Cochrane Database of Syst Rev. 2006(3).
Spijkerman A, Griffin S, Dekker J, et al. What is the risk of mortality for people who are screen positive in a diabetes screening programme but who do not have diabetes on biochemical testing? Diabetes screening programmes from a public health perspective. J Med Screen. 2002;9(4):187-190. [pmid: 12518011].
Spijkerman AM, Dekker JM, Nijpels G, et al. Impact of diabetes duration and cardiovascular risk factors on mortality in type 2 diabetes: the Hoorn Study. Eur J Clin Invest. 2002;32(12):924-930. [pmid: 12534452].
Spijkerman AM, Henry RM, Dekker JM, et al. Prevalence of macrovascular disease amongst type 2 diabetic patients detected by targeted screening and patients newly diagnosed in general practice: the Hoorn Screening Study. J Intern Med. 2004;256(5):429-436. [pmid: 15485479].
Srivastava PM, Calafiore P, MacIsaac RJ, et al. Thiazolidinediones and congestive heart failure—exacerbation or new onset of left ventricular dysfunction?. Diabet Med. 2004;21(8):945-950. [pmid: 15270804].
Steg PG, Bhatt DL, Wilson PWF, et al. One-year cardiovascular event rates in outpatients with atherothrombosis. JAMA. 2007;297(11):1197-1206. [pmid: 17374814].
Stein EA, Corsini A, Gimpelewicz CR, et al. Fluvastatin treatment is not associated with an increased incidence of cancer. Int J Clin Pract. 2006;60(9):1028-1034. [pmid: 16939542].
Steiner G. A new perspective in the treatment of dyslipidemia : can fenofibrate offer unique benefits in the treatment of type 2 diabetes mellitus?. Treat Endocrinol. 2005;4(5):311-317. [pmid: 16185099].
Steines W, Piehlmeier W, Schenkirsch G, et al. Effectiveness of a disease management programme for patients with type 2 diabetes mellitus and albuminuria in primary care - the PROSIT project (Proteinuria Screening and Intervention). Exp Clin Endocrinol Diabetes. 2004;112(2):88-94. [pmid: 15031773].
Stephens JW, Williams R. Time to stop talking about screening for diabetes?. Diabet Med. 2006;23(11):1163-1164. [pmid: 17054589].
Stevens RJ, Coleman RL, Adler AI, et al. Risk factors for myocardial infarction case fatality and stroke case fatality in type 2 diabetes: UKPDS 66. Diabetes Care. 2004;27(1):201-207. [pmid: 14693990].
Stevens RJ, Stratton IM, Holman RR, et al. UKPDS58—modeling glucose exposure as a risk factor for photocoagulation in type 2 diabetes. J Diabetes Complications. 2002;16(6):371-376. [pmid: 12477619].
Stewart-Brown S, Farmer A. Screening could seriously damage your health. Bmj. 1997;314(7080):533-534. [pmid: 9055702]. [pmcid: 2126029].
Stratton IM. Association of glycaemia with macrovascular and microvascular complications of type 2 diabetes (UKPDS 35): prospective observational study. Bmj. 2000;321(7258):405-412. [pmid: 10938048]. [pmcid: 27454].
Stratton IM, Cull CA, Adler AI, et al. Additive effects of glycaemia and blood pressure exposure on risk of complications in type 2 diabetes: a prospective observational study (UKPDS 75). Diabetologia. 2006;49(8):1761-1769. [pmid: 16736131].
Streets P. Screening for type 2 diabetes. Undiagnosed diabetes must be detected. Bmj. 2001;323(7310):453-454. author reply 454–455.
Strippoli GFM, Craig M, Schena FP, et al. Antihypertensive agents for preventing the progression of diabetic kidney disease. Cochrane Database of Syst Rev. 2006(3).
Tan HH, McAlpine RR, James P, et al. Diagnosis of type 2 diabetes at an older age: effect on mortality in men and women. Diabetes Care. 2004;27(12):2797-2799. [pmid: 15562187].
Tanne D, Koren-Morag N, Goldbourt U. Fasting plasma glucose and risk of incident ischemic stroke or transient ischemic attacks: a prospective cohort study. Stroke. 2004;35(10):2351-2355. [pmid: 15308782].
The Mount Hood Modeling Group. Computer Modeling of Diabetes and Its Complications: A report on the Fourth Mount Hood Challenge Meeting. Diabetes Care. 2007;30(6):1638-1646. [pmid: 17526823].
Thomas GN, Chan P, Tomlinson B. The role of angiotensin II type 1 receptor antagonists in elderly patients with hypertension. Drugs Aging. 2006;23(2):131-155. [pmid: 16536636].
Thomas MC, Walker MK, Emberson JR, et al. Prevalence of undiagnosed Type 2 diabetes and impaired fasting glucose in older British men and women. Diabet Med. 2005;22(6):789-793. [pmid: 15910633].
Thompson WG. Early recognition and treatment of glucose abnormalities to prevent type 2 diabetes mellitus and coronary heart disease. Mayo Clin Proc. 2001;76(11):1137-1143. [pmid: 11702902].
Thornberry NA, Weber AE. Discovery of JANUVIA (Sitagliptin), a selective dipeptidyl peptidase IV inhibitor for the treatment of type 2 diabetes. Curr Top Med Chem. 2007;7(6):557-568. [pmid: 17352677].
Thornley-Brown D, Wang X, Wright JT Jr, et al. Differing effects of antihypertensive drugs on the incidence of diabetes mellitus among patients with hypertensive kidney disease. Arch Intern Med. 2006;166(7):797-805. [pmid: 16606818].
Torgerson JS, Arlinger K, Kappi M, et al. Principles for enhanced recruitment of subjects in a large clinical trial. The XENDOS (XENical in the prevention of Diabetes in Obese Subjects) study experience. Control Clin Trials. 2001;22(5):515-525. [pmid: 11578785].
Tunis S. Econoic anaylsis in healthcare decisions. Am J Manag Care. 2004;10:301-304. [pmid: 15152698].
Tuomilehto J, Leiter LA, Kallend D. A review of the efficacy of rosuvastatin in patients with type 2 diabetes. Int J Clin Pract. 2004;Supplement.(143):30–40.
Tuomilehto J, Wareham N, Tuomilehto J, et al. Glucose lowering and diabetes prevention: are they the same?. Lancet. 2006;368(9543):1218-1219. [pmid: 17027710].
Twigg SM, Kamp MC, Davis TM, et al. Prediabetes: a position statement from the Australian Diabetes Society and Australian Diabetes Educs Association. Med J Aust. 2007;186(9):461-465. [pmid: 17484708].
Matthews DR, Stratton IM. United Kingdom Prospective Diabetes Study Group, et al. Risks of progression of retinopathy and vision loss related to tight blood pressure control in type 2 diabetes mellitus: UKPDS 69. Arch Ophthalmol. 2004;122(11):1631-1640. [pmid: 15534123].
Unwin N, Shaw J, Zimmet P, et al. Impaired glucose tolerance and impaired fasting glycaemia: the current status on definition and intervention. Diabet Med. 2002;19(9):708-723. [pmid: 12207806].
Vaag AA. Glycemic control and prevention of microvascular and macrovascular disease in the Steno 2 study. Endocr Pract. 2006;12(Suppl 1):89-92. [pmid: 16627389].
Vaccaro O, Riccardi G. Changing the definition of impaired fasting glucose: impact on the classification of individuals and risk definition. Diabetes Care. 2005;28(7):1786-1788. [pmid: 15983335].
Vaccaro O, Riccardi G. Comment to: Borch-Johnsen K, Colagiuri S, Balkau B et al. (2004) Creating a pandemic of prediabetes: the proposed new diagnostic criteria for impaired fasting glycaemia. Diabetologia 47:1396–1402. Diabetologia. 2004;47(11):2047–2048.
Valk GD, Kriegsman DMW, Assendelft WJJ. Patient education for preventing diabetic foot ulceration Cochrane Database of Syst Rev. 2006(3).
van Dam RM, Rimm EB, Willett WC, et al. Dietary patterns and risk for type 2 diabetes mellitus in U.S. men. Ann Intern Med. 2002;136(3):201-209. [pmid: 11827496].
Van de Laar FA, Lucassen P, Akkermans RP, et al. Alpha-glucosidase inhibitors for type 2 diabetes mellitus. Cochrane Database of Syst Rev. 2006(3).
Van de Laar FA, Lucassen PL, Akkermans RP, et al. Alpha-glucosidase inhibitors for people with impaired glucose tolerance or impaired fasting blood glucose. Cochrane Database Syst Rev. 2006(4):CD005061.
van de Laar FA, van de Lisdonk EH, Lucassen PL, et al. Fat intake in patients newly diagnosed with type 2 diabetes: a 4-year follow-up study in general practice. Br J Gen Pract. 2004;54(500):177-182. [pmid: 15006122]. [pmcid: 1314827].
van de Veire NR, de Winter O, Gillebert TC, et al. Diabetes and impaired fasting glucose as predictors of morbidity and mortality in male coronary artery disease patients with reduced left ventricular function. Acta Cardiol. 2006;61(2):137-143. [pmid: 16716014].
Varma R, Torres M, Pena F, et al. Prevalence of diabetic retinopathy in adult Latinos: the Los Angeles Latino eye study. Ophthalmology. 2004;111(7):1298-1306. [pmid: 15234129].
Varughese GI, Lip GY, Varughese GI, et al. Antihypertensive therapy in diabetes mellitus: insights from ALLHAT and the Blood Pressure-Lowering Treatment Trialists' Collaboration meta-analysis. J Hum Hypertens. 2005;19(11):851-853. [pmid: 16079882].
Verdecchia P, Reboldi G, Angeli F, et al. Adverse prognostic significance of new diabetes in treated hypertensive subjects. Hypertension. 2004;43(5):963-969. [pmid: 15037557].
Vermes E, Ducharme A, Bourassa MG, et al. Enalapril reduces the incidence of diabetes in patients with chronic heart failure: insight from the Studies Of Left Ventricular Dysfunction (SOLVD). Circulation. 2003;107(9):1291-1296. [pmid: 12628950].
Viberti G, Kahn SE, Greene DA, et al. A diabetes outcome progression trial (ADOPT): an international multicenter study of the comparative efficacy of rosiglitazone, glyburide, and metformin in recently diagnosed type 2 diabetes. Diabetes Care. 2002;25(10):1737-1743. [pmid: 12351470].
Vijan S, Hayward RA. American College of P. Pharmacologic lipid-lowering therapy in type 2 diabetes mellitus: background paper for the American College of Physicians. Ann Intern Med. 2004;140(8):650-658. [pmid: 15096337].
Vinik AI, Maser RE, Mitchell BD, et al. Diabetic autonomic neuropathy. Diabetes Care. 2003;26(5):1553-1579. [pmid: 12716821].
Vivian EM, Rubinstein GB. Pharmacologic management of diabetic nephropathy. Clin Ther. 2002;24(11):1741-1756. discussion 1719. [pmid: 12501871].
Walker M, Thomson A, Whincup PH. Screening for type 2 diabetes. Screening would have important resource implications for primary care. Bmj. 2001;323(7310):454-455.
Wang JJ, Qiao Q, Miettinen ME, et al. The metabolic syndrome defined by factor analysis and incident type 2 diabetes in a Chinese population with high postprandial glucose. Diabetes Care. 2004;27(10):2429-2437. [pmid: 15451912].
Wareham NJ, Griffin SJ. Should we screen for type 2 diabetes? Evaluation against National Screening Committee criteria. Bmj. 2001;322(7292):986-988. [pmid: 11312236]. [pmcid: 1120142].
Weinstein AR, Sesso HD, Lee IM, et al. Relationship of physical activity vs body mass index with type 2 diabetes in women. JAMA. 2004;292(10):1188-1194. [pmid: 15353531].
Wens J, Van Casteren V, Vermeire E, et al. Diagnosis and treatment of type 2 diabetes in three Belgian regions. Registration via a network of sentinel general practices. Eur J Epidemiol. 2001;17(8):743-750. [pmid: 12086092].
White JR Jr. Economic considerations in treating patients with type 2 diabetes mellitus. Am J Health Syst Pharm. 2002;59(Suppl 9):S14-17. [pmid: 12489382].
Wild SH, Smith FB, Lee AJ, et al. Criteria for previously undiagnosed diabetes and risk of mortality: 15-year follow-up of the Edinburgh Artery Study cohort. Diabet Med. 2005;22(4):490-496. [pmid: 15787678].
Wilson J, Junger G. Priciples and practice of screening for disease. Geneva: World Health Organization. 1968;(Public Health Papers No. 34).
Wilson Tang WH, Maroo A, Young JB. Ischemic heart disease and congestive heart failure in diabetic patients. Med Clin North Am. 2004;88(4):1037-1061. [pmid: 15308389].
Wing LM, Reid CM, Ryan P, et al. A comparison of outcomes with angiotensin-converting—enzyme inhibitors and diuretics for hypertension in the elderly. N Engl J Med. 2003;348(7):583-592. [pmid: 12584366].
Winkelmayer WC, Zhang Z, Shahinfar S, et al. Efficacy and safety of angiotensin II receptor blockade in elderly patients with diabetes. Diabetes Care. 2006;29(10):2210-2217. [pmid: 17003295].
Woerle HJ, Pimenta WP, Meyer C, et al. Diagnostic and therapeutic implications of relationships between fasting, 2-hour postchallenge plasma glucose and hemoglobin a1c values. Arch Intern Med. 2004;164(15):1627-1632. [pmid: 15302632].
Woodward G, van Walraven C, Hux JE. Utilization and outcomes of HbA1c testing: a population-based study. CMAJ. 2006;174(3):327-329. [pmid: 16446473]. [pmcid: 1373714].
Woolthuis K, de Grauw W, van de laar F, et al. Screening for type 2 diabetes mellitus. Cochrane Database of Syst Rev. 2006;1(3).
Worrall G. Screening healthy people for diabetes: is it worthwhile?. J Fam Pract. 1991;33(2):155-160. [pmid: 1890396].
Wylie-Rosett J, Herman WH, Goldberg RB. Lifestyle intervention to prevent diabetes: intensive and cost effective. Curr Opin Lipidol. 2006;17(1):37-44. [pmid: 16407714].
Xiang AH, Peters RK, Kjos SL, et al. Pharmacological treatment of insulin resistance at two different stages in the evolution of type 2 diabetes: impact on glucose tolerance and beta-cell function. J Clin Endocrinol Metab. 2004;89(6):2846-2851. [pmid: 15181067].
Zeymer U. Cardiovascular benefits of acarbose in impaired glucose tolerance and type 2 diabetes. Int J Cardiol. 2006;107(1):11-20. [pmid: 16337493].
Zhou H, Isaman DJ, Messinger S, et al. A computer simulation model of diabetes progression, quality of life, and cost. Diabetes Care. 2005;28(12):2856-2863. [pmid: 16306545].
Ziemer DC, Berkowitz KJ, Panayioto RM, et al. A simple meal plan emphasizing healthy food choices is as effective as an exchange-based meal plan for urban African Americans with type 2 diabetes. Diabetes Care. 2003;26(6):1719-1724. [pmid: 12766100].

### Not Available in English

Chalmers J. ADVANCE study: objectives, design and current status. Drugs. 2003;63(Spec No 1):39-44. [pmid: 12708881].
Kosugi E. Effect of small-dose captopril on microalbuminuria in normotensive type 2 diabetic patients: A two-year pilot study. Toho Igakkai Zasshi. 2002;49(45):227-232.
Tao LL, Deng YB, Fan XB, et al. Effect of exercise training in patients with impaired glucose tolerance. Zhongguo Linchuang Kangfu. 2004;8(15):2912-2913.