# Appendix B Evidence Tables

Table B1 Evidence Table On Re-Screening Intervals (SQ1)

Author, Year Quality assessment | Study objective | Country/Setting | Study design | N | Length of follow-up | Inclusion criteria | Exclusion criteria | Participant selection | Population | Intervention | Results | Loss to follow-up | Comments
Lindeman, 2003^42^ Fair | To determine frequency necessary for screening healthy elderly persons (>65 y) using FSG | New Mexico, US | Longitudinal, prospective cohort | 299 | 12.4 y (mean) | New Mexico Aging Process Study (NMAPS) participants > age 65 y at study entry Healthy (defined as not meeting exclusion criteria) | Overt clinical conditions, (eg, coronary heart disease, diabetes mellitus, significant peripheral vascular disease, hepatic disease) History of internal cancer in last 10 y Hepatitis On prescription medication, except for thyroid replacement therapy and antihypertensive medications to control systolic blood pressure initially < 180 mm Hg or diastolic pressure < 100 mm Hg | Community-based volunteers | Upper, middle class 97% Caucasian; 3% Hispanic 117 Men; 182 Women Mean age 71.6 (4.8 SD) | NMAPS participants followed with annual FSG concentrations and BMI Started in 1980, some followed up to 18 y (mean 12.4 y) | Slopes of FSGs plotted over time in y for each person: 220 had a negative slope (of which 48 significantly negative [p<0.05]) and 79 had a positive slope (of which 9 significantly positive [p<0.05]) - FSGs mainly tended to < with age. 4 of 299 (1.3%) with entry FSG < 126 mg/dL and 6+ annual visits have subsequently met criteria for DM2 (2 consecutive FSGs > 126 mg/dL). Mean number of annual examinations 12.4 y (SD) 0 of 68 > 75 y old developed diabetes or significantly positive slope. | Started with 303 in 1980 (195 in this cohort lost to follow-up over the years) 1985, 56 participants added to replace those to death or drop out (# not given) 1997, 310 had returned for 6 annual visits; of which 164 had returned for 12+ annual visits 11 dropped from analysis because of diabetes diagnosis 299 in final analysis with 6+ exams; entire analysis has data over 18 y | Paper states that ADA recommends screening for everyone > 45 y every 3 y. Author's conclusion that not necessary to screen non-obese elders (excluding minorities) age >65 y with a FSG <100 mg/dL, or those age >75 y every 3 y, as recommended by the ADA. Suggestions are not made for re-screening intervals in this population.

Abbreviations: ADA, American Diabetes Association; BMI, body mass index; DM2, type 2 diabetes; FSG, fasting serum glucose; N, number of study participants; NMAPS, New Mexico Aging Proceess Study; SQ, subsidiary question; y, year.

Table B2 Evidence Table on A1C (SQ2)

Author, Year Quality | Study objective | Setting; Country | Study design | Length of follow-up | Inclusion criteria | Exclusion criteria | Participant selection | Population | Diabetes risk factors | Screening intervention | Outcomes | Other Results | Comments
Anand et al, 2003^50^ Not rated | To investigate whether the addition of A1c measurement to fasting glucose improves the classification of patients with glucose intolerance compared to the use of fasting glucose alone | Multi-center Canada December 1996 – October 1998 | Cross-sectional study Nondiabetic participants Construct receiver operating characteristic curves for fasting glucose and A1c measurements using the 1998 WHO diagnostic criteria as gold standard | N/A | Nondiabetic status (definition NR) | Established diabetes | Random recruitment, clinical setting NR | Total n = 936 % male NR Ethnicity: South Asian 34% Chinese 33% European 33% | NR | FPG and A1c (low-pressure chromatography - not standardized) compared to: Gold standard criteria (WHO - all 2-h glucose values follow a 75 g glucose load): Normal - FPG < 126 mg/dL AND 2-h glucose < 140 mg/dL IGT - FPG < 126 mg/dL AND 2-h glucose 140 – 198 mg/dL Diabetic - FPG ≥ 126 mg/dL OR 2-h glucose ≥ 200 mg/dL 1997 ADA criteria were also applied to the population and compared to WHO criteria | Optimal cut-points for diagnosis of diabetes: A1c ≥ 5.9% (95% CI):; - Sensitivity - 75.0 (64.0 – 86.0); - Specificity - 79.1 (76.4 – 81.8); - Positive LR - 3.6 (2.9–4.3); - Negative LR - 0.3 (0.2–0.5); A1c ≥ 5.9% and FPG ≥ 103 mg/dL:; - Sensitivity - 71.7 (60.3–83.1); - Specificity - 95.0 (93.5–96.4); - Positive LR - 14.3 (9.6–19.0); - Negative LR - 0.3 (0.2–0.4); For the diagnosis of IGT, the receiver operating characteristic curves were nearly linear, indicating any increase in sensitivity was associated with a similar increase in false-positive rates. | Prevalence of diabetes and IGT in this population using WHO criteria:; - Normal - 78.4%; - IGT - 15.2%; - Diabetes - 6.4%; Sensitivity of ADA criteria using WHO criteria as standard: 48.3 (35.7 – 61.0) | A1c correlated with stages of glucose tolerance as defined by WHO criteria. The operating characteristics of the FPG + A1c tests varied substantially between ethnic groups. The combination of both tests was least sensitive (47.4) amongst those of European descent, but had good specificity (97.6). The test performed best amongst those of South Asian descent. The reporting of likelihood ratios allows application of these tests in populations with differing pre-test probabilities of disease. The variation between ethnic groups seen here underscores the need to interpret test results according to the characteristics of the population in which it is being applied.
Bennett et al, 2007^51^ Good | To assess the validity of A1c as a screening tool for early detection of DM2 | Multiple studies in systematic review 1994 – September 2004 | Systematic review | N/A | A1c articles published in English 75g OGTT results as reference test FPG as comparison test Reference test performed in at least 80% Sensitivity and specificity data of tests available Studies had to report, or have results convertable to, DCCT-aligned A1c results | Lack of inclusion criteria | Community volunteers Primary care referrals Hospitalized patients at high-risk for diabetes/prediabetes | Community-based studies: Range of n: 401 – 10,447 Ethnicity/nationality: Australia, Italy, United States, United Kingdom Diabetes prevalence: 6.2 – 44% Age varied widely: 13 – 92 y Hospital-based studies: Range of n: 111 – 2877 Ethnicity/nationality: Australia, Poland, Japan, Chinese, Indian, Malay, Hong Kong Diabetes prevalence: 10.7 – 21% Mean age: 43 – 56 y (excluding one study, which did not report mean) | Obesity, family history of diabetes, history of gestational diabetes, history of hypertension 1 study included patients with IGT | DCCT-aligned A1c FPG 75 g OGTT (reference standard, WHO criteria used to define diabetes) | Three optimum A1c cutpoints: 5.9% - Sensitivity 76 – 95%, Specificity 67 – 86% 6.1% - Sensitivity 78 – 81%, Specificity 79 – 84% 6.2% - Sensitivity 43 – 81%, Specificity 88 – 99% FPG: ≥ 126 mg/dL - Sensitivity 19% – 91%, Specificity 21.6 – 100% (all hospital based studies had specificities of 100%) | A1c and FPG sensitivity lower for detecting IGT | Review had fairly strict inclusion criteria. Risk for diabetes varied between populations of different included studies - most studies included populations that were at higher risk for diabetes. Comparisons between studies should be interpreted with caution given the difference in included populations.
Colagiuri et al, 2004^53^ Not rated | Evaluate the performance characteristics of the variations of a screening protocol for the identification of people with undiagnosed diabetes, IGT, or IFG | Multi-center Australia 1999-2000 | Cross-sectional study Analysis of the AusDiab study | N/A | Age > 24 y | Rural communities and those with predominant Aboriginal or Torres Strait Islander populations were excluded | 42 representative census districts randomly chosen and all adult residents > age 24 y were approached | Total n = 11,247 Diabetes prevalence: 7.4%, half known and half undiagnosed Total n without known diabetes: 10,508 N with one risk factor and without known diabetes: 5604 Demographics NR 38% of total population age ≥ 55 y | Age ≥ 55 Age ≥ 45 with obesity, positive family history, or HTN Age ≥ 35 and high-risk ethnicity IGT or IFG Clinical cardiovascular disease History of gestational diabetes Obese women with polycystic ovary syndrome | FPG, A1c (by high-pressure liquid chromatography), and OGTT in all people without known diabetes Assessment of risk factors for diabetes Evaluated the operating characteristics of risk factor assessment along with FPG with or without A1c measurements in detecting diabetes or IGT/IFG as defined by OGTT measurement | N with IGT (FPG < 126 mg/dL and 2-h OGTT ≥ 140 mg/dL) = 1372 (11%) N with IFG (FPG 110–126 mg/dL and 2-h OGTT < 140mg/dL) = 642 (5.9%) The following calculations use n = 5604 (population with 1 risk factor and without known diabetes): If FPG > 108 mg/dL, then use A1c ≥ 5.3%:; - DM diagnosis - sensitivity 73.7, specificity 89.2, PPV 21.4; - IGT or IFG diagnosis - sensitivity 33.5, specificity 94.1, PPV 54.8; FPG > 108 mg/dL OR A1c ≥ 5.3%:; - DM diagnosis - sensitivity 84.9, specificity 73.5, PPV 11.4; - IGT or IFG diagnosis - sensitivity 60.3, specificity 80.8, PPV 40.2 | NNS to identify one new case of diabetes: 32 The risk factors of age alone, or age + one additional risk, accounted for 87% with undiagnosed diabetes History of cardiovascular disease or gestational diabetes added little | Study examined the performance characteristics of the Australian screening protocol, which includes provisions to use OGTT in persons with FPG 100–124 mg/dL. Few persons in the study were identified as being from a high-risk ethnic group.
Edelman et al, 2004^54^ Fair | To determine the 3 y incidence of diabetes in an outpatient population and to determine if baseline A1c is an independent predictor of new onset diabetes. | Single center United States - VA Medical Center 1996-1998 | Prospective cohort | 3 y | Age 45–64 y with 1 outpatient visit between October 1996 – March 1998 | Prevalent diabetes by participant self-report, prescription for hypoglycemic medication, short life-expectancy, no telephone access | All persons with outpatient visit during recruitment period that agreed to participate | Total n = 1253 Age: 55 y % male: 94 Ethnicity: White 69% African American 29% Other 2% | Family history diabetes 38% Overweight 43% Obese 35% HTN 53% | Baseline: A1c (high-pressure liquid chromatography) and FPG if A1c ≥ 6.0% Annual follow-up for two years: self-report of new DM diagnosis Rescreening third year: identical to baseline assessment Diabetes diagnosis either FPG > 126 mg/dL or self-report | N with prevalent unrecognized DM at baseline: 56/1253 (4.5%) Person-years follow-up: 3257 Incidence of DM: 2.2/100 patient-years 80% retention of cohort at three years Annual incidence of DM according to A1c:; - Normal (A1c ≤ 5.5%) - 0.8%/year; - High-normal (5.6–6.0%) - 2.5%/year; - Elevated (6.1–6.9%) - 7.8%/year; After adjusting for baseline A1c, only baseline BMI was associated with incident diabetes. Obese persons with elevated baseline A1c had annual DM incidence of 11.4%. | Odds ratio for developing DM for each additional 5 Units BMI increase was 1.7 (95%CI - 1.4–2.1) | Mostly male population - results may be less generalizable Incidence rate of DM higher in this population than in community based setting Some cases of incident DM may have been missed because only those with A1c ≥ 6.0 were screened with FPG Though this approach may sacrifice sensitivity, those at highest risk for diabetes are likely to be identified and may be re-screened at shorter intervals
Ellison et al, 2005^55^ Not rated | Evaluate the performance characteristics of A1c in identifying persons with undiagnosed diabetes as defined by FPG and 2-h OGTT results | Community-based subsample of a large hepatitis B screening study which targeted non-Europeans New Zealand | Cross-sectional | N/A | Participants in hepatitis B screening study age > 20 y, without known diabetes, and with A1c levels 5–7% who lived within 1 hour of testing centers | Established diabetes | Community recruitment | Total n (hepatitis B screening study): 50,819 244/300 (81%) approached to participate in substudy completed all testing Age: 48.7 y % male: 50 Ethnicity: Maori 82% Pacific Islander 7% Asian 9% European 4% | Most of population from high-risk ethnic group, other risk factors NR | A1c (high-pressure liquid chromatography), OGTT | Of total n (50,819), mean (SD) A1c was 5.4 (1.0). Diabetes substudy: 12% had A1c ≥ 6.1%, 4% had A1c ≥ 7.1% Prevalence of undiagnosed diabetes (as defined by FPG ≥ 126 mg/dL or 2-h OGTT ≥ 200 mg/dL): 35/244 = 14.3% Ability of A1c ≥ 6.1% to detect: FPG ≥ 126 mg/dL: Sensitivity - 94% Specificity - 77% FPG ≥ 110 mg/dL: Sensitivity - 64% Specificity - 89% 2-h OGTT ≥ 200 mg/dL: Sensitivity - 90% Specificity 73% | The receiver operating characteristics are presented and the greatest specificity for detecting diabetes by elevated FPG comes with A1c cutoff of 6.4% (sensitivity 59%, specificity 93%). | The population under study is mostly comprised of ethnicity groups at high risk for diabetes and the prevalence of undiagnosed diabetes in this population is high. Those with A1c < 5% were excluded from study, so the persons at lowest risk for having undiagnosed diabetes were not represented in this study.
Geberhiwot et al, 2005^56^ Not rated | To determine whether A1c may be useful in selecting persons with DM risk factors for OGTT who have normal FPG levels | Single center United Kingdom | Cross-sectional | N/A | 2+ diabetes risk factors Initial FPG ≤ 108 mg/dL | Established diabetes | Convenience sample of metabolic clinic referral population | Total n = 580 Study n (initial FPG ≤ 108 mg/dL) = 225 Age: Men 52.9 y (12.0) Women 53.3 y (13.5) % male: 52 Race NR | Obesity, dyslipidemia, HTN, previous history of IGT, family history of diabetes | A1c (high-pressure liquid chromatography), OGTT Diabetes diagnosis: WHO criteria according to OGTT results | Prevalence rates:; - Normal glucose tolerance - 173/225 = 76.9%; - IGT - 45/225 = 20%; - DM - 7/225 = 3.1%; From receiver operating characteristic curve, optimal A1c cut-point of 5.6% in detecting 2-h OGTT ≥ 140 mg/dL:; - Sensitivity - 72%; - Specificity - 77% | Mean FPG (SD): 97 mg/dL (9 mg/dL) | Almost one-quarter of this population with normal FPG had abnormal glucose tolerance on OGTT testing. This is a referral population at risk for diabetes, so generalizability may be an issue. Not clear how many persons would fall into lowered threshold for IFG diagnosis (100 mg/dL)
Jesudason et al, 2003^57^ Not rated | 1) Compare different thresholds of A1c and FPG to OGTT for screening DM2; 2) Determine relationship between A1c and FPG and cardiovascular risk; 3) Compare A1c measured by a portable device to HPLC | Single center United Kingdom | Cross-sectional | N/A | Age > 18 y with no prior history of diagnosed diabetes and with risk factors for DM2, or symptoms of hyperglycemia | Pregnant women | Volunteers from community | N = 505 | Obesity, family history of diabetes, history of gestational diabetes | A1c (by HPLC and DCA 2000, a portable immunoassay device from Bayer) Fasting plasma glucose 75g OGTT Questionnaire re: existing CV disease | Prevalence rates: WHO criteria; - IGT - 123/505 = 24.4%; - DM - 54/505 = 10.7%; ADA criteria; - IFG - 36/505 = 7.1%; - DM - 20/505 = 4.0%; A1c (HPLC assay) compared to OGTT: ≥ 4.7% - Sensitivity 100%, Specificity 10.0%, CV risk ratio 1.3 ≥ 5.6% - Sensitivity 85.2%, Specificity 80.5%, CV risk ratio 1.8 ≥ 6.2% - Sensitivity 42.6%, Specificity 99.1%, CV risk ratio 2.3 FPG (mmol/L) compared to OGTT: ≥ 4.7 - Sensitivity 100%, Specificity 23.1%, CV risk ratio 1.4 ≥ 5.6 - Sensitivity 79.6%, Specificity 85.8%, CV risk ratio 1.7 ≥ 6.4 - Sensitivity 59.3%, Specificity 99.1%, CV risk ratio 2.0 A1c by HPLC compared to DCA2000 assay: good correlation - R2 0.876 | N/A | Did not find independent association between A1c and CV risk - both FPG and A1c were continuously associated with increasing CV risk.
Maynard et al, 2007^58^ Not rated | Compare the ability of Spectral measurement of AGEs (SAGE) to detect undiagnosed diabetes and IGT to FPG and A1c | Single center United States | Cross-sectional | N/A | Age > 18 with no prior diagnosis of diabetes, with 1+ ADA diabetes risk factors, and found to have abnormal glucose tolerance (IGT or diabetes) according to OGTT results | Established diabetes | Volunteers from community | Total n = 351 N with abnormal glucose tolerance = 84 | Many from high-risk ethnic group, other factors NR | SAGE FPG OGTT A1c (HPLC) | IGT - 55/351 = 15.7% Undiagnosed DM2 - 29/351 = 8.3% A1c ≥ 5.8% - Sensitivity 63.8%, Specificity 77.4% FPG ≥ 100 mg/dL - Sensitivity 58.0%, Specificity 77.4% SAGE ≥ 50 - Sensitivity 74.7%, Specificity 77.4% | Area under the curve: A1c - 79.2% Area under the curve: FPG 72.1% Area under the curve: SAGE 79.7% | Paper mainly focused on SAGE operating characteristics. A1c had slightly better sensitivity at a given specificity compared to FPG.
McAulley et al, 2004^59^ Not rated | Assess acceptability, sensitivity, specificity, effectiveness, and cost of A1c measured by rapid immunoassay (A1c analyzer: DLA 2000 ) | Single center Australia Aboriginal population 1999 | Cross-sectional | N/A | Aboriginal above age 30 and with no history of diabetes | NR | Consecutive patients January – May 1999 | N = 238 | NR | A1c by DCA 2000 (immunoassay) FPG 75gm OGTT All patients with A1c over 7% were referred for OGTT Patients with A1c 6–7% were referred for OGTT if they had risk factors for diabetes | Mean A1c: 5.4% Only 46/238 had A1c >6% and only 14 of these had OGTT performed | N/A | Poor quality study. Few people had enough data available to compare A1c and other methods of screening. Few conclusions can be drawn from the study.
Norberg et al, 2006^60^ Fair | 1) To find a simple and practical method to identify persons at high risk for future DM2; 2) Compare operating characteristics of new and old FPG criteria in screening models of future DM2 | Community/Primary care centers Sweden 1989 - 2001 | Population-based prospective cohort study matching incident diabetes cases to non-diabetic referents | 8.8 y (mean) | Incident diabetes according to WHO criteria | Unavailability of blood samples | Population-based cohort from 1 county in northern Sweden 52% of population participated in survey and outcomes tracked through local hospital and primary care centers | Total n = 28,736 Prevalent diabetes: 6088 Incident diabetes: 277 Final n = 164 cases and 304 referents (after exclusion of type 1 diabetes and persons without blood samples) | NR | 75g OGTT FPG A1c (by HPLC) | Background prevalence of DM2: 5.2% From multivariate prediction model, the following were predictors of DM2 development: A1c ≥ 4.7%*, BMI ≥ 30, IFG (by WHO criteria), and IGT (in women). Using model of IFG or IGT, BMI ≥ 27, A1c ≥ 4.7%:; - 2 of 3 criteria - PPV 17–27%, NPV 98–99.5%; - 1 of 3 criteria - PPV 8 – 9%, NPV 98–99.5%, proportion of attributable cases = 82–92%; Family History + BMI ≥ 30 + A1c ≥ 4.7%: PPV 35% | Adding OGTT identified few additional persons FPG cutoff of 5.6 mmol/l (new criteria) decreased PPV without clear increase in proportion of subjects at risk | OGTT adds little to prediction of future DM2 over and above the suggested model. The PPV were modest at best, but the high NPV may be of use in identifying patients who could potentially forego regular screening. The participation rate of only about 50% may be a limitation, though characteristics between participants and non-participants were similar.
Perry et al, 2001^52^ Not rated | To find more sensitive criteria, in a population at-risk for diabetes and with nondiagnostic FPG, to diagnose people with IGT or diabetes as diagnosed by OGTT | Part of the EDIP study Multi-center study in the United States | Cross-sectional analysis of the EDIP study, which is a randomized-controlled trial | N/A | Risk-factors for diabetes and FPG 100–144 mg/dL | Age < 24, pregnancy, recent cancer treatment, HIV or tuberculosis, recent myocardial infarction/bypass grafting/angioplasty, congestive heart failure, 3rd degree atrioventricular block, uncontrolled HTN, elevated AST/ALT, serum creatinine > 2.2 mg/dL in men and 2.1 in women, anemia, hypertriglyceridemia | Volunteers from community | N = 244 Age: 53.6 y (11.4) % male: 32 Ethnicity: Caucasian 78% African-American 18% Hispanic 2% Asian 2% | Obesity, history of gestational diabetes, family history of diabetes, patient report of “pre-diabetes” | Comparison of FPG and A1c (immunoturbidimetric immunoassay) with 2-h 75g OGTT values | 121/244 (50%) participants had diabetes as defined by 2-h OGTT values ≥ 200 mg/dL Elevated A1c (> 2 standard deviations above mean):; - Sensitivity 61% (95% CI: 51–71); FPG > 126 mg/dL:; - Sensitivity 45% (35–55); Combination of FPG > 126 mg/dL and elevated A1c:; - Sensitivity 76% (66–86); Two FPG measures > 126 mg/dL:; - Sensitivity 42% (32–52) | N/A | Specificities (or data to derive them) are not reported. Of note, 50% of those with diabetes risk factors and FPG in the IFG range had diabetes by 2-h OGTT.
Peters et al, 1996^61^ Fair | To determine if A1c could be used in place of OGTT to diagnose diabetes | Multiple studies in systematic review Search 1966 - 1994 | Systematic review | N/A | Reports in which A1c were measured concurrently with and compared to OGTT | Study populations who had conditions that would alter glucose tolerance (pregnancy, cystic fibrosis) | MEDLINE search of English language abstracts, reference list searches and expert files | Total number studies = 34 18/34 studies provided individual level data giving sample of 11,276 subjects (83% of all subjects in literature) Final analysis used data from 10 studies, in which an A1c assay was used (the other glycosylated hemoglobin assays had greater variance): 8984 subjects | NR | FPG A1c (method not defined) 75g OGTT | Sensitivity/specificity/predictive value positive of A1c in detecting OGTT > 200 mg/dL in hypothetical population with diabetes prevalence of 6%: A1c + 2 SDs 66%/98%/63% A1c + 3 SDs 48%/100%/90% In normoglycemic patients, 69.1% had A1c < 5.5%, 90.9% had A1c < 6.0% Sensitivity/Specificity for clearly diabetic and clearly normal cases: A1c 5.5% - Sensitivity 100.0%, Specificity 69.1% A1c 7.0% - Sensitivity 99.6%, Specificity 99.9% Using A1c cutoff of 7%, false positive rate of only 0.1% (normal glucose tolerance), but 58% false negative rate | Prevalence of diabetes: 6.5% Mean A1c (SD) in patients with normoglycemia (FPG < 115 mg/dL) and OGTT < 140 mg/dL: 5.2 (0.6) In patients with normoglycemia and OGTT > 200 mg/dL: 5.8 (1.0) | Authors argue that, in a population at high-risk for diabetes, A1c > 7% is an appropriate cut-off. It will miss many patients with abnormal OGTT, but since A1c is used to guide clinical treatment, the cut-point of 7% would identify the population most likely to require pharmacologic intervention, while others would benefit from lifestyle modification.
Rohlfing et al, 2000^62^ Not rated | To determine the sensitivity and specificity of A1c in diagnosing diabetes as defined by FPG ≥ 126 mg/dL | Multicenter/Population based - NHANES III United States 1988-1994 | Cross-sectional | N/A | NHANES participants with fasting plasma glucose age ≥ 20 y | Nonfasting status, prevalent diabetes by patient report | Population-based survey with oversampling of non-Hispanic blacks and Mexican-Americans | Total n = 6559 Non-Hispanic white 2789 Non-Hispanic black 1752 Mexican-American 1751 Other 267 | NR | FPG A1c (by HPLC) 2871/6559 underwent OGTT | Sensitivity%/Specificity% at different A1c cutoffs (FPG ≥ 126 mg/dL is gold standard): A1c 5.6 (1SD above mean) - 83.4/84.4 6.1 (2 SD above mean) - 63.2/97.4 (non-Hispanic black: 75.8/93.0, Mexican-American: 83.6/97.8) 6.5 (3 SD above mean) - 42.8/99.6 7.0 (4 SD above mean) - 28.3/99.9 | Prevalence of undiagnosed diabetes (FPG ≥ 126 mg/dL): 4.0% Mean A1c (SD) for normoglycemic participants: 5.17 (0.45) | A1c had higher sensitivity in high-risk ethnic groups. The use of FPG as the gold standard in this case is of some concern given that the sensitivity of this test has been called into question when compared to OGTT results.
Shibata et al, 2005^63^ Not rated | To compare A1c and FPG in their ability to detect post-prandial hyperglycemia | Single center, primary care Japan 2001-2002 | Cross-sectional | N/A | All individuals undergoing routine medical checkup at study center Only persons with discordant FPG and A1c measures underwent OGTT testing and were included in analysis FPG cutoff - 7.0 mmol/L A1c cutoff - 6.5% | Prevalent diabetes (those on diabetes treatment) | Population- based, consecutive enrollment | Total n = 6184 Those included in analysis including OGTT n = 104 | Mean BMI: Men 22.9 (2.8) Women 22.1 (2.9) | FPG A1c (by HPLC) 75g OGTT (for those with discordant FPG and A1c results) | Participants with post-prandial hyperglycemia - 77 54/77 had FPG > 7.0 mmol/L, but A1c < 6.5% true-positive odds ratio of A1c to FPG was 0.43 (0.26–0.69) | Reducing A1c cutoff improved detection of persons with post-prandial hyperglycemia. False-positive OR A1c/FPG 0.40 (0.13 – 1.27), p = 0.090 | Cutoffs chosen were fairly high. Clearly, lowering A1c cutoff will improve sensitivity. Low rate of false positives in study limit interpretation of comparative false positive rates between both tests.
Simmons et al, 2005^64^ Not rated | To compare A1c, FPG and risk factors in their ability to detect abnormal glucose tolerance | Community-based New Zealand | Cross-sectional | N/A | Persons without known diabetes | Known diabetes | Population-based sampling within European, Maori, and Pacific Islander areas, stratified by age and ethnicity | Total n screened for diabetes = 1899 OGTT performed, n = 534 (67.9% of those invited) | Among those with new diabetes: Mean age 55 y (9) Obesity 79.1% Family history 33.7% HTN treatment 18.5% | All patients - random glucose Those with random glucose ≥ 117 mg/dL within 2 h of a meal, or ≥ 108 mg/dL 2 h after a meal, were invited for OGTT at which time FPG and A1c (immunoturbidmetric assay) was performed. A random sample (28%) of those with normoglycemia at initial screening were also selected for OGTT. | Sensitivity = specificity for diagnosis of diabetes at following cutpoints: A1c 5.6% Random glucose 104 mg/dL Fasting glucose 104 mg/dL Number of risk factors 1 ROC at these cutpoints: A1c 0.86 (0.82 – 0.90) Random glucose 0.75 (0.69 – 0.80) Fasting glucose 0.92 (0.89 – 0.95)* Number of risk factors 0.60 (0.55 – 0.66) * p < 0.0083 vs A1c | ROC improved for all measures in higher risk ethnic subgroups (Pacific Islander > Maori > European) | Gold standard of OGTT applied to less than half original sample. Data presented cannot be used to calculate sensitivity and specificity.
Wang et al, 2002^65^ Not rated | To find the optimal combination of A1c and FPG for detecting diabetes as defined by 2h OGTT results in participants with IFG | Multiple communities United States | Cross-sectional and prospective cohort (though essentially was 2 cross-sectional studies) | 4 y | Age 45–74 y American Indian A1c, FPG, and OGTT measures available | Prior diabetes, oral hypoglycemic or insulin use, renal dialysis, history of kidney transplant | Population-based recruitment | Baseline exam n = 2389 Second exam n = 1644 | NR | FPG A1c (by HPLC) 75g OGTT | FPG ≥ 126 mg/dL sensitivity 44.8 – 62.8% To detect new diabetes amongst IFG participants: - FPG + A1c had largest area under ROC curve (0.72 vs 0.64 with FPG alone, p < 0.001) Optimal critical line: sensitivity 58.8%, specificity 76.8% for following situations - A1c 6.5 when FPG = 110 A1c 4.6 when FPG = 126 FPG 162.9 when A1c 0 | Approximately 20% (19.3% baseline and 22.9% at second test) of IFG participants had 2 h OGTT > 200mg/dL (false negatives)

* A1c in this study was calibrated according to Swedish MonoS standard and values are approx 1% lower than DCCT calibration

Abbreviations: ADA, American Diabetes Association; ALT, Alanine AminoTransferase; AST, Aspartate AminoTransferase; BMI, body mass index; CV, cardiovascular; DCCT, Diabetes Control and Complications Trial; DM, diabetes; DM2, type 2 diabetes; EDIP, Early Diabetes Intervention Program; FPG, fasting plasma glucose; h, hour; HIV, Human Immunodeficiency Virus; HPLC, high-performance liquid chromatography; HTN, hypertension; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; LR, likelihood ratio; N, number of participants in study; N/A, not applicable; NHANES, National Health and Nutrition Examination Survey; NPV, negative predictive value; NR, not reported; OGTT, oral glucose tolerance test; PPV, positive predictive value; ROC, receiver operating curve; SAGE, Spectroscopic measurement of advanced glycation end products; SD, standard deviation; SQ, subsidiary question; WHO, World Health Organization; y, years.

Table B3 Screening Evidence Table (KQ1)

Author, Year Quality rating | Study objective | Country; Setting | Study design | Length of follow-up | Inclusion criteria | Outcomes | Adherence Withdrawals (%) | Conclusions | Comments
Agarwal et al, 2006^86^ Poor | To compare the occurrence of diabetic retinopathy in targeted screening diabetic patients with newly-diagnosed diabetic patients in general practice | India, rural communities and urban clinics | Cross-sectional with comparison group | NA | Group I (targeted diabetes screening): N=173; >30 years who attended rural or urban diabetes screening clinics, who screened (+) for DM2, and who then reported for eye examination Group II (newly diagnosed in general practice): N=128; diagnosed with DM in last 1 month and reported for eye examination | Diagnosis of diabetic retinopathy: Group I: 6.4% Group II: 11.7% (between-group p-value =0.22) | NA | Diabetic retinopathy was found in both screen-detected and newly-diagnosed in general practice, with no significant difference in prevalence between the 2 groups. | Group I: only 15% reported for eye examination; 100% for Group II Study performed in urban and rural India; may not be applicable to United States populations
Olafsdottir et al, 2007^85^ Fair | To establish a gold standard for prevention of blindness in DM2 populations by comparing a DM-screened population to a nonDM population for visual acuity | Sweden, using national register for diabetes and control group from population register | Cohort with comparison group | NA | All inhabitants of Laxa with DM2; this community has a systematic screening program Age- and sex-matched controls from national register | No significant difference in visual acuity between DM and control groups; except more control subjects had acuity ≥ 1.0 (p=0.027) | NA | In a population that had been screened for DM2 and for diabetic eye disease, the prevalence of visual impairment and blindness was no greater than in the control group | DM group was considered ‘screened’ but likely some were detected clinically
Schellhase et al, 2003^84^ Good | To determine if glucose screening reduces the risk of diabetic complications | United States, HMO | Case control | 10 y | Cases: diagnosed with DM2 after age 3y, had developed 1+ microvascular complications attributable to DM2, enrolled in health plan for 10+y Control subjects: randomly selected and matched to cases Exclusion criteria NR | Number of screening BG tests over 10y period: cases 6.3, controls 4.8 88% of testing was random BG; 81% of BG tests occurred without symptoms (i.e. were screened) OR for BG screening at least once vs no screening: (adjusted) 0.87 (0.38–1.98) | NA | Persons who had 1+ screening events in the 10y period had a 13% decreased the risk of developing severe microvascular complications from DM2 after adjusting for multiple confounding factors | The study included persons tested without symptoms of diabetes, persons with HTN, or other incidental screening with other chronic illnesses that could include CVD

Abbreviations: BG, blood glucose; CVD, cardiovascular disease; DM, diabetes; DM2, type 2 diabetes; HMO, Health Maintenance Organization; HTN, hypertension; N, number of participants, NA, not applicable; NR, not reported; OR, odds ratio; y, years.

Table B4 Evidence Table of Ongoing Trials

Trial; Author, Year | Study aims | Country | Treatment groups sample size | Length of follow-up | Inclusion criteria | Exclusion criteria | Participant selection | Diabetes Treatment | Intervention | Primary endpoint (s)
KQ1
ADDITION Study by Lauritzen et al, 2000^88^ (Anglo-Danish Dutch Study of Intensive Treatment in People with Screen Detected Diabetes in Primary Care) | 1) Evaluate whether screening for prevalent undiagnosed diabetes is feasible; 2) Evaluate whether subsequent optimized intensive treatment and associated risk is feasible and beneficial | Multi-center: Denmark, England, Netherlands | Goal = 1,500 conventional treatment vs. 1,500 intensive treatment | 5 y | [underlined: Screening study]: Ages 40–69 Without known diabetes [underlined: Treatment study]: Newly diagnosed DM2 (FPG ≥ 108 or 2-h > 198 mg/dl [≥ 6.0 or 2-h OGTT >11.0 mmol/l] | [underlined: Screening study]: Previously diagnosed diabetes Treated with blood glucose lowering agents [underlined: Treatment study]: IGT and/or IFG, contraindications or intolerance to study medications, alcoholism, drug abuse, psychosis or emotional problems, malignant disease with a poor prognosis, pregnant or lactating | Population-based screening recruitment in outpatient clinics | Stepwise increases in drug treatment for hyperglycemia (drugs not specified) | 2 phases: [underlined: Screening study to assess 3 approaches to identifying undiagnosed diabetes]: Denmark: questionnaire to assess risk factors sent to patients, encouraging those with high risk to contact physician for screening test; England: validated risk score generated from computerized medical records used to determine high risk; Netherlands: all age-qualified patients will be offered screening test. Random capillary blood glucose measured using HemoCue. If ≥ 99 mg/dl (5.5 mmol/l), then fasting glucose test and OGTT [underlined: Treatment study]: Conventional care (national guidelines) vs. intensive, multifactor care (lifestyle advice, aspirin and ACE-inhibitors, protocol-driven tight control of blood glucose, blood pressure, and cholesterol, lifestyle changes) Further randomization will allocate some patients to country-specific interventions with emphasis on adherence to lifestyle changes and medication. | [underlined: Primary]: All cause mortality, cardiovascular mortality/morbidity, nonfatal myocardial infarction, nonfatal stroke, amputations, hospitalization for angina or congestive heart failure, coronary revascularization, or peripheral revascularization [underlined: Secondary]: Renal impairment, blindness, diabetic ulcers, retinopathy, reduced visual acuity, macular edema, health status and utility, quality of life, satisfaction, costs [underlined: Intermediate]: Smoking status, physical activity, lipid levels, blood pressure, microalbuminuria, BMI, etc [underlined: Process-of-care]: Visits to outpatient clinics, outpatient admissions
KQ2
ACCORD Trial^102^ (Action to Control Cardiovascular Risk in Diabetes Trial) Sponsored by National Heart, Lung, and Blood Institute (NHLBI) | 1) Using intensive glycemic control, intensive blood pressure control, and intensive lipid management to prevent major cardiovascular events in adults with DM2 | Multi-center: Canada and United States (77 clinics) | Goal: 10,000 (5,000 I; 5,000 C) | 4–8 y | DM2 diagnosis for >3 months Aged 40 y or older: history of CVD* Aged 55 y or older: a history of CVD or at high risk for experiencing a CVD event *Heart attack, stroke, history of coronary revascularization, history of peripheral or carotid revascularization, or demonstrated angina | Age <40 or >79 Hypoglycemic coma/seizure within last 12 months Hypoglycemia requiring 3rd party assistance in last 3 months with concomitant glucose < 60 mg/dl (3.3 mmol/l) History consistent with type 1 diabetes Unwilling to do frequent capillary blood glucose self-monitoring or unwilling to inject insulin several times a day BMI > 45 kg/m2 Serum Creatinine > 1.5 mg/dl (132.6 umol/l) obtained within the previous 2 months Transaminase >2 times upper limit of normal or active liver disease ongoing medical therapy with known adverse interactions with the glycemic interventions (e.g., corticosteroids, protease inhibitors) Cardiovascular event or procedure (as defined for study entry) or hospitalization for unstable angina within last 3 months Current symptomatic heart failure, history of NYHA Class III or IV congestive heart failure at any time, or ejection fraction (by any method) < 25% A medical condition likely to limit survival to less than 3 years or a malignancy other than non-melanoma skin cancer within the last 2 y Any factors likely to limit adherence to interventions Failure to obtain informed consent from participant Currently participating in another clinical trial Any organ transplant Weight loss > 10% in last 6 months Pregnancy, currently trying to become pregnant, or of child-bearing potential and not practicing birth control Participants with recurrent requirements for phlebotomy or transfusion of red blood cells | Population-based screening recruitment in outpatient clinics | Hypoglycemic agents, hydroxymethylglutaryl-CoA reductase inhibitors, and antihypertensive agents | All participants receive drug treatment to lower blood glucose to either current guideline targets, or more aggressive targets (N=10,000) Depending on blood pressure and cholesterol levels, participants are further assigned to receive high blood pressure or high blood fats (cholesterol and triglycerides) drug treatment, at either current guideline targets, or more aggressive targets | [underlined: Primary:] First occurrence of a major CVD event, specifically nonfatal heart attack, nonfatal stroke, or cardiovascular death
KQ3
CANOE Trial Zinman et al, 2007^166,^ 2006^167^ (Preventing type 2 diabetes using combination therapy: design and methods of the CAnadian Normoglycaemia Outcomes Evaluation (CANOE) Trial) | 1) To determine whether treatment with metformin plus rosiglitazone, in addition to a healthy living lifestyle programme in people with IGT, will prevent development of DM2; 2) To determine whether this treatment approach will improve cardiovascular risk factors associated with IGT | Canada, multicenter | Goal = 200 total (100 I; 100 C) | 3–5 y | IGT diagnosis Ages 30–75 y (18–75 for Native Canadians) Resident of Ontario | Current use of metformin or rosiglitazone Prior use of medication to treat DM2 (except gestational DM2) Use of drugs known to exacerbate glucose tolerance History of DM2 (except gestational DM2) Clinically significant hepatic disease, LFTs > 2.5 times the upper limit of normal, or renal dysfunction Active liver disease including jaundice, chronic hepatitis or previous liver transplant Anemia Any major illness with life expectancy <5 y or that may interfere with study participation Involvement in another drug study History of congestive heart failure or current congestive heart failure Excessive alcohol consumption Pregnancy or unwilling to use reliable contraception Inability to communicate in English language | Recruitment detail NR | Pharmacotherapy and healthy lifestyle counseling | Metformin (500 mg) plus rosiglitazone (2 mg) administered as one capsule twice daily, will be compared to matched placebo. In addition, a healthy living lifestyle programme based on latest national evidence-based guidelines recommended by Canadian Diabetes Association (includes discussions of diabetes prevention, physical activity, nutrition, weight loss, and maintenance of a healthier lifestyle), will occur in both treatment and control groups | [underlined: Primary]: Development of new-onset diabetes [underlined: Secondary]: Longitudinal changes in blood pressure, microalbuminuria, lipids, beta cell function, insulin resistance, inflammatory marker C-reactive protein, homocysteine, adiponectin, insulin and proinsulin, & assessment of lifestyle intervention
FIN-D2D Study by Saaristo et al, 2007^168^ (National type 2 diabetes prevention programme in Finland) | 1) To reduce the incidence and prevalence of DM2 and prevalence of cardiovascular risk factor levels using lifestyle interventions; 2) To identify individuals who are unaware of their DM2; 3) To generate regional and local models and programs to prevent DM2; 4) To evaluate effectiveness, feasibility, and costs of the programme; 5) To increase the awareness of DM2 and it's risk factors | Finland (5 hospital districts) | Potential population of 1.5 million | 4 y | Population-wide | Population-wide | Population-based screening recruitment in hospitals | Pharmacotherapy, tailored dietary and exercise goals, & group guidance maintenance sessions. | 3 Strategies: [underlined: High-risk identification strategy]: Uses “FINDRISC” the Finnish Diabetes Risk Score calculator to determine risk level. Scores < 7 are not at risk & do not receive preventive measures. Scores 7–14 receive written info on preventive measures. Scores ≥ 15 receive OGTT & appropriate treatment measures (see next strategy for details). [underlined: Early diagnosis and management]: To bring those newly diagnosed with DM2, using the FINDRISC score calculator, into immediate treatment, with the goal of preventing diabetic complications. Treatment includes pharmacotherapy, tailored dietary and exercise goals, & group guidance maintenance sessions. [underlined: Population strategy]: Media communication, training, life-style counseling (physical and nutrition); an extensive network to support these activities will be used. All will be evaluated (feasibility, cost effectiveness, effects) by Finnish National Public Health Institute. | DM2 diagnosis, incidence rates, feasibility, cost effectiveness, & effects of program

Abbreviations: ACE, angiotensin-converting enzyme; BMI, body mass index; C, control (placebo) group; CVD, cardiovascular disease; DM2, type 2 diabetes mellitus; FPG, fasting plasma glucose; h, hour; I, intervention group; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; KQ, key question; LFT, liver function test; N, number of participants in study; NYHA, New York Heart Association; OGTT, oral glucose tolerance test; y, years.

Table B5 Studies Modeling Screening for Type 2 Diabetes (KQ1)

Author, Year (in date order) | Objective | Type of screening; Perspective | Type of model | Population; Country | Included costs | Discount rate | Base case assumptions | Time horizon | Data sources | Sensitivity analyses | Intervention | Outcomes | Conclusions | Quality assessment
CDC Diabetes Cost-effectiveness Group, 1998^90^ | To estimate the cost-effectiveness of early detection and treatment of DM2 compared to current practice (clinical diagnosis) | One-time opportunistic screening during regular physician visit; Single-payer health care system | Monte Carlo Computer simulation | Hypothetical cohort of 10,000 persons with newly-diagnosed DM2 from the general United States population >25 y | Direct costs: screening, diagnostic tests, treatment | 3%; costs expressed in in 1995 US$ | Screening reduces the prediagnosis interval by 5y (from 10.5y to 5.5y); prevalence of undiagnosed DM2 is 3.2% (varied by age, sex, race per NHANES data); glycemic control relates to microvascular (but not macrovascular) complications | Lifetime or age 95y | Various epidemiologic data and treatment trials, including UKPDS | A1c as screening test (decreases $/QALY), sensitivity and specificity of the screening test, prediagnosis interval (shorter interval, increased $/QALY); prevalence of DM2 (increased prevalence produces decreased $/QALY); intensive treatment for glycemic control (increases $/QALY) | One-time screening intervention with FPG, OGTT for confirmation of positives | Incremental cost of screening is $236,449 per life-year gained and $56,649/QALY; more CE among younger persons (as more complication-free years and CHD not modeled) and among African Americans | Screening may produce cost/QALY within range of currently acceptable, especially for younger persons and African Americans | Limited sensitivity analyses CVD not modeled; screening and treatment only influence microvascular complications No information on how QALYs determined No mention harms of screening Lack of transparency of details of model Used data from DM1 for microvascular disease risk reduction with treatment
Goyder et al, 2000^91^ | To determine whether the potential benefits of screening are likely to outweigh the potential harms; explore which variables influence the balance of benefit and harm from screening | Universal screening Perspective: NA (does not involve cost) | Decision analysis | Cohort of 10,000, mainly Caucasian 45–60 y United Kingdom | NA | 3% annual rate for QALYs | Positive screening test is followed by a ‘gold standard’ diagnostic test before treatment; harms of negative or false positive test negligible; reduction in QALYs associated with early diagnosis proportional to time from diagnosis to when clinical diagnosis would have been made; optimal treatment is available from the time of clinical diagnosis; diabetes will be diagnosed at the time of or before symptomatic complications present; baseline risk of CVD complications is similar in diagnosed and undiagnosed DM2; sensitivity of screening test 90%; treatment for 1 CVD risk factor leads to a risk reduction of 1/3; extent to which BG is reduced during early treatment is 50% of that achieved after clinical diagnosis; clinical diagnosis 6y after onset | Lifetime | UKPDS and other sources | One-way sensitivity analysis: benefits no longer outweigh harms if: baseline annual risk of CVD is <0.8%; RR CVD is reduced by <13% during earlier treatment; discount rate >7% | Various interventions for hyperglycemia, HTN, lipids | QALYs gained by screening 10,000 persons: 10.5: 4 from postponed microvascular complications, 17 from avoided CVD complications and 11 lost from early diagnosis | The immediate disutility of earlier diagnosis and additional treatment may be greater than the potential long-term benefit from postponing microvascular complications; screening decisions should be based largely on CVD risk and interventions to reduce that risk | Used data from DM1 for microvascular disease risk reduction with treatment Details and assumptions of the model not clear
Hofer et al, 2000^92^ | To define the relative benefits of screening for DM2 | Universal and targeted screening | Markov model | Cohort of recent onset DM2 (<5y) | NA | NA | Onset of DM2 prior to diagnosis 5y; A1c increases at constant rate of 0.2%/y in diagnosed and undiagnosed; one-time drop in A1c of 10% at time of start of treatment; undiagnosed were diagnosed at rate of 5%/y up to A1c of 13%, beyond which were diagnosed at 50%/y | Lifetime | NHANES III, UKPDS for progression of glycemia, DCCT for benefits of tight glycemia control on ESRD and retinopathy | Duration undiagnosed DM2, treatment effect, rate of case finding | Perfect screening: diagnosis at time of onset Improved treatment: A1c ≤ 9% | Number blind/1000 persons with diabetes, age 40y, A1c 12%: Case finding: 141 Perfect screening: 133 Case finding, A1c <9%: 90 Screening, A1c <9%: 41 Screening produces 7% of the benefit of reduced number of cases of blindness; improved treatment alone is 65% Targeted screening (with 2+ risk factors): achieved 75% of the benefits of universal screening | Largest impact of improving treatment and diagnosis is in younger person with high A1c; focus should first be on improving glycemic control of known diabetics with high A1c; if that is achieved then the benefits of screening will become more important | Does not include benefits of HTN and lipid treatment Only examines microvascular complications
Chen et al, 2001^43^ | To evaluate the efficacy of screening for DM2 compared to no screening; to evaluate the inter-screening interval and age of start of screening on health outcomes; to examine the CE of screening | Mass screening Single payer health plan | Markov process Monte Carlo simulation | Over age 30y, general community population; cohort of 30,000 Taiwan | Direct costs including costs of screening, treatment; indirect costs not included; costs in US$ | 3% annual rate | Early diagnosis and treatment can control BG and reduce micro- and macrovascular complications | 30y or until death | Taiwan demographic data; transition parameters from a variety of sources including Framingham Heart Study, UKPDS | None | Screening program lasts for 10y; standard treatments such as that of UKPDS for persons with DM2 | Cumulative incidence rates of microvascular complications: 2y screening: Blindness: 3.06%; ESRD: 0.19%; LEA: 0.97% 5y screening: Blindness 3.13%; ESRD: 0.19%; LEA: 0.99% Control (no screening): Blindness: 4.3%; ESRD: 0.54%; LEA: 1.43% NSD between 2 and 5-y screening Cost-effectiveness (cost/QALY): 2-y: $17,833; 5-y: $10,531 Incremental cost/QALY: lowest 40–49y group ($9,193), highest 70y+ ($36,467) | Mass screening is CE compared to opportunistic screening Costs incurred with mass screenings are offset with life-years gained Mass screening for DM2 is relatively CE compared to other screening interventions (e.g. cervical cancer or HTN) Screening is more CE in younger than older patients | Lack of transparency for assumptions, data synthesis No sensitivity analyses Do not include CVD risk reduction in model Do not include adverse effects of screening
Hoerger et al, 2004^87^ | To estimate the incremental cost-effectiveness of two diabetes screening strategies: targeted to people with HTN and universal screening | One-time opportunistic screening during regular physician visit Targeted to persons with HTN Single payer health care system Not an economic study | Markov model with cohort simulation; is an update of the CDC model (CDC Diabetes Group 2002); considers 5 complications: nephropathy, neuropathy, retinopathy, coronary heart disease, stroke | General primary care population based on census United States | Direct medical costs: screening, diagnostic tests, treatment | 3% annual rate | In the absence of screening, DM2 diagnosed on average 10y after onset; one-time screening makes diagnosis 5y after onset; with targeted screening only people with HTN are screened; with universal screening all persons are screened; 47% of people age 45–74 have HTN; intensive BP control adds as much benefit to DM2 as to prediabetes; RRR CHD events 51%; initially screening by capillary blood glucose with (+) followed by FPG which is repeated if (+); assume 100% sensitivity and specificity of FPG; intensive glycemic control after diagnosis | Lifetime; Cost/QALY | UKPDS, HOT trial, US Census data | One-way sensitivity analysis for age 55y, examining 129 critical parameters: findings were robust to treatment costs, screening costs, screening lead time, effect of HTN therapy | Treatment of HTN to goal of DBP 80mm Hg (HOT); intensive glycemic control for diagnosed DM2 (UKPDS) | Results per true diabetes case, compared to no screening, with intensive glycemic control and intensified HTN control after diagnosis: Targeted screening for people with HTN only: QALYs gained per person screened (cost/QALY) ranged from 0.08 with screening at 35y ($87,096), to 0.23 for screening at 65y ($31,228) Universal screening: QALYs gained per person screened (cost/QALY) ranged from 0.05 with screening at 35y ($126,238), to 0.11 for screening at 75y ($48,146) Universal vs. targeted screening, incremental cost/QALY: 35y: $143,830; 75y $443,433 Universal vs targeted screening: Relative to targeted screening, universal screening has high cost-effectiveness ratios which increase with age | Targeted screening to persons with HTN is more CE than universal screening at every age when each alternative is compared to no screening Targeted and universal screening are more CE when take into account reduction in CHD events from earlier treatment of HTN for ages 55, 65, 75 than for 35 and 45y The most CE approach to one-time screening: target people with HTN 55 to 75y Benefit of screening comes mainly from reducing CHD events by control of HTN rather than from reducing microvascular complications | Did not include adverse effects of screening Thorough sensitivity analyses Includes submodels for CVD and stroke Includes benefits for tight BP control, but not other CVD risk reduction interventions Assumes 100% uptake and follow-up
Glumer et al, 2006^93^ | To describe the uncertainties in estimates of the cost-effectiveness of screening for DM2 where the outcome is CHD risk | NR; appears to be health care system perspective | Population-based simulation model | Based on community sample age 30–60y Denmark | Screening and treatment for DM2 and complications | 0 | Overall compliance rates from 30 to 75%; risk prediction for CHD events from the UKPDS; risk reductions in screened populations same as those in RCTs of various diabetes-related treatments; examine 2 extreme scenarios for assumption on how single CVD risk factor reductions combine when more than 1 factor is treated:combined therapy only as effective as most effective single agent and where risk reductions combine in a multiplicative manner | 5y | UKPDS, Danish Inter99 study (population data), other RCTs | Model not sensitive to decisions about which groups to screen nor to costs of screening or treatment; model strongly affected by assumptions about how treatments combine to reduce risk | Optimal treatment of screen-detected persons; details not provided | Least conservative model (low costs and multiplicative risk reduction for combined treatments): CE ratio: 23,000 to 82,000 pounds; major contributors to uncertainty: risk reduction for hypertension treatment and UKPDS risk model intercept | There is considerable uncertainty about the cost-effectiveness of screening for DM2; the most important parameter is the effect of treatment and whether risk reductions are multiplicative or additive | Model combines effects of treatment of hyperglycemia, hypertension and dyslipidemia Time horizon 5y
Waugh et al, 2007^13^ Health Technology Assessment | To quantify the trade-off between the costs and benefits of screening and early treatment | Population screening National Health Service | Markov model | United Kingdom general population 40–70 y | Screening and treatment for DM2 and complications | 3.5% for costs and benefits | Onset of DM2 A1c is 5.9%; preclinical phase 11y; prevalence of undiagnosed DM2 1.4 to 4.4%; 14% CHD risk reduction per 1% fall in A1c (per UKPDS); prevalence of diagnosed CVD negligible (would have been screened) | 40y | UKPDS CVD risk engine; other sources | Rate of A1c progression, risk reduction with glycemic control; various treatment regimes; costs | Screening with A1c followed by OGTT if A1c > 5.7% Various interventions for hyperglycemia, HTN, lipids | Cost reduction and QALYs gained from fewer CVD events, largely from statin treatment, as well as fewer microvascular complications Incremental cost per QALY £2,266 for base case (40–70y) CE greatest for 60–69y: cost per QALY £1,152 | Screening is relatively cost effective for persons 40–70y of age; more cost-effective for the older group and for persons with hypertension or obesity | Includes macro and microvascular complications; relatively simple model

Abbreviations: BG, blood glucose; BP, blood pressure; CDC, Center for Disease Control; CE, cost effectiveness; CHD, coronary heart disease; CVD, cardiovascular disease; DBP, diastolic blood pressure; DCCT, Diabetes Control and Complications Trial; DM1, type 1 diabetes; DM2, type 2 diabetes; ESRD, end-stage renal disease; FPG, fasting plasma glucose; HOT, Hypertension Optimal Trial; HTN, hypertension; LEA, lower extremity amputation; NA, Not applicable; NHANES, National Health and Nutrition Examination Survey; NR, not reported; NSD, no significant difference; OGTT, oral glucose tolerance test; QALY, quality-adjusted life year; RCT, randomized controlled trial; RR, relative risk; RRR, relative risk reduction; UKPDS, United Kingdom Prospective Diabetes Study; US, United States; y, year.

Table B6 Diabetes vs. Nondiabetes Evidence Table of Trials (KQ2)

Study; Author, year | Topic of study | Country/ Setting/ Year(s) of study | Treatment groups Sample size | Length of follow-up | Inclusion criteria | Exclusion criteria | Duration of DM2 | Participant selection | Population | Diabetes diagnosis | Diabetes treatment | Existing vascular disease | FBG (mg/dl) A1c (%) | Lipids (mg/dl) | Blood pressure (mm Hg) | Other CVD risk factors | Intervention | Primary endpoint(s) | Outcomes | Outcomes, continued | Adherence withdrawals (%) | Adverse Events
ALLHAT (Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial) Whelton et al, 2005^103^ ALLHAT Officers, 2002^115^ Barzilay et al, 2001^231^ | BP treatment (pharmacology) | United States, Canada, Puerto Rico, Virgin Islands Primary care clinics, hypertension clinics (623 centers) February 1994 – March 2002 | Overall study: Total n = 42,418 Chlorthalidone = 15,255 Amlodipine = 9048 Lisinopril = 9054 Doxazosin = 9061 (this arm discontinued early because RR of heart failure high) Treatment assignment for DM subgroup (only from Barzilay 2001) DM total n = 15,297 (36%) DM on chlorthalidone = 5535 DM on amlodipine = 3327 DM on lisinopril = 3217 DM subgroup analysis (excluding doxazosin arm): Total n = 31,512 DM = 13,101 IFG = 1399 NG = 17,012 | 4.9 y (mean) | Age ≥ 55; - Stage 1 or 2 HTN; - 1 additional CHD risk factor or past history of atherosclerotic CVD | History of CHF and/or LVEF < 35% Symptomatic MI, angina, or CV event within last 6 months Serum Cr ≥ 2 HTN resistant to > two drugs BP > 180/110 on two separate readings Requirement for study drugs for non-HTN indications | Unknown | Provider selected, most identified by chart review | DM subgroup info: %Black:; - DM 39%; - IFG 30%; - NG 32%; Age:; - DM 67(7); - IFG 67(8); - NG 67(8); % male:; - DM 51%; - IFG 62%; - NG 55%; Overall group: Race; - White 47%; - Black 32%; - White Hispanic 13%; - Black Hispanic 3%; - Other 5%; Age: mean (SD) (y); - 66.9(7.7); % male; - 53% | DM subgroup analysis: Fasting BS ≥ 126, with DM agents in last 2y, nonfasting baseline BS ≥ 200 IFG 110–125 and no history of DM NG - no history of DM and baseline BS < 110 | Unknown | DM subgroup analysis: Atherosclerotic CVD; - DM 36%; - IFG 63%; - NG 62%; LVH; - DM 15%; - IFG 26%; - NG 27%; Baseline history of CHD; - DM 20%; - IFG 31%; - NG 17% | NR | DM subgroup from Barzilay 2001: TC; - 203–227; LDL; - 128–150 (unavailable for overall group); HDL; - 39–53 (unavailable for overall group); DM subgroup analysis: History of HDL < 35; - DM 9%; - IFG 18%; - NG 13% | SBP/DBP; - DM 147/83 (15/10); - IFG 147/85 (16/10); - NG 146/85 (16/10); % on antiHTN meds; - DM 92%; - IFG 89%; - NG 89%; Baseline values by intervention category is not available for diabetes subgroup | Smoking:; - DM 13%; - IFG 24%; - NG 28%; BMI mean (SD):; - DM 31 (6); - IFG 31 (6); - NG 29 (6); % taking aspirin:; - DM 34%; - IFG 38%; - NG 38% | Trial is in two parts: HTN trial is comparative effectiveness: Step 1 - study drug; - chlorthalidone vs lisinopril, amlodipine, (or doxazosin); - the doxazosin arm stopped prematurely; Step 2 - addition of open-label atenolol, clonidine, or reserpine Step 3 - addition of hydralazine (or other study drugs) | Primary: fatal CHD or nonfatal myocardial infarction Secondary: all-cause mortality, fatal and nonfatal stroke, combined CHD (primary outcome, coronary revascularization, or hospitalized angina), and combined cardiovascular disease (combined CHD, stroke, other treated angina, heart failure, peripheral arterial disease), end-stage renal disease, and any of the above individually | Comparisons listed as RR (p-value) Only significant comparisons listed - all others are nonsignificant. Amlodipine/chlorthalidone:; - higher risk of heart failure in DM group 1.39 (<.001) and NG group 1.30 (.001), and marginally increased risk in IFG group 1.66 (.06); - higher risk of CHD in IFG group 1.73 (.02) | Lisinopril/chlorthalidone:; - marginally higher risk of heart failure in DM group 1.15 (.06) and significantly higher risk in the NG group 1.19 (.03); - higher risk of stroke in NG group 1.31 (.003); - higher risk of combined CVD in NG group 1.13 (.001) | After 5y, adherence to lisinopril compared with chlorthalidone was worse in all 3 glycemic strata % dropping assigned study medication (lisinopril vs chlorthalidone):; - DM 17% vs 14%; - IFG 16% vs 9%; - NG 16% vs 12%; Details about reasons for withdrawal NR | Overall group data (NR for DM subgroup): Angioedema - chlorthalidone (0.1%) Amlodipine (<.01%) Lisinopril (0.4%) One death from angioedema in the lisinopril group No differences in gastrointestinal bleed rates amongst groups
ALLHAT-LLA (Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial - Lipid Lowering Arm) ALLHAT Officers, 2002^115^ | Lipid treatment (pharmacology) | See above 513 eligible clinics | Total n = 10,355 Pravastatin = 5170 Usual care = 5185 The only DM specific information available is from Barzilay 2001 paper. Total n (including doxazosin group) = 3635 Pravastatin = 1854 Usual care = 1871 | 4.8 y (mean) | Enrollment in HTN trial LDL 120–189 mg/dL (or 100–129 mg/dL if known CHD), and TG ≤ 350 mg/dL | Current lipid-lowering treatment Secondary causes of hyperlipidemia ALT > 2 ULN Enrollment “discouraged” for those whose physicians recommended cholesterol lowering treatment | Unknown | Provider selected, most identified by chart review | No DM subgroup info available | DM subgroup analysis: Fasting BS ≥ 126, treatment with DM agents in last 2y, nonfasting baseline BS ≥ 200 IFG 110–125 and no history of DM NG - no history of DM and baseline BS < 110 | Unknown | See above - no DM specific information in lipid substudy | NR | DM specific information NA Baseline TC: I: 223.7 mg/dL (26.9), C: 223.7 mg/dL (26.7) LDL: I: 145.6 mg/dL (21.4), C: 145.5 mg/dL (21.3) HDL: I: 47.6 (13.4), C: 47.4 (13.6) TG: I: 150.6 (70.4), C: 152.8 (73.0) After 4 years follow-up: TC decreased 17.2% in I group, 7.6% in C group LDL decreased 27.7% in I group, 11.0% in C group HDL increased 3.3% in I group, 2.4% in C group | DM specific information NA Baseline BP SBP: I: 145 mmHg (13.8), C: 145 (14.0) DBP: I: 84 (9.8), C: 84 (9.8) | DM specific information not available Smoking: I: 23.1%, C: 23.3% Obesity: I: 42.8%, C: 42.5% History of CHD: I: 13.4%, C: 15.0% | I: pravastatin titrated to achieve 25% reduction in LDL cholesterol + diet C: diet, primary care physicians could prescribe LDL lowering treatment, but “vigorous therapy was discouraged” By year 6, 26% of control group participants were receiving a statin drug | Primary: all-cause mortality Secondary: fatal CHD or nonfatal myocardial infarction, cause-specific mortality, total and site-specific cancers, EKG evidence of myocardial infarction, health-related quality of life, major costs of medical care | All cause mortality (pravastatin vs usual care - relative risk and confidence interval):; - DM 1.03 (0.86–1.22); - nonDM 0.96 (0.84–1.11); CHD death + nonfatal myocardial infarction:; - DM 0.89 (0.71–1.10); - nonDM 0.92 (0.76–1.10) | NR | After 6y, 23% were not receiving the study drug in the pravastatin group | Specific AE data not collected
ASCOT (Anglo-Scandinavian Cardiac Outcomes Trial) Sever et al, 2003,^116^ 2005^118^ | Lipid treatment (pharmacology) | United Kingdom, Ireland, Denmark, Iceland, Sweden Primary care centers 1998 - 2000 | Total population: Atorvastatin: 5168 Placebo: 5137 | 3.3y (median) | Age 40–79 with either untreated (>160/100 mm/Hg) or treated (>140/90 mg/Hg) HTN; TC ≤ 251 mg/dL (≤ 6.5 mmol/l); no statin or fibrate use. Patients had to have at least 3 of the following: left ventricular hypertrophy, other EKG abnormality, DM2, peripheral arterial disease, previous stroke or transient ischemic attack, male, age ≥55, microalbuminuria or proteinuria, smoking, plasma total cholesterol/HDL ≥ 232 mg/dl (≥ 6 mmol/l), premature family history of CHD | Previous MI, treatment for angina at time of study, cerebrovascular event within 3m of study, fasting triglycerides > 395 mg/dL (4.5mmol/L), heart failure, uncontrolled arrhythmias, any clinically important hematological or biochemical abnormality | NR | Recruitment method NR Of total n, about 53% were recruited from primary care practices and 47% from referral centers | Total population- Race: 94.6% white Mean age: I: 63.1y (SD 8.5) C: 63.2y (SD 8.6) Male: 81% | NA | NA | Previous stroke or TIA: I: 485/5168 (9.4%), C: 516/5137 (10.0%) Peripheral vascular disease: I: 261/5168 (5.1%), C: 253/5137 (4.9%) Other relevant CVD (not described): I; 188/5168 (3.6%), C: 207/5137 (4.0%) Mean (SD) number of cardiovascular risk factors: I: 3.7 (0.9), C: 3.7 (0.9) | Glucose: I: 112 mg/dL, SD 38 (6.2 mmol/L, SD 2.1) C: 112 mg/dL, SD 6.2 mmol/L, (SD 2.1) | TC: 212 mg/dL (SD 31) both groups (5.5 mmol/L, SD 0.8) LDL: 131 mg/dL (SD 27) both groups (3.4 mmol/L, SD 0.7) HDL: 50 mg/dL (SD 15) both groups (1.3 mmol/L, SD 0.4) TG: I 149 mg/dL (SD 79) (1.7 mmol/L, SD 0.9), C 140 mg/dL (SD 79) (1.6 mmol/L, SD 0.9) On lipid-lowering treatment: I: 0.8%, C: 1.0% By the end of follow-up, LDL cholesterol was 29% lower in the intervention group compared to placebo | I: 164.2/95.0 (SD 17.7/10.3), C: 164.2/95.0 (SD 18.0/10.3) Any antiHTN use I: 4147/5168 (80.2%), C: 4141/5137 (80.6%) | Smoker: I: 1718/5168 (33.2%) C: 1656/5137 (32.2%) Left ventricular hypertrophy: I:744/5168 (14.4%), C:729/5137 (14.2%) EKG abnormalities other than left ventricular hypertrophy: I:741/5168 (14.3%), C:729/5137 (14.2%) | I: atorvastatin 10mg qd C: placebo qd The lipid trial was a substudy of a larger antihypertensive trial comparing a calcium channel blocker based regimen to a beta-blocker based regimen | To assess and compare the long-term effects on the combined endpoint of non-fatal MI (including silent MI) and fatal CHD Secondary endpoints: symptomatic MI + fatal CHD, all cause mortality, cardiovascular mortality, fatal and non-fatal stroke, heart failure, total coronary endpoints, total cardiovascular events and procedures | All comparisons I vs C (including p-values) Nonfatal MI + fatal CHD (including silent MI) - Primary endpoint 100/5168 (1.9%) vs 154/5137(3.0%) Rate/1000 patient y: 6.0 vs 9.4 HR 0.64 (0.50–0.83), p=0.0005 Total CV events and procedures 389/5168 (7.5%) vs 486/5137 (9.5%) Rate/1000 patient y: 24.1 vs 30.6 HR 0.79 (0.69–0.90), p=0.0005 Total coronary events 178/5168 (3.4%) vs 247/5137 (9.5%) Rate/1000 patient y: 10.8 vs 15.2 HR 0.71 (0.59–0.86), p=0.0005 Nonfatal MI (excluding silent MI) + fatal CHD 86/5168 (1.7%) vs 137/5137 (2.7%) Rate/1000 patient y: 5.2 vs 8.3 HR 0.62 (0.47–0.81), p=0.0005 | CV mortality 74/5168 (1.4%) vs 82/5137 (1.6%) Rate/1000 patient y: 4.4 vs 4.9 HR 0.90 (0.66–1.23), p=0.5066 Fatal and non-fatal stroke: 89/5168 (1.7%) vs 121/5137 (2.4%) Rate/1000 patient y: 5.4 vs 7.4 HR 0.73 (0.56–0.96), p=0.0236 Fatal and non-fatal heart failure: 41/5168 (0.8%) vs 36/5137 (0.7%) Rate /1000 patient y: 2.5 vs 2.2 HR 1.13 (0.73–1.78), p=0.5794 | Total withdrawals: I: 5, C: 9 Withdrawals due to AEs NR | No difference reported between groups One person in the I group developed rhabdomyolysis, but in the setting of high alcohol intake and a febrile illness
| See above | See above | DM population: Atorvastatin 1258 Placebo 1274 | See above | See above | See above | NR | See above | DM population: White race: I: 1131/1258 (89.9%) C: 1163/1274 (91.3%) Mean age: I:63.6y (SD 8.5) C: 64.0y (SD 8.2) Male: I: 77.0% C: 75.6% | Patient self-report with DM treatment (including diet, oral hypoglycemics, insulin) OR baseline FBG >108 mg/dL (>6.0mmol/L) and 2-h value ≥200 mg/dL (≥11.1 mmol/L) after 75-g glucose load | Oral hypoglycemics: I:645/1258 (51.3%), C:683/1274 (53.6%) Insulin: I:92/1258 (7.3%), C:96/1274 (7.5%) | Previous stroke or TIA: I: 93/1258 (7.4%), C: 98/1274 (7.7%) Peripheral vascular disease: I: 70/1258 (5.6%), C: 65/1274 (5.1%) Other significant CVD: I: 50/1258 (4.0%), C: 43/1274 (3.4%) Mean (SD) number of CV risk factors: I: 4.1 (1.0), C: 4.0 (1.0) | Glucose: I: 155 mg/dL, (8.6 mmol/L, SD 2.8) C: 157 mg/dL, (SD 8.7 mmol/L, SD 2.8) | TC: 205 mg/dL, SD 31 both groups (5.3 mmol/L, SD 0.8) LDL: I 127 mg/dL, SD 27 (3.3 mmol/L, SD 0.7), C 127 mg/dL, SD 31 (3.3 mmol/L, SD 0.8) HDL: 46 mg/dL, SD 12 both groups (1.2 mmol/L, SD 0.3) TG: 166 mg/dL, SD 87 both groups (1.9 mmol/L, SD 1.0) On lipid-lowering treatment: I: 1.1%, C: 1.6% By the end of follow-up, LDL cholesterol was 29% lower in the intervention group compared to placebo | I: 165.1/92.9 (SD 17.6/10.3), C: 164.8/92.4 (SD 17.1/10.3) Any antiHTN use I: 1069/1258 (85%), C: 1065/1274 (83.6% | Smoker: I: 257/1258 (20.4%) C: 258/1274 (20.3%) | I: atorvastatin 10mg qd C: placebo qd By end of the study, 14% in placebo group were receiving open-label statins and 84% of those originally assigned a statin were still taking one | See above | DM population: I vs C Nonfatal MI + fatal CHD (including silent MI) - Primary endpoint 38/1258 (3.0%) vs 46/1274 (3.6%) Rate/1000 patient y: 9.6 vs 11.4 HR 0.84 (0.55–1.29) Total CV events and procedures 118/1258 (9.2%) vs 151/1274 (11.9%) Rate/1000 patient y: 30.2 vs 39.1% HR 0.77 (0.61–0.98), p = 0.036 | Fatal and non-fatal stroke 27/1258 (2.1%) vs 41/1274 (3.2%) Rate/1000 patient y: 68. vs 10.2 HR 0.67 (0.41–1.09) There were NSD in risk reduction when comparing diabetes and no diabetes groups for any of the above outcomes (p-value for heterogeneity all > 0.1) For the primary endpoint, the p-value for heterogeneity between diabetic patients and nondiabetic patients was 0.14) | 30 patients had incomplete data; 4 vital data only at end of follow-up (reasoning NR) | No “excessive risk of adverse reactions” No significant differences in liver enzyme abnormalities No rhabdomyolysis
CONVINCE (Controlled ONset Varapamil Investigation of Cardiovascular Endpoints Trial) Black et al, 2003^104^ | BP treatment (pharmacology) | 15 countries (North America, South America, Europe) “Clinical sites” 1996 - 1998 | Total population: I :COER verapamil: 8241 C: Atenelol or hydrochlorothiazide: 8361 | 2–4.25 y (median 3 y) | Age >55 years; treatment for HTN or diagnosis of HTN: (current use of antihypertensive medication(s) for at least the past 2 months and BP 175/100 or no current use of antihypertensive medications or use of antihypertensive medications for < 2 m and 140 < SBP < 190 mm Hg or 90 < DBP < 110 mm Hg at the qualifying visit; presence of at least one of the following prior to randomization: history of MI (12m); history of stroke (6m) prior to randomization; history of cigarette use (current or within 3y); DM2; LVH by echocardiogram or electrocardiogram; low HDL (,35 mg/dL [,0.9 mmol/L]), high LDL (.159 mg/dL [.4.11 mmol/L]), or high TC (.250 mg/dL [.6.46 mmol/L]) on two occasions in the 5y prior to randomization; history of TIA with hospitalization; body weight >25% above ideal; presence of any known atherosclerotic vascular disease; presence of a vascular bruit | History of CHF, NYHA classification II – IV; cardiac dysrhythmias requiring medical treatment; secondary HTN due to any cause; sick sinus syndrome, heart block greater than first degree, bradycardia, or presence of Wolff-Parkinson-White or Lown-Ganong-Levine syndrome; other contraindications to either COER-verapamil or both HCTZ and atenolol; contraindication to either HCTZ or atenolol indicates eligibility; working an evening, night or alternating shift; known MI within 12 months or stroke within 6 months of randomization date; known renal impairment (serum creatinine > 2.0 mg/dL [> 177 mmol/L] or creatinine clearance , 30 mL/min); factors suggesting noncompliance with the protocol; a disease likely to cause death within 5y such as untreated malignancy; the investigator's clinical judgment that the patient will not achieve adequate BP control using a three-drug regimen; current SBP.190 mmHg or DBP.110mmHg without treatment by antihypertensive medication; medical condition at screening requiring treatment with any of the specific study medications; previous admission to the study; participation in another clinical trial of antihypertensive medications within 30 days of randomization | NR | Chart review at clinical site by participating physician | Total n = 16,476 Race: White - I: 84.2%, C: 84.5% Black - I: 6.9%, C: 6.8% Asian - I: 1.2%, C: 1.2% Hispanic - I: 7.3%, C: 7.0% Other - I: 0.4%, C: 0.5% Mean age I: 65.5 (SD 7.4), C: 65.6 (SD 7.4 Male: I 43.8%, C: 44.2% | NR | NR | Total population- Previous MI: I: 607/8179 (7.5%), C: 652/8297 (7.9%) Established vascular disease: I: 1362/8179 (16.7%), C: 1387/8297 (16.8%) Stroke: I: 370/8179 (4.5%), C: 393/8297 (4.8%) TIA: I: 184/8179 (2.3%), C: 162/8297 (2.0%) | NR | NR | I: 150.1/86.8 (SD 15.8/9.8), C: 150.1/86.8 (SD 16./9.8) | Obesity: I: 4150/8179 (51.0%), C: 4096/8297 (49.6%) Dyslipidemia: I: 2540/8179 (31.2%), C: 2575/8279 (31.2%) Vascular bruit: I: 403/8179, C: 409/8297 (5.0%) | COER verapamil 150mg qd (evening) vs atenolol or hydrochlorthiazide Hydrochlorthiazide, if necessary, could be added to regimen of patients receiving COER verapamil or atenolol, and atenolol could be added to those receiving initial hydrochlorthiazide | To compare the 2 regimens in preventing acute MI, stroke or CVD death Secondary: expanded CVD endpoint to include: hospitalization for angina, cardiac revascularization or transplant, heart failure, transient ischemic attack or carotid endarterectomy, accelerated or malignant hypertension, renal failure; all-cause mortality; cancer; hospitalization for bleeding (excluding hemorrhagic stroke); incidence of primary endpoint occurring between 6am-noon | Total population Primary composite outcome: I vs C 364/8179 vs 365/8297 HR 1.02 (0.88–1.18; p=0.77); - Fatal or nonfatal MI: I vs C 133/8179 vs 166/8297 HR 0.82 (0.65–1.03; p=0.09); - Fatal or nonfatal stroke: I vs C 133/8179 vs 118/8297 HR 1.15 (0.90–1.48; p=0.26); - CV-related death: I vs C 152/8179 vs 143/8297 HR 1.09 (0.87–1.37; p=0.47) | DM vs non-DM - DM - RR 0.86 (0.66 – 1.12) non-DM - RR 1.10 ( 0.92 – 1.31) Interaction of diabetes treatment p = 0.16 | Treatment withdrawals: I: 39.4%, C: 39.7% Participants in intervention group withdrew more often due to adverse events (p = 0.02) Withdrawals due to constipation: I: 216/8179, C: 28/8361 | New cancer: I: 3.8%, C: 3.6 % HR 1.06 (0.91–1.24), p = .46 Death or hospitalization due to bleeding (not including intracerebral bleeding): I: 1.4%, C: 1.0% HR 1.54 (1.15–2.04), p = .003 Deaths from bleeding 0.1% in both groups Death or hospitalization due to serious AE: I: 16.9%, C: 16.4% HR 1.04 (0.97 – 1.12), p = 0.29
HPS (Heart Protections Study) HPS Collaborative Group, 2003^95^ | Lipid treatment (pharmacology) | United Kingdom Study clinic (referral from general practitioner) 1994 - 1997 | Simvastatin: 10269 Placebo: 10267 | 4.8y (mean) | Age 40–80 with nonfasting TC at least 135 mg/dl w/history of DM, coronary disease, occlusive disorder of noncoronary arteries or treated HTN (if also male and at least 65y) | Patients that general practitioner considered statin use to be clearly indicated or contraindicated, previous MI, stroke, hospital admission for angina within previous 6m; chronic liver disease or evidence of abnormal liver function, severe renal disease or evidence of substantially impaired renal function, inflammatory muscle disease or evidence of muscle problems, concurrent treatment with cyclosporin, fibrates or high-dose niacin, child-bearing potential, severe heart failure, life-threatening condition other than vascular disease or diabetes, conditions that might limit long-term compliance | 9.3y (mean) N=5348 | Use of medical records to identify potentially eligible patients with cooperation of general practitioners | DM population (5963) vs non-DM population (14,573) (Note: DM population includes DM1 and DM2) Race: NR Age: 62.1 y (SD 8.9) vs 64.7 (SD 8.1) Male: 30% vs 22% | NR | DM2 population: Insulin: 25% Sulphonylureas: 42% Metformin: 31% None of these agents: 21% | DM population vs non-DM population: Prior M: 1125/5963 (19%) vs 7385/14573 (51%) Other CHD: 856/5963 (14%) vs 4020/14573 (28%) Other vascular: 1070/5963 (18%) vs 2930/14573 (20%) | NR | DM population vs non-DM population: TC: 220 mg/dL, SD 39.8 (5.7 mmol/L, SD 1.03) vs 228 mg/dL, SD 38.6 (5.9 mmol/L, SD 1.00) LDL: 124 mg/dL, SD 31.7 (3.2 mmol/L, SD 0.82) vs 131 mg/dL, SD 31.7 (3.4 mmol/L, SD 0.82) HDL: 41 mg/dL, SD 13.9 (1.06 mmol/L, SD 0.36) vs 41 mg/dL, SD 12.0 (1.06 mmol/L, SD 0.31) TG: 204 mg/dL, SD 61.4 (2.3 mmol/L, SD 1.59) vs 177 mg/dL, SD 49.0 (2.0 mmol/L, SD 1.27) | DM population vs non-DM population: 148/82 (SD 23/12) vs 143/81 (SD 24/12) | Smoker (ever): DM population vs non-DM population 4008/5963 (67%) vs 11354/14573 (78%) | I: simvastatin 40mg qd C: placebo | Vascular mortality and morbidity of a substantial LDL cholesterol reduction maintained for several years | Non-DM population Major coronary events: I: 8.5% vs C: 11.5% Stroke: 4.0% vs 5.4% Revascularization: 9.3% vs 12.3% Major vascular events: 19.6% vs 25.2% DM population (Type 1 and 2 combined) Major coronary events: I: 9.4% vs C: 12.6% Stroke: I: 5.0% vs C: 6.5% Revascularization: I: 8.7% vs C: 10.4% Major vascular event: I: 20.2% vs C: 25.1% Risk reduction, I vs C (95% CI, p): Major coronary events; - nonDM, 27% (19–34, <.0001); - DM, 27% (15–38, <.0001) — reflected a 20% (4–34, .02) Reduction in coronary mortality; Stroke; - nonDM, 26% (14–36, .0002); - DM, 24% (6–39, .01); Revascularization; - nonDM, 26% (18–33, <.0001); - DM, 17% (3–30, .02); Major vascular events; - nonDM, 25% (19–30, <.0001); - DM, 22% (13–30, <.0001); No significant differences between DM and nonDM groups for outcomes above (p-value for heterogeneity all > 0.3) | Other subgroup comparisons on first major vascular event:; - A comparison amongst subgroups of diabetic persons revealed no significant differences in risk reduction according to: sex, age, history of treated hypertension, BMI, duration of diabetes, or baseline level of glycemic control; - Diabetic persons without CHD benefited to similar degree as those with CHD and no diabetes; Risk reduction of first major vascular event associated with simvastatin use according to baseline features:; - DM alone, RRR 32.9%, ARR 4.4%, p = .0003; - Occlusive arterial disease alone, RRR 24.5%, ARR 6.2%, p <.0001; - DM + occlusive arterial disease, RRR 18.4%, ARR 6.6%, p = .002 | Compliance based on at least 80% of scheduled intervention taken at each follow-up (every 4 months for 1st y, then every 6 months) 82% simvastatin compliance, placebo NR Withdrawals: “about 1/6 stopped taking simvastatin” | NR
Olivarius et al, 2001^98^ | Disease management | Multi-center: 311 Danish practices (474 general practitioners) | Start of study: Routine care: 614 Structured care: 649 Analyzed for outcomes: Routine care: 415 Structured care: 459 | 6y (through January 1998) | Ages ≥ 40 y Newly diagnosed diabetes, defined as ≥126 mg/dL (≥ 7.0 mmol/l), between March 1989 – February 1991 Registered with a participating general practitioner | Life threatening somatic disease Mental illness Declined to consent Diagnosis not confirmed Non-white ethnicity | Newly- diagnosed | Invitations sent to random sample of general practitioners; patients identified by screening through these general practitioners | Structured care vs routine care, respectively: % male: 52.4, 53.1 Median age: 65.5 (55.3–74.0), 65.3 (56.3–73.5) 100% White | Diagnosed by primary care physician and confirmed by FPG ≥ 126 mg/dL | Diabetes treatment methods varied per specific doctor's decisions, based on structured care approach | Structured care vs routine care %, respectively: History of myocardial infarction: 6.6, 7.7 Angina pectoris: 11.7, 11.9 History of stroke: 3.5, 4.2 Intermittent claudication: 3.9, 3.3 Amputation: 0.3, 0.2 | Structured care vs routine care %, respectively: 10.2, 10.2 | Structured care vs routine care median, respectively: TC: 6.2, 6.2 Fasting TG: 2.03, 1.98 | Structured care vs routine care median, respectively: BP: 150/85, 148/85 | Structured care vs routine care median, respectively: BMI: 29.4/28.8 Current smokers: 35.5, 34.5 Former smokers: 31.3, 37.6 Never smokers: 33.2, 27.9 Note: Baseline variables for occupation and smoking habits were significantly different between I and C groups, p=0.01 and p=0.039 respectively | Routine care (national guidelines) vs structured care (routine care + additional 3 month questionnaires completed by doctor; 3 month consultations between patient and doctor discussing status and treatment goals; doctors received annual descriptive reports on patients; annual half day educational seminar for doctor; educational pamphlets distributed to patient) | Primary: Overall mortality and incidences of diabetic retinopathy, urinary albumin concentration ≥ 15 mg/l, myocardial infarction, and stroke Secondary: New peripheral neuropathy, angina pectoris, intermittent claudication, and amputation Tertiary outcomes: Levels of risk factors included in patient's goals Note: Focus of study to evaluate attitudes and opinions of doctors, risk factors, and varying treatment regimes, but provides 6 y morbidity and mortality outcomes of screen-detected population | Nonfatal outcomes and mortality were the same in both groups (p< 0.01 is significant): Overall mortality p=0.82 Diabetic retinopathy p=0.55 Urinary albumin > 15 mg/l p=0.04 MI p=0.40 Stroke p=0.95 Peripheral neuropathy p=0.41 Angina pectoris p=0.68 Intermittent claudication p=0.96 Amputation p=0.35 | Metformin was used more frequently in intervention group for 32 patients (10%) vs 14 patients (5), p=0.013 | Structured care vs routine care #s, respectively: Death during study: 155, 164 Withdrew consent: 17, 17 Lost to follow-up: 18, 18 | NR
PPP (Primary Prevention Project) Sacco et al, 2003^96^ | Aspirin and Vitamin E treatment | Italy outpatient and diabetic clinics 1994 - 1998 | Aspirin: 519 Vitamin E: 509 | 3.6y (mean) | Age ≥ 50 with at least one major cardiovascular risk factor (age ≥ 65, HTN, hyperlipidemia, diabetes, obesity, family history of premature CHD) | Severe pathology; treatment with antiplatelet drugs (history of vascular events or disease); chronic use of antinflammatory agents or anticoagulants; chronic use of aspirin or vitamin E; disease with predictable poor short-term prognosis; predictable psychological or logistical difficulties affecting compliance with trial requirements | NR | Recruited from general practitioner and diabetes clinics; method NR | DM population: Race: NR Age: 64.2 y (SD 7.5) Male: 48.2% | Fasting venous plasma glucose ≥140 mg/dL (≥7.8mmol/L) on at least two occasions or treatment with antidiabetic drugs | Aspirin group: I: n=519 Diet: 141 Sulphonyloureas: 133 Metformin: 18 Sulphonyloureas + metformin: 169 Insulin + OHA: 47 Other: 11 C: n=512 Diet: 137 Sulphonyloureas: 135 Metformin: 17 Sulphonyloureas + metformin: 166 Insulin + OHA: 48 Other: 9 Vitamin E group: I n=509 Diet: 133 Sulphonyloureas: 147 Metformin: 14 Sulphonyloureas + metformin: 162 Insulin + OHA: 44 Other: 9 C n=522 Diet: 145 Sulphonyloureas: 121 Metformin: 21 Sulphonyloureas + metformin: 173 Insulin + OHA: 51 Other: 11 | DM population n=1031 HTN: 643 (62.4%) Hypercholesterolemia: 308 (29.9%) | NR | DM population: TC: 224.6 (SD 44.0) HDL: 49.8 (SD 16.2) TG: 175.1 (SD 105.9) | DM population: 148.7/84.9 (SD 17.1/9.0) antiHTN treatment: 624/1031 | DM population: BMI 29.0 (SD 5.0) Current smoker: 168/1031 3 or more CV risk factors: 613 (59.5%) | Aspirin 100mg qd Vitamin E 300 mg qd | Reduction in the incidence of major CV and cerebrovascular events (CV deaths, nonfatal MI, nonfatal stroke) | DM population - aspirin vs no aspirin Main combined endpoint 3.9% vs 4.3% RR 0.90 (0.50–1.62) Total CV events 10.2% vs 11.5% RR 0.89 (0.62–1.26) CV deaths 1.9% vs 1.6% RR 1.23 (0.49–3.10) MI 1.0% vs 2.0% RR 0.49 (0.17–1.40) Stroke 1.7% vs 2.0% RR 0.89 (0.36–2.17) Angina: 3.1% vs 3.9% RR 0.80 (0.39–1.64) TIA: 1.7% vs 2.4% RR 0.69 (0.27–1.79) Peripheral artery disease 2.6% vs 3.2% RR 0.83 (0.38–1.84) | DM population - Vitamin E vs no Vitamin E Main combined endpoint 4.3% vs 3.8% RR 1.13 (0.62–2.04) Total CV events 10.0% vs 11.7% RR 0.86 (0.60–1.22) CV deaths 2.0% vs 1.5% RR 1.28 (0.51–3.22) MI 1.4% vs 1.5% RR 0.90 (0.33–2.46) Stroke 1.6% vs 2.1% RR 0.75 (0.30–1.83) Angina 3.4% vs 3.6% RR 0.93 (0.45–1.90) TIA 1.5% vs 2.7% RR 0.54 (0.21–1.43) Peripheral artery disease 2.4% vs 3.4% RR 0.71 (0.32–1.58) | NR | Nonfatal bleeding higher with aspirin use 1.9 vs 0.2%; p=0.007 for aspirin vs no aspirin
| See above | See above | See above | 3.7y (mean) | See above | See above | See above | See above | non-DM population: Race: NR Age: 64.4y (SD 7.7) Male: 41.5% | See above | See above | Non-DM population n=3753 HTN: 2580 (68.8%) Hypercholesterolemia: 1498 (39.9%) (both of these significantly more frequent than in DM group) | See above | Non-DM population: TC: 237.8 (SD 44.7) HDL: 53.8 (SD 17.0) TG: 149.7 (SD 80.4) (Total and HDL cholesterol significantly higher than in DM group, and TG's significantly lower than in DM group) | Non-DM population: 144.6/85.5 (SD 16.0/8.4) antiHTN treatment: 2523/3753 | Non-DM population: BMI 27.3 (SD 4.5) Current smoker: 555/3753 3 or more CV risk factors: 849 (22.6%) Many fewer - about 60% less- in the nonDM group had multiple CV risk factors as compared to the DM group | See above | See above | Non-DM population - aspirin vs no aspirin Main combined endpoint 1.6% vs 2.7% RR 0.59 (0.37–0.94) Total CV events 5.3% vs 7.5% RR 0.69 (0.53–0.90) CV deaths 0.4% vs 1.3% RR 0.32 (0.14–0.72) MI 0.8% vs 1.2% RR 0.69 (0.36–1.35) Stroke 0.6% vs 0.1% RR 0.59 (0.28–1.25) Angina 2.7% vs 3.1% RR 0.85 (0.56–1.28) TIA 1.4% vs 2.0% RR 0.71 (0.41–1.22) Peripheral artery disease 0.4% vs 1.0% RR 0.38 (0.15–0.99) | Non-DM - Vitamin E vs no Vitamin E Main combined endpoint 2.2% vs 2.1% RR 1.03 (0.66–1.60) Total CV events 6.3% vs 6.5% RR 0.97 (0.74–1.26) CV deaths 0.7% vs 1.0% RR 0.73 (0.36–1.47) MI 1.0% vs 1.0% RR 0.95 (0.49–1.82) Stroke 1.0% vs 0.6% RR 1.51 (0.72–3.15) Angina 3.3% vs 2.6% RR 1.29 (0.85–1.95) TIA 1.8% vs 1.6% RR 1.09 (0.63–1.87) Peripheral artery disease 0.4% vs 1.0% RR 0.37 (0.14–0.96) | NR | See above
PROSPER (Prospective Study of Pravastatin in the Elderly at Risk trial) Shepherd et al, 2002^117^ | Lipid treatment (pharmacology) | Scotland, Ireland, Netherlands Setting not specified 1997 - 1999 | Pravastatin: 2891 Placebo: 2913 | 3.2 y (mean) | Age 70–82 Pre-existing vascular disease or higher risk for vascular disease because of smoking, HTN, or diabetes TC: 155 – 348 mg/dL (4.0 – 9.0 mmol/L) Triglycerides < 531 mg/dL (6.0 mmol/L) | After run-in period, those using less than 75% or more than 120% of assigned treatment were excluded Poor cognitive function | NR | NR | Total n = 5804 Diabetic subgroup: 11% I: 320/2891, C: 303/2913 Race: NR % male: 48 Mean age (SD): I: 75.4 (3.3), C: 75.3 (3.4) | NR | NR | History of angina: I: 806/2891 (27.9%), C: 753/2913 (25.8) History of claudication: I: 198/2891 (6.8%), C: 192/2913 (6.6%) History of myocardial infarction: I: 377/2891 (13.0%), C: 399/2913 (13.7%) History of stroke or TIA: I: 328/2891 (11.3%), C: 321/2913 (11.0%) History of angioplasty or CABG: I: 129/2891 (4.5%), C: 108/2913 (3.7%) History of peripheral vascular disease surgery: I: 67/2891 (2.3%), C: 56/2913 (1.9%) History of vascular disease: I: 1306/2891 (45.2%), C: 1259/2913 (43.2%) | NR | TC (both groups): 220 mg/dL, SD 34.7 [5.7 mmol/L, SD 0.9] LDL (both groups): 147 mg/dL, SD 30.9 [3.8 mmol/L, SD 0.8] HDL ( both groups): 50 mg/dL, SD 11.6 [1.3 mmol/L, SD 0.3] TG (both groups): 133 mg/dL, SD 27.0 [1.5 mmol/L, SD 0.7] % on lipid meds: NR Baseline values for I and C separately | I: 154.7/83.6 (21.9/11.2), C: 154.6/83.9 (21.8/11.7) | Smoker: I: 753/2891 (26.0%), C: 805/2913 (27.6) History of HTN: I: 1799/2891 (62.2%), C: 1793/2913 (61.6%) | I: Pravastatin 40 mg/day C: placebo daily | Primary endpoint: combined outcome CHD mortality, non-fatal myocardial infarction, fatal or non-fatal stroke Secondary outcomes: each of the above components examined separately Tertiary outcomes: included TIA, disability, and cognitive function | Primary outcome: I: 408/2891 (14.1%), C: 473/2913 (16.2%) HR: 0.85 (0.74–0.97), p = 0.014 95% CI Primary endpoint - DM group: I: 70/303 (23.1%), C: 59/320 (18.4%) NonDM group: I: 338/2588 (13.1%), C: 414/2593 (16.0%) HR: 1.27 (0.90 – 1.80), p-value for interaction 0.015 CHD mortality or non-fatal myocardial infarction (including silent and unrecognized events): I: 292/2891 (10.1%), C: 356/2913 (12.2%) HR: 0.81 (0.69 – 0.94), p = 0.006 Fatal or non-fatal stroke: I: 135/2891 (4.7%), C: 131/2913 (4.5%) HR: 1.03 (0.81 – 1.31), p = 0.81 | CHD mortality or non-fatal myocardial infarction (excluding silent and unrecognized events): I: 193/2891 (6.7%), C: 246/2913 (8.4%) HR: 0.77 (0.64 – 0.93), p = 0.007 CHD mortality: I: 94/2891 (3.3%), C: 122/2913 (4.2%) HR 0.76 (0.58 – 0.99), p = 0.043 All-cause mortality: I: 298/2891 (10.3%), C: 306/2913 (10.5%) HR: 0.97 (0.83 – 1.14), p = 0.74 At 2y follow-up, pravastatin induced decrease in LDL cholesterol was 27% | Discontinued: I: 724/2891, C: 725/2913 Non-fatal adverse events: I: 107/2891, C: 116/2913 | Rhabdomyolysis: none in either group Cancer: HR for new cancer diagnosis I vs C: 1.25 (1.04 – 1.51), p = 0.02 Myalgias: I: 36/2891, C: 32/2913
WHI (Women's Health Initiative) Ridker et al, 2005^97^ | Aspirin treatment | United States Community-based, primary-care feasible 1992 - 2004 | Aspirin: 19,934 Placebo: 19,942 | 8.1y (mean) | Age ≥ 45, female | History of: CHD, cerebrovascular disease, cancer, other major chronic illness History of side effects to aspirin or vitamin E Regular NSAID, vitamin A, vitamin E, or beta-carotene use Anticoagulant or steroid use | NR | Volunteers recruited through mass mailing to female health professionals | Female health professionals Diabetes subgroup: 2.6% I: 538/19,934, C: 499/19,942 Age: 54.6 (7.0) in both groups Race: NR % male: 0% ≥ 65: 10% | NR | NR | None - history of CHD or cerebrovascular disease were exclusion criteria History of peripheral vascular disease not reported, but likely minimal | NR | Hyperlipidemia defined as TC ≥ 240 mg/dL or self-reported physician-diagnosed hyperlipidemia with hyperlipidemia: I: 5960/19,934 (29.9%) C: 5803/19,942 (29.1%) | <130/85 mm Hg: I: 12,838/19,934 (64.4%), C: 12,903/19,942 (64.7%) 130–139/85–89 mm Hg: I: 3887/19,934 (19.5%), C: 3849/19,942 (19.3%) ≥ 140/90: I: 3209/19,934 (16.1%), C: 3171/19,942 (15.9%) | Current smokers: I: 2591/19,934 (13.0%), C: 2652/19,942 (13.3%) Obese: I: 3648/19,934 (18.3%), C: 3629/19,942 (18.2%) Family history premature MI: I: 2591/19,934 (13.0%), C: 2573/19,942 (12.9%) 10y Framingham risk: < 5.0%: I: 16,824/19,934 (84.4%), C: 16,871/19,942 (84.6%) ≥ 10.0%: I: 777/19,934 (3.9%), C: 818/19,942 (4.1%) | I: Aspirin 100 mg every other day C: placebo | Primary endpoint: combination of CHD death, non-fatal MI, non-fatal stroke Secondary endpoints: included individual end points of fatal or nonfatal MI, fatal or nonfatal stroke, ischemic stroke, hemorrhagic stroke, CHD death Tertiary end points: included all-cause mortality, transient ischemic attack, need for coronary revascularization | Total event rates: Major CV event: I: 477/19,934, C: 522/19,942 RR 0.91 (0.80 – 1.013), p = 0.13 Stroke: I: 221/19,934, C: 266/19,942 RR 0.83 (0.69 – 0.99), p = 0.04 DM vs non-DM: Major CV event - DM group: I: 58/538, C: 62/499 RR 0.9 (0.63 – 1.29), p = 0.57 Major CV event - nonDM group: I: 418/19,396, C: 460/19,433 RR 0.9 (0.79 – 1.03). p = 0.13 Stroke - DM group: I: 15/538, C: 31/499 RR 0.46 (0.25 – 0.85), p = 0.01 Stroke - nonDM group: I: 206/19,396, C: 235/19,433 RR 0.87 (0.72 – 1.05), p = 0.15 | Other than age and smoking status, there was no evidence of interaction between any of the other risk factors considered, including diabetes, and treatment effects | NR | No DM specific numbers Gastrointestinal bleeding: I: 910/19,934 (4.6%), C: 751/19,942 (3.8%) RR 1.22 (1.10 – 1.34), p , 0.001 Peptic ulcer: 542/19,934 (2.7%), C: 413/19,942 (2.1%) RR 1.32 (1.16 – 1.50), p < 0.001 Hematuria: I: 3,039/19,934 (15.2%), C: 2,879/19,942 (14.4%) RR 1.06 (1.01 – 1.12), p = 0.02 Easy bruising, epistaxis, and any report of gastric upset were also significantly more common in the aspirin group There were 5 fatal GI bleeds, 2 in the aspirin group and 3 in the placebo group

Abbreviations: AE, adverse effect; ALT, alanine aminotransferase test; ARR, absolute risk reduction; BMI, body mass index; BP, blood pressure; BS, blood sugar; C, control group; CABG, Coronary artery bypass graft; CHD, coronary heart disease; CHF, congestive heart failure; COER, controlled-onset extended-release; CVD, cardiovascular disease; DBP, diastolic blood pressure; DM, diabetes mellitus; DM2, type 2 diabetes; EKG, electrocardiogram; FBG, fasting blood glucose; FPG, fasting plasma glucose; GI, gastrointestional; HCTZ, hydrochlorothiazide; HDL, high density lipoprotien cholesterol; HPS, Heart Protection Study; HR, hazard ratio; HTN, hypertension; I, intervention group; IFG, impaired fasting glucose; LDL, low density lipoprotein cholesterol; LVEF, left ventricular ejection fraction; LVH, left ventricular hypertrophy; MI, myocardial infarction; N, number of participants in study; NA, not applicable; NG, normoglycemic; NR, not reported; NSAID, Non-Steroidal Anti-Inflammatory Drug; NSD, no significant difference; NYHA, New York Heart Association; OHA, Oral Hypoglycaemic Agent; qd, daily; RR, relative risk; RRR, relative risk reduction; SBP, systolic blood pressure; SD, standard deviation; TC, total cholesterol; TG, triglycerides; TIA, transient ischemic attack; ULN, upper limit of normal; y, year.

Table B7 Diabetes vs. Nondiabetes Evidence Table of Systematic Reviews (KQ2)

Author, year Quality rating | Aims | Included studies | Time period covered | Eligibility criteria | Length of follow-up | N | Characteristics of included articles: study design / interventions / treatment | Outcomes | Main results | Adverse events
Blood Pressure Lowering Treatment Trialists' Collaboration, 2005^107^ Fair | Meta-analysis to compare effects of different BP lowering regimens on cardiovascular events and death in patients with and without DM | AASK ABCD (H) ABCD (N) HOPE HOT INDT LIFE NICOLE PART2 PREVENT PROGRESS RENAAL SCAT SCOPE SYST-EUR UKPDS-HDS | NR - 2003 | Must meet one of the below criteria:; 1) Randomization of patients between a BP lowering agent and a control (placebo or less intensive BP lowering regimen) or; 2) Randomization of patients between regimens based on different classes of BP lowering drugs; Trials must also: ≥ 1000 patient-years of planned follow up in each randomized group Must not have presented or published main results before finalization of the overview protocol in July 1995 Must not have aspirin or cholesterol lowering regimens added to the BP lowering regimen | 2.6 – 8.4y | Total: 158,709 DM: 33,395 NonDM: 125,314 | RCT Angiotensin-converting enzyme inhibitors, calcium antagonists, angiotensin receptor blockers, and diuretics/beta-blockers: ramipril, perindopril, indapamide, enalapril maleate, amlodipine, nisoldipine, nitrendipine, irbesartan, losartan potassium, atenolol, candesartan, metoprolol, lisinopril, chlorthalidone, hydrochlorothiazide, captopril, atenolol, COER verapamil, lacidipine, nifedipine GITS, amiloride, nicardipine, trichlormethiazide, diltiazem, felodipine, isradipine, pindolol, verapamil | 6 primary outcomes: Nonfatal stroke or death from cerebrovascular disease; nonfatal MI or death from CHD, including sudden death; heart failure causing death or requiring hospitalization; total major cardiovascular events (stroke, CHD events, heart failure, and other cardiovascular death); total cardiovascular death; total mortality | 27 RCTs included. Total major cardiovascular events were reduced to a “comparable extent” in patients with and without DM for ACE-I, calcium antagonists, ARBs, diuretics, and beta-blockers (p> 0.19 for all by ×2 test of homogeneity) Stroke: ARBs provided less protection for those with DM, than for those without DM (p=0.05) CHD: ARBs provided greater protection for those with diabetes than for those without diabetes (p=0.002). Reduction in risk of total major cardiovascular events (p=0.03) and cardiovascular deaths (p=0.02) in those with DM vs without DM using regimens targeting lower BP goals (favors more vs less intensive regimen). More protection against cardiovascular death (p=0.05) and total mortality (p=0.03) for those with DM vs without DM using ACE-I | NR
Costa et al, 2006^119^ Good | Meta-analysis to evaluate clinical benefits of lipid lowering drug treatment in patients with and without DM, for primary and secondary prevention | AFCAPS/TexC ALLHAT-LLA ASCOT-LLA HHS HPS PROSPER | 1966 – April 2004 (MEDLINE); 1980 – April 2004 (Embase); through issue 2, 2004 (Cochrane Central) | Lipid lowering/cholesterol drug arm Placebo arm Adequate concealment of random allocation Double blind assessment, including clinical outcomes ≥ 500 patients per group Type 2 diabetic and non-diabetic patients in both arms Follow up of ≥ 3 y Cardiovascular event as primary or secondary endpoint Provision for allowing calculation of individual results for DM vs nonDM groups Those with and without previous coronary artery disease (to evaluate primary and secondary prevention) | ≥ 3y | 80,862 | RCT Lipid lowering drug treatment: lovastatin, pravastatin, gemfibrozil, atorvastatin, simvastatin, fluvastatin, lovastatin | [underlined: Primary outcomes]: Major coronary events (coronary artery disease death, non-fatal MI) or myocardial revascularization procedures (coronary artery bypass grafting or percutaneous transluminal coronary angioplasty) [underlined: Secondary outcomes]: Coronary artery disease death, non-fatal MI, revascularization procedures, stroke, blood lipid concentration changes, TC, LDL, HDL,TG | 12 studies included (6 primary prevention, 8 secondary prevention) Lipid lowering drug treatment was found to be equally efficacious in DM and nonDM patients: Primary Prevention: [underlined: RR for major coronary events treated with either statins or gemfibrozil:] DM: 21% (95% CI, 11–30%, p<0.0001) NonDM: 23% (95% CI, 12–33%, p=0.0003) [I^2^ = 68%] [underlined: RD for major coronary events]: DM: -0.02 (-0.04 to -0.00; p=0.1) NonDM: -0.02 (-0.02 to -0.01; p<0.00001) [underlined: NNT for major coronary events:] DM: 37 (24 – 75) NonDM: 47 (35 – 73) | NR

Abbreviations: AASK, African-American Study of Kidney Disease and Hypertension Trial; ABCD (H), Appropriate Blood Pressure Control in Diabetes trial (hypertensive subgroup); ABCD (N), Appropriate Blood Pressure Control in Diabetes trial (non-hypertensive subgroup); ACE-I, angiotensin-converting enzyme-inhibitor; AFCAPS/TexCAPS, Air Force/Texas Coronary Atherosclerosis Prevention Study; ALLHAT-LLA, Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial—Lipid Lowering Arm; ARBs, angiotensin II receptor blockers; ASCOT-LLA, Anglo-Scandinavian Cardiac Outcomes Trial—Lipid Lowering Arm; BP, blood pressure; CHD, coronary heart disease; COER, controlled onset extended release; DM, diabetes; GITS, gastrointestinal transport system; HDL, high density lipoprotein; HOPE, Heart Outcomes Prevention Evaluation study; HOT, Hypertension Optimal Treatment study HPS, Heart Protection Study; IDNT, Irbesartan Diabetic Nephropathy Trial; LDL, low density lipoprotein; LIFE, Losartan Intervention for Endpoint Reduction Trial; MI, myocardial infarction; NICOLE, Nisoldipine In Coronary Artery Disease in Leuven; NNT, number needed to treat; NR; not reported; PART2, Prevention of Atherosclerosis with Ramipril Therapy; PREVENT, Prospective Randomized Evaluation of the Vascular Effects of Norvasc Trial; PROGRESS, Perindopril Protection Against Recurrent Stroke Study; PROSPER, Prospective Study of Pravastatin in the Elderly at Risk trial; RCT, randomized controlled trial; RENAAL, Randomized Evaluation of Non-Insulin-Dependent Diabetes Mellitus with the Angiotensin II Antagonist Losartan; RD, risk difference; RR, relative risk; SCAT, Simvastatin/Enalapril Coronary Atherosclerosis Trial; SCOPE, Study on Cognition and Prognosis in the Elderly; SYST-EUR, Systolic Hypertension-Europe trial; TC, total cholesterol; TG, triglycerides; UKPDS-HDS, United Kingdom Prospective Diabetes Study; y, year.

Table B8 Studies Modeling Treatment of Persons with Newly-Diagnosed Type 2 Diabetes

Model name Author, year (in date order) | Objective | Type of screening; Perspective | Type of model | Population Country | Included costs | Discount rate | Base case assumptions | Time horizon | Data sources | Sensitivity analyses | Intervention | Outcomes | Conclusions
Global Diabetes Model Brown et al, 2000^133,^ ^126^ | To examine the predictions of the Global Diabetes Model for 20y cumulative rates of various outcomes | NA Payer | Monte Carlo microsimulation (stochastic) model using continuous prediction equations; can be used to simulate a single individual or populations | 5000 newly diagnosed DM2 white males; no CVD or other macro- or microvascular complications; based on Kaiser health maintenance organization United States | Direct medical costs | 0% | A1c predicts microvascular events only; risks maintained at baseline levels | 20y | Kaiser databases, world scientific literature, observational data such as Framingham Heart Study | None (Palmer 2000) | Intensive lipid management (LDL from 150 to 100 mg/dl and HDL from 40 to 50 mg/dl) | A1c 9.5%, SBP 130: % survival: 82.7% Total costs per person ($US): $85,920 Lower costs for lower A1c, higher costs for higher SBP | Survival improves with intensive lipid therapy
CDC / RTI Model (Centers for Disease Control and Prevention / Research Triangle Institute) CDC Diabetes Group, 2002^123^ | To estimate the incremental CE of intensive glycemic control, intensified HT control, and reduction in TC for patients with DM2 | Health care system (for costs) | Markov model, with emphasis on macrovascular complications, interdependencies among diabetes progression paths Subjects proceed through 5 different disease paths; nethropathy, neuropathy, retinopathy, CHD, stroke | Newly diagnosed DM2; 55% female, 8% 25–34y, 8% 35–44y, 26% 45–54y, 18% 55–64y, 23% 65–74y, 13% 75–84, 4% 84–94y United States | Health care system only; no indirect or direct patient costs | Costs and QALYs discounted at 3% (sensitivity analysis 0 to 5%) | Intensified HT control did not have an effect on CHD; intensive treatments assumed for lifetime | Death or age 95y | UKPDS for population distribution at diagnosis, other data for DM and CHD progression from other sources; costs data from literature; health utility values: 0 deceased, 1 perfect health, 0.690 blindness, lower extremity amputation 0.80; estimates of hazard rates of complications based on DCCT data and assumed to work for DM2; efficacy of intensified HT treatment from 7 UKPDS; estimates of risk reduction from reduction in cholesterol on CHD (31% in subjects without CHD, 25% in subjects with CHD) based on West of Scotland Prevention Study | If intensive glycemic control reduced CHD risk, QALYs increased to 0.3325 and CE ratio decreased to $27000 If microalbuminuria does not lead to HT or persons with HT do not progress faster: moderate increase in CE ratio Intervention provided to subjects who develop HT after diagnosis of DM2: CE ratio $2091/QALY Reduction in TC: if intervention required no additional visits or tests: decreased CE ratio by $47716/QALY | All subjects were assumed to receive conventional treatment to control blood glucose (treatment based on UKPDS control arm which produced an average A1c of 7.9% over 10y) Intensive glycemic control: to reduce FPG to <108 mg/dl using chlorpropamide, glipizide, insulin Intensified HT control: ACE-I or B-blocker for baseline BP ≥ 160/95 Reduction in TC: pravastatin for baseline level ≥200 mg/dl | Intensive glycemic control applied to all persons newly diagnosed with DM2 in the US: increase in QALY of 0.1915 (discounted), CE ratio: $41,384 per QALY; CE ratio increases markedly with age; cumulate incidence of nethropathy, neuropathy, retinopathy decreased by 11 to 27% Intensified HT control: increased QALYs by 0.392 relative to moderate HT control; CE ratio - $1,959/QALY (i.e. cost savings); age had little effect Reduction in serum cholesterol: increase in discounted QALYs 0.3475, CE ratio $51,889 per QALY, lowest ratio for 45–85y | Intensified HT control reduces costs and improved health outcomes relative to moderate HT control (CE ratio - $1959); intensive glycemic control (CE ratio $41,384) and reduction in serum cholesterol (CE ratio $51,889) increase costs and improve health outcomes Intensive glycemic control is most CE for younger persons
CORE Model (Center for Outcomes Research) Palmer et al, 2004^124,^ ^128^ | To simulate the development of diabetes complications and the effect of new and existing interventions on clinical and cost outcomes | Third party payer | Markov using Monte Carlo simulation; 15 submodels each of which simulates different complications associated with DM | Newly diagnosed patients: baseline age 52y, A1c 9.1%, SBP 137 mm Hg, TC 212 mg/dl, HDL 39 mg/dl Switzerland; modeled using payer US costs United States | Direct medical costs; day-to-day DM management costs excluded; expressed in 2003 values in the US setting | 3% annual rate for costs; outcomes not discounted | Rates of MI for males and females are the same; most transition probabilities can be altered | Lifetime; 1 to 90y can be modeled | UKPDS, Framingham, other published sources | Discount rate 0–6%: no impact on relative outcomes | Hypothetical interventions that led to individual 10% improvements in A1c, SBP, TC, HDL | QALE: increased 1.72y with improvements in all of A1c, SBP, TC, HDL Lifetime costs of DM-related complications: decreased $14,533 with improvements in all of A1c, SBP, TC, HDL; improved A1c alone: decreased $10,800, SBP alone: decreased $7,048 | 10% improvements in A1c, SBP, TC, HDL, individually and in combination are likely to improve length and quality of life; most marked improvement with all 4; individually A1c had greatest gains in life expectancy and quality-adjusted life expectancy
UKPDS Model (United Kingdom Prospective Diabetes Study) Clarke et al, 2005,^125^ 2004,^131^ 2003,^130^ 2001^129^ | To estimate the economic efficiency of:; 1) Intensive BG and BP control in DM2 patients with HT; 2) Metformin in overweight patients | Health care purchaser | UKPDS Outcomes Model: based on an integrated system of parametric equations which predict probability of endpoints and Monte Carlo methods to predict occurrence of events; probabilistic discrete-time illness-death model | Newly diagnosed DM2 aged 25–65y; mean age 52.4y, 58% male; 81% Caucasian; n=3867 United Kingdom | Direct medical costs | 3.50% | UKPDS data and costs used; end-of-trial A1c and BP levels same for all patients (mean); i.e. assumes no continuing benefit of therapy | Lifetime (Clarke 2005) Within-trial data: mean duration 10.3y (Clarke 2003) | UKPDS for both outcomes and costs | Various | Intensive BG control with insulin or sulphonylurea versus conventional glucose control (mainly diet); 342 patients >120% of ideal body weight were assigned to metformin and compared with 411 overweight patients on conventional treatment Embedded study randomized 1148 patients with HT to BP<180/<105 vs n=758 with BP goal <150/85 mm Hg | QALY per patient modeled over lifetime: Intensive BG control: 0.15(-0.20, 0.49) Metformin therapy: 0.55(-0.10, 1.20) Tight BP control: 0.29(-0.14, 0.59) Probability of being cost-effective at a ceiling ratio of 20,000 Pounds per QALY: Intensive BG control: 74% Metformin therapy: 98% Tight BP control: 86% Life years gained per patient with metformin treatment versus conventional, within-trial data (Clarke 2001): 0.6 (95% CI, 0.0, 1.2) | Intensive BG control and BP control for persons with HT adds QALYs over lifetime; relatively cost-effective compared to many other accepted uses of health care resources

Abbreviations: ACE-I, angiotension converting enzyme inhibitor; BG, blood glucose; BP, blood pressure; CE, cost effectiveness; CHD, coronary heart disease; CVD, cardiovascular disease; DCCT, Diabetes Control and Complications Trial; DM, diabetes; DM2, type 2 diabetes; FPG, fasting plasma glucose; HDL, high density lipoprotein; HT, hypertension; LDL, low density lipoprotein; MI, myocardial infarction; N, number of participants; NA, Not applicable; QALE, quality-adjusted life expectancy; QALY, quality-adjusted life year; SBP, systolic blood pressure; TC, total cholesterol; UKPDS, United Kingdom Prospective Diabetes Study; US, United States; y, year

Table B9 Randomized Controlled Trials of Prediabetes (KQ3)

Study name Author, year Quality Rating | Country Setting Year(s) | Treatment groups Sample size | Length of follow-up | Inclusion criteria | Exclusion criteria | Participant selection | Population | Existing vascular disease | FBG (mg/dl) A1c (%) | Lipids (mg/dl) | Blood Pressure (mm Hg) | Other CVD risk factors | Intervention | Primary endpoint(s) | Outcomes | Adherence Withdrawals (%) | Adverse Events | Other Results
Diabetes Prevention Program DPP Research Group, 2002,^79^ 2000,^139^ 2005^140,^ ^145^ Fujimoto et al, 2000^141^ Good | US 27 centers 1996 - 1999 | I1: 1079 I2: 1073 C: 1082 | 2.8y (mean) (range, 1.8 to 4.6) For CVD outcomes: 3.2y (DPP 2005) | High risk for DM2: ≥ 25y, BMI ≥ 24 kg/m^2^ (≥ 22kg/m^2^ Asian American) FG of 95–125 mg/dl (5.3 – 6.9 mmol/l) (or ≤124 mg/dl for American Indian) and OGTT (2 hr-75-g) 140–199 mg/dl (7.8 to 11.0 mmol/l) | Recent MI, CHD symptoms, taking medication for glucose intolerance, serious illness | Volunteers, 4-step screening process including 3w run-in with trial of medication compliance | Race overall: Caucasian (55%); African American (20%); Hispanic (16%); American Indian (5%); Asian American (4%) Age y (SD): I1: 50.6 (11.3); I2: 50.9 (10.3); C: 50.3 (10.4) % male: I1: 32; I2: 33.8; C: 31 | Overall (%): History of MI: 32 History of stroke: 34 History of revascularization: 16 Metabolic syndrome: 53 (3 or more criteria from the National Cholesterol Education Program Adult Treatment Panel III) | FPG (mg/dl) (SD) I1: 106.3 (8.1) I2: 106.5 (8.5) C: 106.7 (8.4) A1c I1: 5.91 (0.51) I2: 5.91 (0.50) C: 5.91 (0.50) % Family history DM2 I1: 69.8 I2: 68.3 C: 70.1 | Overall: Elevated LDL (or taking medications): 44% Elevated TG (or taking medication): 28.8% | DBP (SD): I1: 78.6 (9.2) I2: 78.3 (9.5) C: 78.0 (9.2) SBP (SD): I1: 123.7 (14.8) I2: 124.0 (14.9) C: 123.5 (14.4) Overall HTN: 29.6% | BMI (kg/m2) (SD): I1: 33.9 (6.8) I2: 33.9 (6.6) C: 34.2 (6.7) Weight (kg) (SD): I1: 94.1 (20.8) I2: 94.3 (19.9) C: 94.3 (20.2) Waist circumference (cm) (SD): I1: 105.1 (14.8) I2: 104.9 (14.4) C: 105.2 (14.3) Waist-to-hip ratio (SD): I1: 0.92 (0.08) I2: 0.93 (0.09) C: 0.93 (0.09) | All participants encouraged to follow Food Guide Pyramid and a National Cholesterol Education Program Step 1 diet (referred to as standard lifestyle intervention) I1: Lifestyle/dietary changes: intensive 24w program, 16 lesson curriculum, attain and maintain ≥ 7% weight loss, physical activity 150 min/w I2: Metformin: 850 mg qd for 1m, then bid, standard lifestyle recommendations (written form and 20 min one-on-one session annually) C: Placebo bid, standard lifestyle recommendations | Progression to DM2; CVD and risk factors, changes in glycemia, insulin secretion, obesity, PA, diet, QOL, AEs | Crude incidence DM2 [cases per 100 person y]: C: 11; I2: 7.8; I1:4.8 (p <0.001) Incidence of DM2 was 58% lower (95% CI, 48–66%) for I1 and 31% lower (95% CI, 17–43) for I2 than placebo group (p< 0.05) Cumulative incidence DM2 at 3y (%): C: 28.9; I2: 21.7; I1: 14.4% NNT for 3y to prevent 1 case of DM2: I1 6.9 (95% CI, 5.4 – 9,5); I2 13.9 (95% CI, 8.7 – 33.9) Cumulative incidence of CVD and event rate: NSD among groups, but the few CVD events did not provide adequate statistical power (DPP 2005) Prevalence of HTN at 3y: I1 23%, I2 32%, C 31% (between-group p-value <0.04) Subgroup analyses (post hoc): NSD among treatments for sex, race Intervention more effective among persons with lower BG at baseline; metformin more effective with increased BMI Lifestyle group: achieved goal of ≥ 7% weight loss at most recent visit: 38%; 150 min/w of activity: 58% Average weight loss (kg): I1 5.6, I2 2.1, P 0.1 Large waist circumference at baseline was a predictor of diabetes in the placebo and lifestyle groups (Cox hazard ratio per 1 SD in placebo and lifestyle 1.43 and 1.49 for men and 1.29 and 1.53 for women) Lifestyle intervention was more effective in decreasing diabetes incidence with increasing age (p=0.007); metformin group showed trend toward higher diabetes incidence in older participants (p=0.07) DPP women and men were less inactive than the NHANES III sample for most age, BMI and rate/ethnic groups | Medication adherence: I2: 77%; C: 72% (P <0.001) 97% were given full dose of pills, 3% only 1 tablet qd to reduce side effects I1: 50% achieved weight loss of 7% or more at the end of the 24w curriculum period, 38% at the most recent visit; 74% did at least 150 min of activity per week at 24w, 58% at most recent visit I1: Dietary change/daily energy intake kcal decreased (mean/SD) of 450/26; I2: 296/23; C: 249/27) | GI symptoms (no. per 100/person-y): I1: 12.9* I2: 77.8* C: 30.7 Musculoskeletal symptoms (no. per 100/person-y): I1: 24.1* I2: 20 C: 21.1 Hospitalization (%): I1: 15.6 I2: 8.4 C: 7.9 Death (no. per 100/person-y): I1: 0.10 I2: 0.20 C: 0.16 *p<0.0167 compared to control
DREAM (Diabetes Reduction Assessment with Ramipril and Rosiglitazone Medication) DREAM Trial Investigators, 2004,^147^ 2006^82,^ ^148^ Good | 21 countries (191 clinical sites) Screened between July 2001 – August 2003 | I: 2365 C: 2634 | 3y (median) | Age ≥30y IFG: FPG ≥110 and <126 mg/dl (≥6.1 mmol/l and <7.0 mmol/l) and a 2-h plasma glucose <200 mg/dl (<11.1 mmol/l) after a 75-g OGTT; or IGT: FPG <126 mg/dl (<7.0 mmol/l) and 2-h plasma glucose ≥140 and <200 mg/dl (≥7.8 mmol/l and <11.1 mmol/l) [revised criteria in 2003 to include isolated IFG 110 to <126 mg/dl (6.1 to <7.0 mmol/l) and 2-h plasma glucose <140 mg/dl (<7.8 mmol/l)] | Current use of ACE-I and/or thiazolidinediones or the inability to discontinue; previous ischaemic CVD or uncontrolled hypertension requiring medication, history of diabetes, renal or hepatic disease, major illness, use of experimental drug, pregnant, psychiatric disorder, disease or meds that affect glucose tolerance, substance use | Community recruitment, wide variety of strategies that varied by site and country (advertising, news reports, screening fairs, mailings, referral from physicians, etc.); 24,872 screened, 5268 randomized | Geographic distribution (%): I: North America (41.1), South America (21.4), Europe (20.8), India (12.5), Australia (4.2) C: North America (40.5), South America (21.7), Europe (21.1), India (12.6), Australia (4.1) Age y (SD): I: 54.6 (10.9); C: 54.8 (10.9) % male: I: 41.7; C: 39.9 Isolated IGT (%): 57 Isolated IFG (%): 14 Both IGT and IFG (%): 29 | None (excluded) | FPG (SD): I: 140 [5.8 mmol/l (0.7)] C:104 [5.8 mmol/l (0.7)] A1c (%): NR | Statin or fibrate: I: 14.8%; C: 14.8% | DBP (SD): I: 83.3 (10.6); C: 83.5 (10.9) SBP (SD): I: 135.9 (17.9); C: 136.3 (18.8) HTN history: I: 44%; C: 43% | Weight (kg) (SD): I: 84.8 (19); C: 85 (18.9) BMI (kg/m^2^) (SD): I: 30.8 (5.6); 31 (5.6) Waist-to-hip ratio (men;women) (SD): I: 0.96 (0.07); 0.86 (0.07); C: 0.96 (0.07); 0.87 (0.09) Waist circumference (cm) (men;women) (SD): I: 101 (14); 96 (14); C: 102 (13); 96 (14) Current or former tobacco use: I: 43.9%; C: 45.3% | C: matching placebo I: 4 mg qd rosiglitazone for 2m, then 8 mg qd Also randomized to ramipril 15mg qd or placebo on 2×2 factorial design | Primary endpoint: composite of incidence of diabetes and death; Secondary outcomes included CV events, renal events, changes in glucose tolerance and other measures of beta cell functions | Rosiglitazone: New onset DM2 or death: HR: 0.40, 95% CI 0.35–0.46; P<0.0001; Deaths: HR; 0.91, 95% CI, 0.55–1.49; p=0.7 New onset DM2: HR 0.38 (95% CI, 0.33 – 0.44), p<0.0001 Rates of progression to diabetes: I: 280 (10.6%) vs. C: 658 (25%) (p< 0.0001) Both groups had similar frequency of the composite cardiovascular outcome (myocardial infarction, stroke, cardiovascular death, new angina, revascularization, hypertension) and all but one of the components of the composite; Heart failure: HR 7.03 (95% CI, 1.60 – 30.9), p=0.01 Ramapril: New onset DM2 or death: HR: 0.91 (95% CI, 0.81 – 1.03), p=0.15 New onset DM2: HR: 0.91 (95% CI, 0.80 – 1.03) CV events: NSD between groups | Stopped drug on or before last visit: I: 654; C: 566 [underlined: Reasons for stopping:] Patient refusal: I: 18.9%; C: 16.7% Edema: I: 4.8%; C: 1.6% Physician's advice: I: 1.9%; C: 1.5% Weight gain: I: 1.9%; C: .6% Hypoglycemia: I: 1, C: 3 Total lost to follow-up: I: 772; C: 601 % adherent at the end of the study: I: 71.6, C: 75.1 I: 28.5%; C: 24.3% stopped taking pills at any time I: 23.6%; C: 20.2% were not taking pills at their last visit | Peripheral edema at final visit: I: 6.8%; C: 4.9% (p=0.003) | Effects of rosiglitazone were the same in all regions of the world, different ethnic groups, in both sexes, and across all ages Every 1000 people treated with rosiglitazone for 3y, 144 cases of diabetes will be prevented, with an excess of 4–5 cases of congestive heart failure
Finnish Study Tuomilehto et al, 2001^138^ Lindstrom et al, 2006,^153^ 2003,^149,^ ^150^ Eriksson et al, 1999^151^ Laaksonen et al, 2005^152^ Fair | Finland 5 primary care centers November 1993 – June 1998 | I: 265 C: 257 | 3.2y (mean) Lindstrom 2006: Post-intervention 3y (median); total follow-up 7y (median); Intervention discontinued after 4y (median) | Ages 40–65y; BMI >25 kg/m^2^ IGT: plasma glucose concentration of 140 to 200 mg/dl (7.8 to 11.0 mmol/l) 2-h after 75 g of glucose (FPG <140 mg/dl) | DM2, chronic disease, psychological or physical disabilities | Screening members of high risk groups (e.g. 1st degree relatives of patients with DM2 and opportunistic screening) | Race: NR Age y (SD): I: 55 (7); C: 55 (7) % male: I: 34.34 C: 31.52 | NR | FPG (mg/dl) (SD): I: 109 (14); C: 110 (13) A1c (SD): I: 5.7 (0.6); C: 5.6 (0.6) | TC (SD): I: 215 (37); C: 215 (35) HDL (SD): I: 46 (12): C: 47 (11) TG (SD): I: 154 (72); C: 158 (69) % on lipid meds: I: 5%; C: 7% | DBP (SD): I: 86 (9); C: 86 (10) SBP (SD): I: 140 (18); C:136 (17) % on anti-HTN meds: I: 29%; C: 31% | BMI (SD): I: 31.3 (4.6); C: 31 (4.5) Waist circumference (cm) (SD): I: 102 (11); C: 100.5 (10.9) Hip (cm) (SD): I: 110.4 (10.5); C; 109.4 (9.7) | C: 2-page leaflet and oral discussion on diet and exercise at baseline and annual visits; 3d food diary at baseline and annual visits I: 7 nutritionist sessions in y 1 then 1 session every 3m; 3-day food diary 4 times a y; detailed tailored advice on goals; individual counseling; supervised resistance training; nutrient intakes computed; decrease weight 5+%, fat intake <30% total calories, increase fiber, exercise 30 min qd | Progression to diabetes Secondary endpoints: Weight loss, BMI, waist, FPG, A1c, TC, HDL, TG Lindstrom 2006: Incidence of DM2 at 7y follow-up | Cumulative incidence DM2 58% lower in I than in C: HR: 04; 95 % CI, 0.3 to 0.7; p<0.001) at Y6 Cumulative incidence DM2: number (%): Y1: I: 5 (1.9); C: 16 (6.1) Y2: I:15 (6.3); C: 37 (14.4) Y3: I: 22 (9.1); C: 51 (20.9) (p=0.0001) Y4: I: 24 (10.9); C; 53 (23) Y5: I: 27 (20); C: 57 (34.4) Y6: I: 27 (20); C: 59 (42.6) Absolute incidence DM2 (per 100 person-y): I: 32, C:78 DM2 diagnosed in 86 subjects; I: 27; C: 59; Absolute incidence of DM2 in I: 32/1000; C: 78/1000 For men, incidence of diabetes was reduced by 63% (95% CI, 18 to 79%; P= 0.01) and in women by 54% (95% CI, 26 to 81%; p= 0.008) 22 subjects with IGT can be treated for 1y with this intervention, or 5 subjects for 5y, to prevent one case of diabetes. Laakensen 2005: After adjusting for other variables, subjects in the upper 1/3 of the change in total LTPA were 80% less likely to develop diabetes than those in the lower 1.3 (RR 0.20, 95% CI 01.–0.41; P < 0.001) Lindstrom 2006: Incidence rate 7y follow-up: 4.3 (95% CI 3.4 –5.4) and 7.4 (95% CI 6.1 –8.9) per 100 person y in the I and C group, respectively (p=0.0001 log rank test); HR 0.57(0.43–0.76) Incidence rates during the 3y post-intervention period: I: 4.6 and C: 7.2 (p=0.0401) (=36% reduction in relative risk) Cumulative incidence of DM2 at Y6 was 23% in the I group and 38% in the C group [ARR of 15% (7.2 – 23.2)]. NNT to prevent one case of DM2 by lifestyle intervention = 22 for 1y | Rate of adherence to exercise portion of I ranged from 50–85% in different centers Withdrawals (number): I: 23; C: 17 (9 could not be contacted, 3 severe illness, 1 died, 27 for personal reasons) Lindstrom 2006: Follow-up 7y: loss to follow-up I: 10%, C: 8% (p=0.362) | NR
Heymsfield et al, 2000^80^ Fair-poor | US and Europe 39 clinical research centers 1992 - 1995 | I: Lifestyle/orlistat 359 C: Lifestyle only 316 | 2y (attained by 69% of each of C and I group) | Age >18y, BMI of 30–42, adequate contraception in women of childbearing years, absence of weight loss (>4kg) in the previous 3m IGT: 2-h BG 140 to 198 mg/dl (7.8 to 11.0 mmol/L); diabetes: 2-h BG > 198 mg/dl(>11.0 mmol/l) | Had stopped smoking in the last 6m, significant cardiac, renal, hepatic, gastrointestinal, psychiatric, or endocrine disorders; drug treated DM2, history or presence of substance abuse, excessive intake of alcohol, or used medications that alter appetite or lipid levels | Run-in period used to stratify by capacity to lose weight | Age: 43.9y Weight: I: 99.8 kg, C: 99.0 | None existing | I: 109 (6.04 mmol/l) C: 107 (5.92 mmol/l) | Varied among the 3 studies | Varied among the 3 studies | NR | All subjects: 1. Diet: 30% of calories from fat for 4w run-in period, 2. Exercise: Y 1: energy intake was prescribed for each patient based on an estimated daily maintenance energy requirement formula, Y 2: weight maintaining diet/exercise regimen Drug: I: Orlistat 120 mg tid 52 or 104w; C: placebo tid | Weight loss | Change in OGTT status at end of the study: (%) (from Heymsfield) IGT at baseline: normal I 71.8%, C 49.1%; IGT: I 25.4%, C 43.4%; DM2: I 3.0%, C 7.6%; p=0.04 between groups Normal at baseline: normal I 93.4%, C 88.0% | Completers: I: 246/333; C: 217/281 (NSD) | Sjostrom: overall AEs: I 94%, C 82% GI effects more common with I and generally short duration Serious AEs: I 25, C 24 | Weight change
Indian Diabetes Prevention Programme Ramachandran et al, 2006^154^ Fair | India March 2001 – July 2002 | C-1: 136 I-2 (lifestyle modification): 133 I-3 (metformin): 133 I-4 (lifestyle and metformin): 129 | 3y | IGT (WHO criteria): (FG <126 mg/dl [<7.0 mmol/l]; 2-hr glucose 140–199 mg/dl [7.8–11.0 mmol/l]; 35–55y | Major illness; diabetes | Community-based: middle class, workplace service organizations, advertisement for volunteers 10,839 screened, 12.3% had IGT of those, 77% had OGTT | Race: Asian Indian Age y (SD): C: 45.2 (5.7); I-2: 46.1 (5.7); I-3: 45.9 (5.9); I-4: 46.3 (5.7) % male: C: 76%; I-2: 78%; I-3: 80%; I-4: 81% | None (major illness excluded) | FPG (SD): C: 99 [5.5 mmol/l (0.8)] I-2: 97 [5.4 mmol/l (0.7)] I-3: 97 [5.4 mmol/l (0.8)] I-4: 97 [5.4 mmol/l (0.8)] A1c (SD): C-1: 6.2 (0.5) I-2: 6.1 (0.5) I-3: 6.2 (0.6) I-4: 6.2 (0.6) | TC (SD): C: 197 [5.1 mmol/l (0.9)]I-2: 201 [5.2 mmol/l (0.9)]I-3: 201 [5.2 mmol/l (1.0)]I-4:197 [5.1 mmol/l (0.9)]TG: C-1: 168 [1.9 mmol/l (1.2)]I-2: 177 [2.0 mmol/l (1.4)]I-3: 150 [1.7 mmol/l (0.9)]I-4: 150 [1.8 mmol/l(0.9)] % on lipid meds: NR | DBP (SD): C-1: 76.2 (8.6) I-2: 74.4 (8.1) I-3: 74.4 (9.2) I-4: 74.9 (8.1) SBP (SD): C-1: 124.1 (16) I-2: 121.5 (14.4) I-3: 120.7 (15.9 I-4: 122.4 (14.3) % on anti-HTN meds: NR % with HTN: Table 1 | Smokers (%) (SD): C: 36 (26.5) I-2: 29 (21.8) I-3: 23 (17.3) I-4: 27 (20.9) BMI (kg/m^2^) (SD): C-1: 26.3 (3.7) I-2: 25.7 (3.3) I-3: 25.6 (3.7) I-4: 25.6 (3.3) | C: Placebo I-2: LSM; advice on healthy diet and regular physical activity at first visit and by phone or letter after 2w; personal motivation phone calls every m; in-person sessions every 6m I-3: Metformin 250 mg bid I-4: LSM plus Metformin | Incidence of DM2 (FBG ≥ 126 mg/dl and/or 2-h PG ≥ 200, confirmed by OGTT) | Cumulative incidence of DM2 at Y3 C-1: 55% I-2: 39.3% I-3: 40.5% I-4: 39.5% The NNT for 3y to prevent one case of DM2: I-2: 6.4 I-3: 6.9 I-4: 6.5 ARR in DM2 (%): I-1 (15.7), I-2 (14.5), I-3 (15.5) RRR (%, 98% CI): I-1 28.5 (20.5, 37.3), I-2 26.4 (19.1, 35.1), I-3 28.2 (20.3, 37.0) | Overall completion rate: 95.1 C: 98.5 I-2: 91 I-3: 96 I-4: 94.6 | Cardiovascular events (no. of events): C: 2 I-2: 4 I-3: 0 I-4: 5 Death: C-1: post surgery (cerebrovascular accident) I-2: hepatic encephalopathy I-4: post thyroid surgery Symptoms of hypoglycemia: reported when the metformin dose was briefly at 500 mg bid Symptoms did not occur when reduced to 250 mg bid | See paper for details
Kosaka et al, 2005^81^ Fair | Japan, Toranomon Health Medical Center, Hospital 1990 - 1992 | I: 102 C: 356 | 4y | 30–69y IGT: FPG (mg/dl): <140 and a 2-h PG (2hPG) value of 160–239 on 100-g OGTT | Previous history of diabetes; diagnosed or suspected neoplasm, disease of the liver pancreas, endocrine organs or kidney; history of ischemic heart disease or cerebrovascular disease | Health screening program for government employees | Race: Japanese Age y: In 50's: I: 56.9%; C:53.9% % male: 100 | None | FPG (mg/dl) (SD): I: 113 (7.6) C: 112 (8.5) A1c (%): NR | TC (SD): I: 213 (42); C: 214 (38) HDL (SD): I: 52 (14); C: 51 (13) TG (SD): I: 137 (88); C: 138 (78) % on lipid meds: NR | SBP (SD): C: 124 (17) I: 123 (18) DBP (SD): C: 79 (11) I: 78 (13) | BMI (kg/m^2^) (SD): I: 24 (2.3) C: 23.8 (2.1) Family history of DM: I: 41.2 % C: 42.4 % | C: At start and every 6m visit: BMI >24kg/m^2^: advised to take 5–10% smaller meals, increase PA BMI <24kg/m^2^: at start and every 6m, advised to not gain weight by dieting and to keep up PA I: At start and every 3–4m visit: BMI ≥ 22 kg/m2: informed of desirable body weight, advised to weigh themselves weekly, decrease food by 10%, increase vegetables, increase PA to 30–40 mins qd BMI < 22Kg/m^2^: advised to maintain their present weight and not gain weight Review of current eating patterns, diet advice, alcohol consumption, eating out, and PA were provided | Primary outcome: Incidence of DM2, FPG Secondary outcome: A1c, body weight, BMI | Cumulative incidence of diabetes in the intervention group during the 4y I (3%) vs. C (9.3%) (between-group p=0.043). (67.4%) Reduction in diabetes in I group | % of participants who completed 4y follow-up: C: 91%; I: 93.1% | NR | The incidence of diabetes was significantly higher in those with higher baseline FPG (11.8%) than in those with lower FPG (5.4% p=0.044)
Pan et al, 2003^156^ Fair | China 15 medical centers | I: 126 C: 132 | 16w | IGT (WHO criteria): 2 h-postprandial plasma glucose ≥140 mg/dl, <200 mg/dl and FPG <125 mg/dl; age 35–70y, BMI >19 and ≤34kg/m^2^ | Pregnant or lactating women, DM2, childbearing age with no contraception, major diseases, major CV event in last 6m, medication that would impair intestinal mobility, other medications within the last 3m, certain BP and TG parameters, emotional disorder or substance abuse treatment within the last 30d, HTN | Methods of recruitment NR | Race: Chinese Age y (SD): I:53.4 (8.63); C: 55.6 (8.31) (between-group p=0.034) % male: I: 39.2; C: 40.9 | NR; excluded those with major cardiovascular events in the last 6m | Maximum PP plasma glucose (mg/dl) (SD) I: 185.5 (35.5); C: 187.3 (29.7) A1c (%): I: 6.51 (0.72), C: 6.61 (0.62) | TC (SD): I: 199.1 (40.2); C: 201.8 (42.8) LDL (SD): I: 120.9 (33.9); C: 122.4 (34.4) HDL (SD): I: 53.6 (13.2); C: 53 (11.6) TG (SD): I: 138.2 (77.3); C: 144.6 (68.1) % on lipid meds: NR | DBP (SD): I: 78 (7.8); C: 78.1 (8.4) SBP (SD): I: 125.4 (14.1); C: 126.8 (14.9) % on anti-HTN meds: NR | Weight (kg) (SD): I: 67.5 (10.4); C: 68.0 (11.6) | I: acarbose 50 mg qd for 1 w, 50 mg bid for 2 w, 50 mg tid to 16w C: Placebo | Primary outcome: PPGe, serum insulin profile, postprandial glucose profile Secondary outcome: maximum PP insulin concentration, lipid profile, blood pressure, A1c, body weight, conversion to DM2 | Incidence of diabetes I: 7 subjects (5.6%); C: 12 subjects (9.5%); between-group p=0.245 | Compliance: I: 98.4%; C: 95.5% Withdrawals (number): I: 2, C: 3 | Overall drug-related AEs: I: 35.7%; C: 18.2% (differences mainly due to GI effects) Flatulence: I; 15.9%; C: 6.1%; Abdomen enlarged I: 13.5%; C: 3.8% Diarrhea: I: 9.5%; C: 2.3% Serious AEs: I: 1 cerebral infarction, 1 hepatitis, 1 glaucoma C: 1 tenosynovitis | I group showed significant reductions in PPG, serum insulin concentrations, and body weight when compared to placebo TG was the only lipid parameter to be reduced by intervention
STOP-NIDDM Trial (Study TO Prevent Non-Insulin-Dependent Diabetes Mellitus) Chiasson et al, 1998,^158^ 2002,^136^ 2003^159^ Fair | International, multi-center, (Canada, Germany, Austria, Nordic countries, Israel, Spain) 1995 - 1998 | I: 714 C: 715 | 3.3y (mean) 1.15y (SD) | Ages 40–70y; BMI 25–40 kg/m^2^; IGT according to WHO; ≥140 and <198 mg/dl (≥7.8 and <11.1 mmol/l) (2-hr 75 g glucose) and FPG of 101–140 mg/dl (5.6–7.7 mmol/l) | CV event in the last 6m; specific/abnormal levels of serum creatinine, fasting serum TG, liver enzymes, or thyroid stimulating hormone; treated in the last 3m with glucocorticoids, beta-blockers, thiazide diuretics, or nicotine acid; taking drugs that would interfere with gastrointestinal mobility or absorption | Volunteer, 1st degree relatives of DM2 patients | Race (%): Caucasian: I: 97; C: 98 Country (%): Canada: 40; Germany/Austria 27; Nordic 24; Spain 5; Israel: 5 Age y (SD): I: 54.3 (7.9); C: 54.6 (7.9) % male: I: 48; C: 50 | History of CVD %: I: 5; C: 4.7 CV meds (%): I: 21.4; C: 20.1 | FPG (pmol/l) (SD) I: 99.34 (57.64) C:98.13 (56.78) 2h FG (SD): I: 606.37 (437.46) C: 597.99 (414.38) A1c: NR | TC (SD): I: 196 [5.76 mmol/l (1.04)]; C: 217 [5.61 mmol/l (0.99) HDL (SD): I: 46 [1.19 mmol/l (0.32)]; C: 45 [1.17 mmol/l (0.33)] LDL (SD): I: 142 [3.66 mmol/l (0.91)]; C: 137 [3.54 mmol/l (0.90)] TG (SD): I: 183 [2.07 mmol/l (1.10)]; C: 183 [2.07 mmol/l (1.17) Overall: 58% dyslipidemia | DBP (SD): I: 82.8 (9.4 ) C: 82 (9.3) SBP (SD): I: 131.4 (16.3) C: 130.9 (16.2) HTN: (%): I: 52; C: 50 | BMI: (kg/m2) (SD): I: 31 (4.3); C: 30.9 (4.2) Weight (kg) (SD): I: 87.6 (15.3); C: 87.1 (14.1) Waist circumference (SD): I: 102.1 (11.7); C: 102.2 (11.2) Smoking (%): I: 12; C: 14 | All participants seen every 2m; at start received weight reduction/weight maintenance/exercise advice; dietician counseling before randomization and once every y; food and exercise, 3d diary review at each visit I: Acarbose, start at 50 mg qd, up to 100 mg tid C: Placebo tid | Progression to DM2, development of major CV events and hypertension | Progression to DM2: I: 221/682 (32%); C: 285/686 (42%): hazard ratio 0.75 (95% CI 0.63–0.90; between group value = 0.0015) Drug benefit regardless of age, sex, or BMI Incidence of DM2/person y: I: 101/1000; C: 121/1000 [risk difference of 9.1% over 3.3y] (no p value given) Any CV Event: I: 15/682; C: 32/686 (between-group p value = 0.02); hazard ratio: 0.51(0.28 – 0.95) acarbose had RRR of 49% and absolute RR of 2.5%; control rate of CV events 1.4%/y MI: I: 1/682; C: 12/686; Hazard ratio: 0.09 (0.01–0.72) (between-group p value=0.02) HTN: Hazard ratio 0.66 (0.48–0.89) Angina, revascularization procedures, cardiovascular death, congestive heart failure, cerebrovascular event or stroke, or peripheral vascular disease: NSD NNT to prevent 1 CV events: 40 with IGT over 3.3y | Withdrew early: I: 211/682; 130/686 Withdrew due to AEs (%): I: 19; C: 5 Gastrointestinal AEs (mild/ moderate) (%): I: 13; C: 3* flatulence: I: 9; C: 1 diarrhea: I: 5; C: 1 abdominal pain: I: 3; C: 1 Death (%): I: 1; C: <1 Loss to follow-up (number) (%): I: 18 (3); C: 17 (2%) * (between group value=0.0001) | Overall: I: 98; C: 95 Gastrointestinal: I: 83; C: 60 Flatulence: I: 68; C: 27 Diarrhea: I: 32; C: 17 Abdominal pain: I: 17; C: 12 Dyspepsia: I: 7; C: 9 Nausea: I: 5; C: 5 Constipation: I: 4; C: 5 Gastroenteritis: I: 4; C: 5 General symptoms: I:58; C: 62 Cardiovascular: I: I: 31; C: 40 Respiratory: I: 32; C: 39 Musculoskeletal: I: 34; I: 39 Metabolic and Nutritional: I: 31: C: 32 Nervous: I: 27; C: 31 Urogenital: I: 25; C: 28 Skin: I: 21; C: 24 Haematological / lymphatic: I: 4; C: 6 Endocrine: I: 4; C: 4 No serious events related to the study drug
Swinburn et al, 2001^157^ Fair-poor | New Zealand 41 work sites 1988 - 1990 | I: 66 C: 70 (completed y intervention) Original survey sample 4,833; study group approached 2y post original survey | 5y | “Glucose intolerant group” who could be contacted 2y after original study: 2-h glucose 126–198 mg/dl (7.0 –11.0 mmol/l); Ages ≥ 40y | NR | Participants in workforce survey with “glucose intolerance” (4.8% of original survey) | Race: I: 67% European, 20% Pacific Islander, 10% Maori, 3% other C: 76% European, 13% Pacific Islander, 8% Maori, 4% other Age y (SEM): I: 52.5 (.8); C: 52 (.8) % male: I: 67; C: 80 | NR | FPG I (SEM): 121 (SEM) [6.7 mmol/l (0.2)] C (SEM): 119 (SEM) [6.6 mmol/l (0.2)] A1c (%): NR | NR | NR | BMI (kg/m^2^) (SD): I: 29.08 (0.55); C: 29.17 (0.48) Weight (kg) (SD): I: 85.46 (1.80); C: 84.33 (1.55) Waist circumference (cm) (SD): I: 100.48 (1.42); C: 101.60 (1.28) | I: RF structured diet program; monthly small group meeting focused on education, goal-setting & self-monitoring C: CD usual; general dietary advice about health choices only at study entry | Weight, exercise, diabetes, IGT and IFG (WHO criteria) | A smaller proportion of participants had DM2 in the RF group compared to the CD group at 1y (47% compared to 67%) (p-value NR) Incidence DM2 or IGT at 1y among all participants (DM2, IGT, normal): I < C (p=0.015) NSD in incidence among groups at 2, 3, or 5y Data are for entire population, of which only 31% had IFG or IGT | 136 (77%) completed 1y intervention; 104 at 2y (76% of 136); 99 at 3y (73%); 103 at 5y (76%) Compliance assessed by attendance at monthly meetings and completion of diet diaries 40 participants did not complete the study: 4 died, 1 became pregnant, 7 developed serious illnesses, 4 moved, 24 dropped out | NR | Intervention showed a significant effect on OGTT (p= 0.015) at 1y No intervention effect at 2, 3, or 5y No overall effect of diet on FBG, a significant effect on 2-h glucose over the period (p<0.0001) Compliers showed a significantly lower FBG (p=0.041) and 2-h BG 5 y (p= 0.023) Data are for entire population (IGT, IFG, normal)
Watanabe et al, 2003^155^ Fair | Japan, Tokyo Health Clinic 2000 - 2001 | I: 86 C: 87 | 1y | High risk for DM2: [FPG >110 and <126 mg/dl (>6.1 and <7.0 mmol/l); 2-h PG >140, <200 mg/dl (>7.8, < 11.1 mmol/l); 1-h plasma glucose ≥180 mg/dl (≥10 mmol/l)], male, aged 35–70y, living in metropolitan Tokyo | Normal FPG DM2; hypoglycemic, cholesterol lowering or antihypertensive drugs; refused to participate on questionnaire | Annual health check-up in health examination center or workplace | Race: NR Age y (SD): I: 52.2 (7.4); C: 54.9 (6.7) % male: NR | NR | FPG (SD): I: 110 [6.1 mmol/l (0.55)] C: 99 [5.5 mmol/l (0.55) ] A1c (%): NR | TC (SD): I: 201.3 (32); C: 199.5 (37) HDL (SD): I: 52.2 (12.2); C: 52.8 (15.2) TG (SD): I: 128.6 (64); C: 127.1 (71.1) % on lipid meds: NR | DBP (SD): I: 77.4 (10.2); C: 76.4 (10.8) SBP (SD): I: 122.3 (14.4); C: 121.1 (14.3) % on anti-HTN meds: NR | BMI (kg/m^2^) (SD): I: 24.5 (3.0); C: 21.2 (2.7) Smokers: I: 28%; C: 39% | I: NDE program: individual dietary counseling 1m post exam plus mailings at 6m, focus to decrease energy intake at night, increase fish, whole grains, vegetables C: CDE program: general oral and written results of their health exam; leaflet with prevention of lifestyle related diseases | % change 2-h PG | Incidence in diabetes between the two groups was not significant (data NR) | 156 (90.2%) completed y 1 17 subjects left the study: 1 changed jobs, 5 retired (I: 1; C: 4); 1 for financial reasons C; 10 could not be located (I: 6; C: 4) | NR | % changes in FPG or 1-h PG between groups; 2-h PG was significantly different (P <0.001) [I: -8.2 (1.9); C: 11.2 (3.0)]; Of note: FPG and 2-h PG were significantly different between groups at baseline (P<0.05 and P<0.01, respectively)
XENDOS Study (XENical in the prevention of Diabetes in Obese Subjects) Torgerson et al, 2004,^161^ 2001^160^ Fair-poor | Sweden 22 Medical Centers 1997 - 2002 | I: Lifestyle/orlistat 1,650 [350 IGT]C: Lifestyle only 1,655 [344 IGT] ITT population: I: Lifestyle/orlistat 1,640 C: Lifestyle only 1,637 | 4y | 30–60y NGT: 2-h 75 g OGTT whole blood glucose <180 mg/dl (<10.0 mmol/l) and fasting whole blood glucose 121mg/dl (<6.7 mmol/l); or IGT: fasting whole blood glucose <121 mg/dl (<6.7 mmol/l) and 2-h whole blood glucose 121–180 mg/dl (6.7–10.0 mmol/l]; BMI ≥30kg/m^2^ | DM2, myocardial infarction in last 6m, change in body weight >2 kg from screening to baseline measurements, SBP > 165 mm Hg or DBP > 105 mm Hg on 2 visits, cholelithiasis, gastrointestinal surgery for weight reduction, peptic ulcer, gastrointestinal disease, pancreatic disease, malignancy, psychiatric or neurologic disorder, abuse or previous participation in any trial of orlistat | Advertisement, volunteers, 22 medical centers | Race: NR Age y (SD): I: 43 (8); C: 43.7 (8) % male: I: 44.8; C: 44.7 | None existing | FBG (SD): I: 83 [4.6 mmol/l (0.6)] C: 81 [4.5 mmol/l (0.6)] A1c (%): NR | TC (SD): I: 224 [5.8 mmol/l (1.0)]; C: 224 [5.8 mmol/l (1.0)] LDL (SD): I: 143 [3.7 mmol/l (0.9)]; C: 147 [3.8 mmol/l (0.9)] HDL (SD): I: 46 [1.2mmol/l (0.3)]; C: 46 [1.2 mmol/l (0.3)] TG (SD): I: 168 [1.9 mmol/l (1.0)]; C: 168 [1.9 mmol/l (1.2)] % on lipid meds: NR | DBP (SD): I: 82 (10); C: 82.3 (10) SBP (SD): I: 130.8 (15.8); C:130.4 (15.4) % on anti-HTN meds: NR | BMI (kg/m^2^) (SD): I: 37.3 (4.2); C: 37.4 (4.5) Weight (kg) (SD): I: 110.4 (16.3); C: 110.6 (16.5) Waist circumference (cm) (SD): I: 115.0 (10.4); C: 115.4 (10.4) | All subjects: Dietary counseling every 2w 1st 6m, then monthly; exercise encouragement [Diet: ~800 kcal/d deficit, 30% of calories from fat, ≤300 mg cholesterol/d] C: Placebo tid I: Orlistat 120 mg tid | Primary: time to onset of DM2; change in body weight Secondary: anthropometric measurements, metabolic profile, time to onset of IGT | Main analysis: I group showed significantly decreased progression to DM2 compared with C plus lifestyle change (between group p-value = 0.0032); Cumulative incidence rates after 4y: I:6.2% vs. C: 9.0% Hazard ratio (0.627 [95% CI 0.455–0.863]); risk of DM2 with I vs C Sub-analysis: In patients with IGT at baseline: I showed significant decreased progression to DM2 when diagnosed on the basis of a single test (between group p-value = 0.0024) and by repeat positive testing (between group p-value =0.0171); those with IGT were more likely to develop DM2 over 4y than those with NGT (hazard ratio 10.60 [95% CI 7.30–15.40] p<0.0001) | Adherence: ITT population: diet and exercise similar in both groups over 4y period Study drug administration: I: 93.3%; C: 92.8%, NSD. Withdrawals: I: 52%; C: 34% completed the study, between group p-value < 0.0001 Reasons: Refusal of treatment (I: 14%, C: 20%); insufficient therapeutic response (I: 8%, C: 19%) | No deaths were attributed to study medication 4% C vs. 8% I withdrew due to AEs or laboratory abnormalities (mostly gastrointestinal events) More mild to moderate gastrointestinal events in 1st y with I compared to C group (91% vs. 65% in YR 1; 36 vs. 23% in YR 4) At least one serious AE (I: 15%; C: 13%); 2% serious gastrointestinal events in I and C

Abbreviations: ACE-I, angiotension converting enzyme inhibitor; AE, adverse event; ARR, absolute risk reduction; BG, blood glucose; bid, two times daily; BMI, body mass index; BP, blood pressure; C, control group; CD, Controlled Diet; CDE, conventional dietary education; CHD, coronary heart disease; CV, cardiovascular; CVD, cardiovascular disease; d, day; DBP, diabolic blood pressure; DM, diabetes; DM2, type 2 diabetes; DPP, Diabetes Prevention Program; FBG, fasting blood glucose; FG, fasting glucose; FPG, fasting plasma glucose; GI, gastrointestional; h, hour; HDL, high density lipoprotien cholesterol; HR, hazard ratio; HTN, hypertension; I, intervention group; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; ITT, intention to treat analysis; LDL, low density lipoprotein cholesterol; LSM, lifestyle modification; LTPA, leisure time physical activity; m, months; MI, myocardial infarction; meds, medicines; min, minutes; NDE, new dietary education; NGT, normal glucose tolerance; NHANES, National Health and Nutrition Examination Survey; NNT, number needed to treat; NR, not reported; NSD, no significant difference; OGTT, oral glucose tolerance test; PA, physical activity; PG, plasma glucose; PP, postprandial plasma; PPG, postprandial plasma glucose; q, every; QOL, quality of life; RF, reduced fat; RRR, relative risk reduction; SBP, systolic blood pressure; SD, standard deviation; SEM, standard error of the mean; TC, total cholesterol; TG, triglycerides; tid, three times daily; US, United States; w, week; WHO, World Health Organization; y, year.

Table B10 Studies Modeling Treatment of Prediabetes (KQ3)

Model Author, year (in date order) | Objective | Type of screening or perspective | Type of model | Population; Country | Included costs | Discount rate | Base case assumptions | Time horizon | Data sources | Sensitivity analyses | Intervention | Outcomes | Conclusions | Quality assessment
Segal et al, 1998^173^ | To determine the CE of a lifestyle intervention for DM2 prevention relative to other health programs | Health care system | Markov | Based on Australian cohort; cohorts with IGT, normoglycemia and DM2 Australia | Program costs and direct medical costs | 5%/y for benefits and costs | Reduction in LE for DM2 is 2–3y and 0.5–3y for excess weight compared to normoglycemic and BMI<25; cost of DM2/y is $1800 Australian $; only benefits of program relate to effects on incidence of DM2 and life years; QOL ignored (insufficient data); lifestyle reduced incidence DM2 from 70% to 30% in obese; progression among stages at 5y intervals | 25y | Various trial and observational data with follow-up >5y | Varied % successful at weight loss, discount rate, program cost, effect on incidence, life expectancy | 1 Intensive weight loss and fitness program for obese; 2 Standard care | Net cost per life-year saved for persons with IGT (US$): Behavioral program for seriously obese: net saving Surgery for BMI >40: $3300 | Primary prevention of DM2 for persons with IGT is relatively cost-effective | Did not model individual complications Used only one set of transition probabilities; overly simplistic; based on older epidemiologic data and small trials Assumptions not transparent
Caro et al, 2004^174^ | To compare the health and economic outcomes of using acarbose and an intensive lifestyle program to prevent progression to DM2 of persons with IGT | Health care system | Monte Carlo simulation to evaluate a Markov process | Representative cohort of 1000 Canadians with IGT 2-h glucose 7.8–11.1 mmol/l Canada | Direct medical costs | 5%/y cost and health outcomes | Treatment for 5y; prevalence IGT 11%; reduction in rate of transition to DM2: metfomin 21%, acarbose 36%, lifestyle 58%; annual probability of transitioning to DM2 6.3% | 10y or death | Various epidemiological data sources; STOP-NIDDM; DPP, Diabetes Prevention Study; Ontario cost data | Change risk of transition to DM2; intervention effectiveness; costs | 1 Acarbose; 2 Metformin; 3 Intensive lifestyle; 4 No treatment | Incremental cost per life-year gained: relative to no treatment: Metformin: Cost savings Acarbose: Cost savings Lifestyle: $749 | Treatment of IGT to prevent DM2 is cost-effective: lifestyle interventions lead to greatest healthy benefits at reasonable cost | Did not incorporate QOL Assumptions not transparent
Palmer et al, 2004^176^ | To establish whether DPP interventions are cost effective in various countries | Health care system | Markov | Resembled the DPP population (IGT 5.3 –7.0 mml/l): mean age 50.6y, BMI 34.0 32% from minority population Various countries | Direct medical costs | 5%/y for costs and outcomes | Time from onset to diagnosis of DM2 8y; RR for all-cause mortality 1.76 for diagnosis DM2 and 2.26 for diagnosed DM2; side effects from metformin based on DPP data; duration of effects do not persist beyond 3y trial period | Lifetime | DPP, UKPDS | Age, BMI groups, costs, transition probabilities; costs, discount rate | 1 Intensive lifestyle (DPP intervention); 2 Metformin; 3 Control | Mean number of years free from diabetes: Lifestyle: 10.0 Metformin: 9.0 Control: 8.1 Incremental increase in LE if treatment effect lasted a lifetime in years, vs control: Lifestyle: 0.90 Metformin: 0.35 Lifestyle and metformin cost savings in most countries Metformin had more impact on decreasing costs in increasing life expectancy in younger & more obese patients | DPP produces clinically important improvements in LE, with either overall cost savings or minor increases in total costs per patient | Did not model individual complications Transparent reporting; adequate reporting of data sources and synthesis methods
Archimedes Model Eddy et al, 2005,^169^ 2003^170,^ ^171^ | To estimate the effects of the lifestyle modification program used in the DPP on health and economic outcomes | Patient, health plan, societal | Cost-effectiveness analysis using Archimedes model (built from underlying anatomy, biological variables, and pathways) | Adults at high risk for DM2 (BMI >24 kg/m2, FPG 95–125 mg/dl, or 2-h OGTT 140–199 mg/dl); 100,000 simulated persons for health plan United States | Direct and indirect (for societal perspective) | 3% annual rate | Health plan 10% turn over per y; effectiveness and costs observed at end of the DPP persist as long as the person was receiving the lifestyle intervention; weight increased to 4% loss after 3y and persisted | 5 to 30y (for societal) | Data derived from variety of empirical sources; no data are assumed; costs from DPP study, Kaiser Permanente, and others | Model compared to clinical trials to validate; cost of lifestyle intervention was varied and is cost-saving over 30y if it cost $100/y | 1 DPP lifestyle program; 2 Baseline: no lifestyle or other intervention; 3 Lifestyle when FPG>125 mg/dl; 4 Metformin as in DPP study | Individual at high-risk, 30y probability of developing DM2: baseline 72%; lifestyle: 61%, NNT for benefit: 9; metformin 68%Societal perspective: Incremental 30-y cost/QALY: DPP lifestyle for all compared to lifestyle when FPG >125mg/dl: $201,818; Lifestyle when FPG>125 mg/dl compared to baseline: $24,523; compared to baseline, lifestyle intervention for all high-risk would be $62,600/QALY Health plan perspective: 30y cost/QALY of DPP lifestyle program compared to no intervention $143,000; increases with decreased time horizon and smaller plans; over 5y: $2.7 million | Compared to no prevention program, the DPP lifestyle program reduces preDM person's 30y risk of DM2 from 72% to 61%; 30-y cost/QALY of the DPP lifestyle intervention compared to doing nothing from health plan perspective: $143,000; societal perspective: $62,000 Delaying the lifestyle intervention until after diagnosis of DM2 or using metformin: cost/QALY gained compared to no program: $24,500 and $35,400 Marginal cost-effectiveness of DPP lifestyle program for preDM compared to waiting until after DM2 diagnosed: cost/QALY: $201,800 | Validated model Extensive sensitivity analyses Some assumptions not transparent Considers multiple disease processes and transitions
CDC/RTI Model (Centers for Disease Control and Prevention / Research Triangle Institute) Herman et al, 2005^172^ | To estimate the cost-utility of the DPP interventions compared to the placebo intervention | Opportunistic screening Health care system and societal | Markov; modified CDC/RTI model using costs and data from DPP, quality of life associated with IGT, and UKPDS data on diabetes progression and complications | DPP population: 3234 nondiabetic persons ≥ 25y with IGT and FPG 95–125 mg/dl; mean age 51y, 68% female; 45% members of racial/ethnic minority groups United States | Health care system perspective: direct medical costs; societal perspective: also included direct nonmedical costs | 3% annual rate for costs and QALYs; clinical outcomes not discounted Costs in 2000 US$ | Placebo intervention: annual hazard of DM2 was 10.8/100 person-years. At 3y follow-up the RR for lifestyle and metformin interventions were 55.8% and 29.9%; assume these interventions were applied until diabetes onset and that the health and quality of life benefits associated with the interventions persisted until diabetes onset; baseline rates of complications: neuropathy 8.5%, HTN 28%, dyslipidemia 45%, smokers 7%, history of MI 2.0%; nonDM-related mortality for persons with IGT was the same as for persons with DM2; 10y delay between onset and clinical diagnosis of DM2; microvascular complications did not progress during prediabetes; macrovascular risk factors and disease progress during prediabetes | Lifetime | DPP, UKPDS | Age groups, group vs individual program, metformin cost, varying adherence rates, reduced costs and effectiveness; discount rates delay from onset to diagnosis of DM2 Results: Lifestyle is CE in all age groups; metformin not CE in >65y | DPP lifestyle intervention: 7% or more weight loss and 150 min/week of activity; or metformin 850mg bid; or placebo | Delay in onset DM2: compared to placebo intervention, lifestyle delays onset by 11y and metformin by 3y Lifetime development of DM2: 83% in placebo, 63% with lifestyle, 75% with metformin Increase in LE compared to placebo: lifestyle 0.5y, metformin 0.2y Reduction in cumulative incidence complications: Lifestyle vs placebo: blindness 39%, ESRD 38%, amputation 35%, stroke 9%, CHD 8% Metformin vs placebo: blindness 16%, ESRD 17%, amputation 16%, stroke 3%, CHD 2% Incremental cost/QALY compared to placebo: Lifestyle: $1,124; metformin: $31,286 lifestyle intervention cost saving in <45y old | Lifestyle interventions are relatively CE compared to placebo, producing gains in survival and a decrease in microvascular and cardiovascular complications | Extensive sensitivity analyses Transparent reporting, adequate reporting of data sources and synthesis methods
Lindgren et al, 2007^177^ | To assess the cost-effectiveness of the Finnish Diabetes Prevention Study | Health care system | Markov state transition model with seven states using yearly cycles; model evaluated using Monte Carlo simulation | Population-based screening in Stockholm; 60y old men and women Sweden | Direct and indirect medical costs | 3% annual rate for costs and benefits | Risk of developing DM2 6%/y; risk of MI based on UKPDS; lifestyle intervention produces relative risk of DM2 of 0.4; no lasting effect of intervention after treatment was discontinued | 6y (longest follow-up of Finnish Study | Finnish Diabetes Study, UKPDS, Swedish cost data | Discount rate; including costs in added years of life; various cost estimates | Lifestyle intervention | Intervention is associated with an increase in survival of 0.18y; mean QALYs gained: 0.20y; the cost-effectiveness ratio is Euros 2,363/QALY | This model predicts that the Finnish Diabetes Study lifestyle intervention targeted at persons with high risk would be cost-savings for the health case plan and cost-effective for society | Not assessed

Abbreviations: bid, twice daily; BMI, body mass index; CE, cost effectiveness; CHD, coronary heart disease; DM2, type 2 diabetes; DPP, Diabetes Prevention Program; ESRD, end stage renal disease; FPG, fasting plasma glucose; HTN, hypertension; IGT, impaired glucose tolerance; LE, life expectancy; MI, myocardial infarction; min, minutes; NNT, number needed to treat; nonDM, without diabetes; OGTT, oral glucose tolerance test; preDM, prediabetes; QALY, quality-adjusted life year; QOL, quality of life; RR, relative risk; STOP-NIDDM, Study TO Prevent Non Insulin Dependent Diabetes Mellitus; UKPDS, United Kingdom Prospective Diabetes Study; US, United States; y, year.

Table B11 Evidence Table Of Studies Examining Adverse Effects of Screening (KQ4)

Study Author, year Quality rating | Study design | Purpose of study | Country; Setting; Year(s) of study | Treatment groups; Sample size | Length of follow-up | Inclusion criteria | Exclusion criteria | Participant selection | Population | SES or educational level | Pre-existing depression, anxiety analyzed, etc | Existing vascular disease | FBG (mg/dl) A1c (%) | Lipids (mg/dl) | Blood pressure (mm Hg) | Other risk factors (CVD, etc) | Measures used | Intervention | Primary endpoint(s) | Outcomes for standardized measures | Adherence withdrawals (%) | Other results | Comments | Funding
ADDITION Study Thoolen et al, 2006^188^ Not rated | 2X2 factorial (based on time since diagnosis and treatment intensity) cross-sectional study | Investigate how time since diagnosis and treatment intensity influences psychological outcomes in patients with screen-detected DM2 | Southwest Netherlands Multi-center (79 general practices) | 468 invited 227 agreed 206 completed questionnaire 196 included in analysis (10 not included because time since diagnosis occurred between 1–2y, so did not fit parameters) | No follow-up | Patients included in Dutch arm of ADDITION study without serious comorbidities Ages 50–69 Diagnosed with DM2 3–33m previously Receiving usual or intensive treatment From ADDITION STUDY: [underlined: Screening study:] Without known DM2 Identified though specific centers [underlined: Treatment study]: Newly diagnosed DM2, defined by 99 mg/dl (5.5 mmol/l), by fasting and 2-h post-glucose-challenge blood glucose measurements | From ADDITION STUDY: [underlined: Screening study]: Previously diagnosed DM2 Treated with blood glucose lowering agents [underlined: Treatment study]: IGT and IFG, contraindications or intolerance to study medications, alcoholism, drug abuse, psychosis or emotional problems, malignant disease with a poor prognosis, pregnant or lactating | Screen-detected | Mean age: 61–62y (~5y SD) % male (“marginal difference” between groups, ns): Group 1: 71 Group 2: 50 Group 3: 63 Group 4: 57 | Educational level*: Group 1: 3.0±1.6 Group 2: 3.0±1.4 Group 3: 3.4±1.6 Group 4: 3.0±1.7 *Measured on a 6 point scale (1=primary to 6=higher education) | NR | NR | NR | NR | NR | BMI (from self-report) mean (SD): Group 1: 29.0 (4.3) Group 2: 29.4 (4.7) Group 3: 30.0 (4.9) Group 4: 30.0 (4.9) | Hospital Anxiety and Depression Scale (HADS): measure emotional outcomes, including anxiety and depression [standardized] Problem Areas in Diabetes (PAID) Scale: measure diabetes distress [standardized] Cognitive variables included:; 1) perceptions of health threat - measured by a) perceived seriousness of [based on Diabetes Illness Representations Questionnaire], and b) vulnerability for diabetes [not standardized]; 2) self-efficacy - measured by combination of a) Lorig 1996, and b) Kuijer and de Ridder 2003 scales [not standardized]; Self-care behavior measured using revised summary of diabetes self-care activities measure [parts valid] | 4 groups created by categories of usual or intensive multifactorial drug treatment and time since diagnosis (<1 y or 2–3 y) Multivariate analysis used to examine variation in outcomes on time since diagnosis and treatment intensity [underlined: 4 groups analyzed]: Group 1: DM <1y time since diagnosis + usual care Group 2: DM <1y time since diagnosis + intensive treatment Group 3: DM 2–3y time since diagnosis + usual care Group 4: DM 2–3y time since diagnosis + intensive treatment | 7 variables: Anxiety, depression, diabetes-related distress, perceived seriousness and vulnerability, self efficacy, and self-care | “Most patients reported little distress, low perceived seriousness and vulnerability, high self-efficacy, and low self-care, but outcomes varied considerably across conditions” Time effects found for perceived vulnerability (increases significantly with time since diagnosis) (F=14.3, p<0.001) No time effects found for anxiety (F=0.3, ns) nor depression (F=1.2, ns) No time effects found for diabetes distress (F=3.0, ns), perceived seriousness (F=1.8, ns), self efficacy (F=0.2, ns), nor self management (F=0.0, ns) Some reported clinically relevant anxiety (HADS score >8; clinically definite scores >11) in group diagnosed < 1 year, but it seems to be effect of intensive treatment × time, because the intensive treatment group is significantly higher (mean scores, 6.8 vs 4.5, F=5.8, p<0.001). 2–3y group mean scores = 5.0 vs 5.5, ns | NR | Related to treatment: Time × treatment interactions found for anxiety (F=5.8, p<0.01), diabetes-related distress (F=4.6, p<0.05), and self-efficacy (intensively treated patients showed more distress and less self-efficacy in 1st y; usual care patients reported more distress and less self-efficacy 2–3y after diagnosis (F=7.1, p<0.01) | Included participants were more educated and reported lower self-management than non-participants Analysis adjusted for sex, BMI, and number of complaints Psychological effects were not associated with sociodemographic variables, but were associated with BMI and medical complaints | NR
ADDITION Study Eborall et al, 2007^190^ Fair | Controlled clinical trial (embedded within the ADDITION Trial) | To quantify the psychological impact of primary care-based stepwise screening for DM2 | United Kingdom (Cambridge) | Screened: 4370 Control: 964 | Up at 15m | From ADDITION screening study: Without known DM2 Identified though specific clinical centers | See above | Recruitment from clinical settings | 65% male Mean age: 58y Avg BMI: 30.5 NSD between groups | NR for these specific groups (see above) | NR | NR | NR | NR | NR | BMI >30kg/m^2^: (mean [SD]) I: 30.5 (4.7) C:30.6 (4.9) | Spielberger state anxiety inventory, range from 20–80 Hospital Anxiety and Depression Scale (HADS): measure emotional outcomes, including anxiety and depression [standardized] Single item on general health Disease-specific worry: adapted from legman cancer worry scale: sum scores 6–24 | Step-wise screening for DM2: hi-risk for DM2 were identified using computerized general practice records; those were invited to get random BG; if >5.5 mmol/l invited for fasting BG, if >6.1 mmol/l invited for 75-g OGTT | State anxiety, anxiety, depression, diabetes-specific worry, self-rated health | Conclusion: screening has limited psychological impact on patients; being required to return for further tests after an initial positive random BG has small negative psychological impact of doubtful clinical significance Immediate impact of initial (+) screening test compared to test (-): poorer health; higher anxiety, depression, diabetes-specific worry (p all ≤ 0.05) | Invited to screening and did not attend; 32% Random BG (-) at baseline: 67% follow-up at 12–15m Random BG (+) at baseline: 39% follow-up at 12–15m | Test for trend over steps in screening process: worry about DM increased as underwent more screening tests before testing (-) Nonattenders for the initial test: 11% response rate at 12–15m: had high worry at 12–15m (p=0.03) | | Wellcome trust, National Health Service Research and Development
ADDITION Study Eborall et al, 2007^189^ Not rated | Prospective qualitative interview of patients in a screening program for DM2 | To provide insight into factors that contribute to the anxiety reported in the quantitative study of the psychological effect of screening for DM2; to explore expectations and reactions to the screening experience | United Kingdom (Cambridge) | 23 total | No follow-up | From ADDITION screening study: Without known DM2 Identified though specific clinical centers | See above | Recruitment from clinical settings | Population scheduled for OGTT was sampled; additional sampling to address imbalance of sex and diagnosis with initial sampling | NR | NR | NR | NR | NR | NR | NR | Open-ended questions | As above | Perceptions and expectations before and after OGTT | Initial stages of screening processes: most participants not very worried who tested (+) on the first tests Prediagnostic test expectations: many accepted possibility of (+) diagnosis Reactions after new diagnosis of DM2: tendency to downplay importance; all had plans to control the disease; most were grateful for screening program Diagnosed with IFG or IGT: many were confused by this diagnosis; most were unconcerned and unaware of this diagnosis as a risk factor for DM2 or CVD | None | None | | Royal College of General Practitioners scientific foundation board for this study; ADDITION funded by Wellcome trust, National Health Service Research and Development
Edelman et al, 2002^182^ Good | Cohort with comparison (nondiabetic) group | Determine effects of new diagnosis of DM2 discovered by systematic screening | United States Durham Veterans Affairs Medical Center, North Carolina (single center) October 1996 – March 1999 | 1253 total (1,177 without DM2 at screening; 56 [4.5%] with new diagnosis of DM2 at screening) | 1y | Durham Veterans Affairs Medical Center outpatients that did not report having diabetes at start of study | Known diabetes Patients who had a prescription filled for hypoglycemic medication Short life expectancy (incurable cancer, heart or lung disease requiring oxygen) No easy access to a telephone | Systematically screened for DM2 | Ages: 55y mean (6y SD) 94% male Race: 69% Caucasian 29% African American 2% Other | NR | Yes | NR | NR | NR | NR | Body weight: 60% > 120% of ideal body weight Comorbidity: 95% comorbid illness; 34% moderate to severe comorbidity | Prior to study, A1c measurements taken on all subjects: A1c > 6.0% were repeated DM2 defined as A1c > 7.0% or fasting plasma glucose > 126 mg/dl (7.0 mmol/l) Health-related quality of life (HRQoL) assessed using Medical Outcomes Study Short Form 36 (SF-36). 2 parts: Physical Component Scale (PCS) and Mental Component Scale (MCS) Comorbidity assessed using Kaplan-Feinstein Index | HRQoL measured at baseline and 1y after diagnosis using multivariate analysis | HRQoL | No significant differences (p<0.05) between patients with and without DM2 nor between baseline and 1y follow-up [underlined: Baseline PCS]: NonDM2 vs. newly diagnosed DM2 (36.3 vs. 35.6) not different (p=0.67) [underlined: Baseline MCS]: NonDM2 vs. newly diagnosed DM2 (49.6 vs. 48.8) not different (p=0.70) [underlined: 1y follow-up PCS]: NonDM2 vs. newly diagnosed DM2 (35.2 vs. 34.6) not different (p=0.68) [underlined: 1y follow-up MCS]: NonDM2 vs. newly diagnosed DM2 (48.2 vs. 48.0) not different (p=0.94) | NR | Mild-severe comorbid illness associated with lower PCS both at baseline and 1y follow-up (p<0.05) | | Supported by Department of Veteran's Affairs Cooperative Studies and a Research Career Award
Farmer et al, 2003^183^ Good-fair | Single-group cohort | To assess changes in anxiety, well-being, and cognitions associated with screening for DM2 in people at increased risk of DM2 after 1y to identify potential predictors of increased anxiety and lower well-being | United Kingdom, Oxfordshire and South Northamptonshire 1996 - 1998 | 431 total | 1y | [underlined: Probands]: Age ≥ 35 at diagnosis Families with ≥ 3 siblings, and a quarter of families with 2 siblings living within study area [underlined: Participants]: Participants aged 35–74 Family history of DM2 Not known to have DM2 Able to complete questionnaires | [underlined: Participants:] Known DM2 < age 35 or > age 74 | Recruited with information from general practitioners Probands sent questionnaires to assess willingness of siblings to participate | Mean age (SD) & % male: Normal risk of DM: 57.3y (10.2y) & 38.8% Borderline risk of DM: 59.8y (8.9y) & 48.5% High risk of DM: 59.8y (9.0y) & 56.5% Possible diabetes: 58.7y (9.0y) & 72.2% | Occupational group (manual/professional %): Normal risk of DM: 139/86 Borderline risk of DM: 61/38 High risk of DM: 50/31 Possible diabetes: 12/6 | Yes | NR | NR | NR | NR | Mean BMI (SD): Normal risk of DM: 27.3 (5.3) Borderline risk of DM: 28.4 (4.6) High risk of DM: 29.9 (5.3) Possible diabetes: 31.6 (5.9) | Response rates calculated Speilberger State Anxiety Inventory (SSAI-SF) Well-being questionnaire (WBQ-12) Health Anxiety Inventory (HAI) | Questionnaires at baseline and 1y follow-up Analysis separated according to those receiving a “normal” test result <5.5 mmol/L compared with those “at risk” receiving a borderline (99–108 mg/dl [5.5–6.0 mmol/L]), high (>108–140 mg/dl [>6.0–7.8 mmol/L]), or test result indicating diabetes (140 mg/dl [>7.8 mmol/L]) | Anxiety Well-being Cognition | Anxiety decreased from 34.5 (95% CI 33.4–35.6) to 32.3 (31.2–33.4) at 1y (p<0.0001) Well-being scores increased (improved) from 26.8 (26.0–27.4) to 27.4 (26.7–28.1)(p=0.008). Anxiety and well-being over 1y did not differ between participants receiving a normal or at-risk result | 328 (76%) returned questionnaires at 1y | None | BMI and gender (more female) significantly different between groups, p <0.001 and p=0.002 respectively. Same population as Farmer, 2005 | Scientific Foundation Board of the Royal College of General Practitioners, funded by National Health Service Career Development Award
Farmer et al, 2005^184^ Fair | Randomised controlled trial | To assess the impact on response rates and psychological measures of different follow-up schedules in at-risk participants undergoing screening for DM2 | United Kingdom, Oxfordshire and South Northamptonshire | 431 total Limited follow-up (LF): 213 Intensive follow-up (IF): 218 | 1m 6m 1y | [underlined: Probands]: Aged ≥ 35 at diagnosis Families with ≥ 3 siblings, and a quarter of families with 2 siblings living within study area [underlined: Participants]: Participants aged 35–74 Family history of DM2 Not known to have DM2 Able to complete questionnaires | [underlined: Participants]: Known DM2 < age 35 or > age 74 | Recruited with information from general practitioners Probands sent questionnaires to assess willingness of siblings to participate | Mean age (SD): LF: 58.8y (9.5y) IF: 58.1y (9.9y) % Male: LF: 48.8 IF: 42.7 | Occupational group (manual / professional %) LF: 61.4/81 IF: 63/37 | Yes | NR | Plasma glucose: (LF then IF) Normal (<101 mg/dl [<5.6 mmol/L]: 112, 115 Borderline (101–108 mg/dl [5.6–6.0 mmol/L]) 50, 51 At risk (>108–<142 mg/dl [> 6.0–<7.9]): 43, 42 Diabetes (≥142 mg/dl [≥7.9 mmol/l]): 8, 10 | NR | NR | BMI (mean): LF: 27.7 IF: 28.6 | Response rates calculated Speilberger State Anxiety Inventory (SSAI-SF) Well-being questionnaire (WBQ-12) | Random assignment to either limited follow-up (1y) or intensive follow-up (1m, 6m, 1y) Analysis separated according to follow-up rates only | Response rates Anxiety Well-being | No significant difference between groups in SSAI-SF (anxiety) change scores from baseline to 1y follow-up (p=0.13) Limited follow-up group had greater improvement in well-being (change score of the WBQ-12 well-being, p= 0.003 | 10% failed to return SSAI-SF follow-up 11.2% failed to return WBQ-12 follow-up | No difference between groups in proportion of 1y response questionnaires returned | If group slightly more likely to be female, heavier, higher baseline WBQ-12 score Focused on differences between 1 vs. 3 follow-up questionnaires, so groups not very meaningful for our purposes Same population as Farmer, 2003 | Scientific Foundation Board of the Royal College of General Practitioners, funded by National Health Service Career Development Award
Hoorn Study Adriaanse et al, 2002^181^ Not rated | Cohort study with comparison (nondiabetic) group (pilot study) | To explore psychological impact of a stepwise population-screening project for DM2 | Netherlands, Hoorn region | 40 total (11,679) Diagnosed with DM2: 20 At increased risk: 20 | Screen-diagnosed diabetes group: 2m Elevated risk group (controls): 2w | Participant in Hoorn screening project and chosen to be part of pilot study DM2 or elevated risk of DM2 (SRQ score > 6) Ages 51–74 | NR | From population-based screening project; identified as high risk | Mean age: DM2: 62.3y ± 5.9 nonDM2: 64.9y ± 6.2 % Male: DM2: 50 nonDM2: 50 nonDM2 group was high risk | NR | NR | 55% reported family history of diabetes in each group | FPG (mmol/l) newly-diagnosed: 8.5 (2.3) Non-diabetic: 6.5(0.6) | NR | NR | NonDM2 (N=20): 17 with IFG and 10 with both IFG and IGT BMI: DM2: 28.6 ± 3.5 nonDM2: 27.7 ± 4.1 | SRQ - used to identify people in general population at increased risk for DM2 Semistructured interviews examining: In newly-diagnosed DM2: the impact of diabetes, understanding of the test result, perceived severity, sense of control In screened non-diabetics: impact of the test results, intention to change lifestyle Both groups: views on the screening procedure | Qualitative study Semi-structured interviews specific to intervention or control groups: [underlined: Newly-diagnosed diabetes group]: 30–60 minutes at their home [underlined: Non-diabetic group]: 15–30 minutes via telephone | Psychological impact | Screening procedure: both DM2 and nonDM2 participants evaluated screening procedure as positive and not burdensome 1 person alarmed by diagnosis, the 19 others were not Having diabetes was not experienced as a severe disease, no concerns were expressed | 0 | Listed, but not standardized | When capillary glucose > 99 mg/dl (>5.5 mmol/L), venous FPG was measured and within 2w, a 75-g OGTT performed Used WHO (1998) criteria (requiring FPG ≥126 mg/dl (≥ 7.0 mmol/L) on 2 separate occasions, or abnormal OGTT, with 2-h plasma glucose ≥200 mg/dl (≥ 11.1 mmol/L) | Health and Research Development Council of The Netherlands
Hoorn Study Adriaanse et al, 2004^178^ Fair | Cohort study with comparison group (both with DM2) | To determine prospectively health-related quality of life during 1st y following diagnosis of DM2, in newly diagnosed patients in general practice, compared with patients detected early by targeted population screening | Netherlands, Hoorn region | 165 total GPDM (general practice diagnosed diabetes): 49 SDM (screening diagnosed diabetes): 116 | 2w 6m 1y | [underlined: SDM]: Participant in Hoorn screening project and chosen to be part of this study, with DM2, ages 50–75 [underlined: GPDM]: cities of Den Helder and Medemblik, 36 general practices, 1999-2001, with DM2, ages 50–75 | NR | From population-based screening project; identified as DM2 From general practices; identified as DM2 | Mean age: GPDM: 62.2±7.0 SDM: 63.2±7.3 % Male: GPDM: 49 SDM: 56.9 | Educational level: GPDM: 57.1% low, 36.7% middle, 6.1% high SDM: 62.1% low, 30.2% middle, 7.8% high P value = 0.695, ns | Yes | See “other results” column Microalbuminuria (%): GPDM: 26.5 SDM: 20.7 Impaired foot sensitivity (%): GPDM: 51.0 SDM: 46.6 Retinopathy (%): GPDM: 2.0 SDM: 8.6 Lipid lowering med (%): GPDM: 16.3 SDM: 17.2 | See “other results” column | NR | NR | See “other results” column BMI: GPDM: 29.5±6.1 SDM: 29.7±4.9 | SRQ - used to identify people in general population at increased risk for DM2. Type 2 Diabetes Symptom Checklist (DSC-type 2) - measures presence and burden of diabetes-related symptoms Short Form 36 (SF-36) - measures perceived health status Well-Being Questionnaire (WBQ12) - Dutch version, measures emotional well-being | Completed standardized questionnaires at 2w, 6m, and 1y following DM2 positive test result | HRQoL, including: presence and burden of diabetes-related symptoms, perceived health status, emotional well-being | DSC-type 2 score (higher scores indicate more symptom distress) improved significantly within GPDM across follow-up (2w: 0.56; 6m: 0.21; 1y: 0.26, p<0.001), but not for SDM group (2w: 0.24; 6m: 0.24; 1y: 0.29, p=0.093) GPDM consistently worse mean scores on all SF-36 mental health subscales and all WBQ12 scores at each time point compared with SDM Differences were statistically significant (worse) for GPDM group on SF-36 for Role Emotional (F=5.2, p=0.024), Mental Health (F=5.0, p=0.027), and Vitality (F=3.9,p=0.049); Significantly lower Mental Health Component Score for GPDM (F=7.0, p=0.009); Differences were statistically significant (worse) for GPDM group on WBQ12 for General well-being (p=0.048) No differences between groups over time for other dimensions of SF-36 and WB12 SF-36 General Health (F=3.7, p=0.028) and Vitality (F=4.5, p=0.012) scores of GPDM improved significantly over time compared with SDM | GPDM: started with 71, data for 49 SDM: started with 217, data for 116 | General practitioners reported that 76% (31/41) of newly diagnosed GPDM group were detected because of distinct diabetes-related symptoms [underlined: Baseline significant differences]: GPDM higher: fasting plasma glucose (mmol/L) 9.7±3.1 vs. 8.5±2.0, p=0.005 A1c (%) 9.1±2.3 vs. 6.7±1.4, p<0.001 Oral blood glucose lowering agents (%) 77.6 vs. 24.1, p<0.001 SDM higher: Overweight (BMI ≥ 25)(%) 72.9 vs. 88.8, p=0.011 Hypertension (%) 59.2 vs. 75.0, p=0.042 | WHO (1998) criteria used for diagnosis First study to compare these 2 groups | NR
Hoorn Study Adriaanse et al, 2004^180^ Fair | Cohort with comparison (nondiabetic) group | To examine impact of diagnosis of DM2 on psychological well-being and perceived health status in subjects who participated in a targeted population-screening program | Netherlands, Hoorn region | 259 total (from 11,679) Subsequently diagnosed with DM2: 116 Without DM2 143 | 2w 6m 1y | Participant in Hoorn screening project and chosen to be part of this study, with DM2 or elevated risk of DM2 (SRQ score > 6) Ages 51–74 | NR | From population-based screening project; identified as high risk | Race: >99% Caucasian Mean age: DM2: 63.2 ± 7.3 nonDM2: 62.2 ± 7.3 % Male: DM2: 56.9 nonDM2: 51 nonDM group was high risk | NR | Yes | Parent or sibling with DM2: 43.1% nonDM2: 37.8% | FPG mmol/L Diabetic: 7.3 (1.9) Non-diabetic: 5.9 (0.3) | NR | NR | Significant differences in BMI between groups: DM2: 29 + 5.1 vs nonDM2: 27.9 + 4.0, (p=0.045) | SRQ - used to identify people in general population at increased risk for DM2 12-item Well-being Questionnaire (WBQ12) - Dutch version Medical Outcomes Study Short Form 36 (SF-36) | Completed standardized questionnaires at 2w, 6m, and 1y following test result (DM2 diagnosis or not) | Psychological well-being Perceived health status | 2w after diagnosis: no significant mean differences in psychological well-being nor perceived health status 6m after diagnosis: significantly lower scores of DM2 group for Role Physical (mean difference -8.2 [95% CI -16.2; -0.1], p=0.046) and Role Emotional (mean difference -7.9 [95% CI -15.3; -0.5], p=0.038) dimensions of perceived health status; no other significant differences 1y after diagnosis: no significant mean differences in psychological well-being nor perceived health status | NR | None | Significant differences in BMI: DM2 29 ± 5.1 vs. nonDM2 27.9 ± 4.0, (p=0.045) Use of antihypertensive drugs: DM2 36.2% vs. nonDM2 35.7%, NS. | NR
Hoorn Study Adriaasne et al, 2005^179^ Fair | Cohort with comparison (nondiabetic) group | To determine level of diabetes-related symptom distress and its association with negative mood in population-based screening program, comparing DM2 vs nonDM2 (but high risk) groups | Netherlands, Hoorn region | 246 DM2: 116 nonDM2: 130 | 2w 6m 1y | Participant in Hoorn screening project and chosen to be part of this study With DM2 or elevated risk of DM2 (SRQ score > 6) Ages 50–75 | NR | From population-based screening project, identified as high risk or DM2 | Mean age: DM2: 63.2y ± 7.3y nonDM2: 61.9y ± 7.3y % Male: DM2: 56.9 nonDM2: 50.8 Race: >99% Caucasian | NR | Yes | NR | FPG (mmol/l) Diabetic: 7.3 (1.9) Non-diabetic: 5.9 (0.3) | NR | NR | BMI (kg/m^2^): DM2: 29.0±5.1 nonDM2: 28.0±4.0 | SRQ - used to identify people in general population at increased risk for DM2 Diabetes Type 2 Symptom Checklist (DSC-type 2) Negative Well-being (NWB) Subscale of Well-being questionnaire (WBQ12) - Dutch version | Completed standardized questionnaires at 2w, 6m, and 1y following DM2 Screening test Analyzed all variables | Diabetes-related symptom distress Negative mood | Screening-detected DM2 patients reported significantly greater burden of hyperglycemic (F = 6.0, p=0.015) and of fatigue (F = 5.3, p=0.023) symptoms in the 1st y following diagnosis; outcomes did not change over time, no significant group by time interactions were found Total symptom distress (range 0–4) relatively low for both DM2 (median at 2w, 6m, and 1y; 0.24, 0.24, 0.29) and nonDM2 (0.15, 0.15, 0.18) and not significantly different No average difference and change over time in negative well-being Negative well-being significantly positively related with the total symptom distress score (regression coefficient beta = 2.86, 95% CI 2.15–3.58) | DM2: started with 156; data for 116 (74%) nonDM2: started with 163; data for 130 (80%) | None | | NR
Nichols et al, 2004^185^ Poor | Cohort with comparison (nondiabetic) group | To examine functional health status prior to diagnosis of DM2, and measure effect on functional health status of receiving the diagnosis | United States Kaiser Permanente Northwest, Portland, Oregon | Those meeting new diagnostic criteria (I): 498 Comparison group (C): 589 Originally 1014 in each group, response rate of 69%, missing items lead to final numbers (44%) N=273 | 1y | Members of HMO Kaiser Permanente Northwest In Kaiser records, but not in diabetes registry, that meet new criteria for diabetes since ADA lowered diagnosis criteria from 140 to 128 mg/dl (7.8 to 7.0 mmol/l) (soon to be diagnosed) Age and gender match comparison group without DM2 | Previously diagnosed DM2 | Electronic registry database DM2 vs nonDM2 | Mean age: 66.9y + 10.5y % Male: 56 | NR | Yes | Self report: Hypertension (p<0.001) I: 61.6% C:38.7% Heart problems (p<0.001) I: 40.5% C: 23.5% Neuropathy symptoms (p=0.003) I: 30.7% C: 22.5% Diabetes symptoms I: 55.1% C: 47.8% | NR | NR | NR | Self report: Depression I: 14.1% C: 13.4% BMI (p<0.001) I: 30.3% C: 27.9% | SF-12 Health Survey Physical component (PCS-12) Mental component (MCS-12) | After ADA reduced fasting glucose level for diagnosing diabetes from 140 to 126 mg/dl (7.8 to 7.0 mmol/l) in 1998, searched Kaiser Permanente Northwest database back to 1994 (database started in 1988) identifying members who were not currently in diabetes registry, but that met new criteria (before diagnosis group) and added an age and gender-matched comparison group Measured functional health status 1y before and 1y after diagnosis of DM2 | Functional status | Between-group at baseline: Prior to diagnosis, physical functioning already lower in subjects who met the new criteria than comparisons (39.5 vs. 42.1, p<0.001); Mental functioning was ns (51.4 vs. 51.9, p=0.406) Within-group after 1y: Among those who newly met diagnostic criteria, no difference in change in health status (mental or physical) in those who reported receiving a diagnosis (n=105) compared with those who did not (n=168). Adjusted for age difference (at 1y follow-up) between those receiving diagnosis (younger) and those not (67.0 vs. 69.6, p=0.031); After adjustment for age, learning of diagnosis was not associated with any difference in functional status on either questionnaire or with a change in physical (1.55 vs. 0.05, p=0.233) or mental (-0.63 vs. 0.01, p=0.598) health status compared to those who had not been told of their diagnosis | 1y later: Sent out 706 follow-up questionnaires, 623 were still members, received 273 (44%) usable responses | Those meeting new criteria were more likely to report: Hypertension (61.6 vs. 38.7%, p<0.001) Heart problems (40.5 vs. 23.5%, p<0.001) Neuropathy symptoms (30.7 vs. 22.5, p=0.003) Diabetes symptoms (55.1 vs. 47.8%, p<0.019) Higher BMI (30.3 vs. 27.9, p<0.001) | Adjusted for age difference at 1y follow-up | NR
Peel et al, 2004^186^ Not rated | Cross-sectional | To assess impact of DM2 new diagnosis on emotions and views | United Kingdom, Scotland Multicenter (16 different practices and 3 hospitals) | 40 | No follow-up | Newly diagnosed from range of backgrounds (poor, affluent, rural, urban) from various practices and hospitals across Lothian region in Scotland Based within Local Health Care Co-operatives | NR | Recruitment from general practitioners and hospitals | Age (mean [range]): 48y (21–77y) 52.5% male 47.5% female | Number of participants (using Registrar General's classification system): Social classes I–II: 10 Social classes III non-manual: 12 Social class III manual: 13 Social classes IV–V: 5 | NR | Perhaps, but quantitative data NR | NR | NR | NR | Perhaps, but quantitative data NR | In depth interview (not standardized) | In depth interview | Emotional reaction about diagnosis Views about information provision at time of diagnosis | Varied emotional reactions to diagnosis Most wanted detailed information at time of diagnosis | NA | None | Identified 3 “routes” to diagnosis:; 1) Suspected diabetes route; 2) Illness route; 3) Routine screening route | Scottish Executive Health Department
Skinner et al, 2005^187^ Not rated | Cross-sectional (1 time assessment at screening) | To assess impact of diabetes screening on anxiety levels in ethnically mixed population | United Kingdom, Leicestershire | 1,339 1,189 (complete data sets) | No follow-up | Participant in Screening those at Risk (STAR) study Ages 25–75 (40–75 if White) with ≥ 1 risk factor: Known CHD, known risk of CHD or on CHD register, documented history of hypertension with medication, cerebrovascular disease and/or peripheral vascular disease, diagnosis of IGT or IFG, women with polycystic ovary syndrome and obesity (BMI > 25 or > 23 kg/m^2^ in South Asians, BMI > 30 kg/m^2^, BMI > 25 kg/m^2^ with sedentary lifestyle), women with previous history of gestational disease, first-degree relative with DM2 | Housebound Terminal illness Previously diagnosed DM2 Unable to read or complete questionnaire unaided | Identified at high risk of developing DM2 though general practitioner's or cardiovascular team's lists, Coronary Heart Disease register, or through public media recruitment | High risk for DM2 54% male 46% female 21% Asian 75% Caucasian 4% Other Ages: Asian: 51.2y ± 11.2y Caucasian: 60.5y ± 9.9y | NR | NR | NR | NR | TC Asian: 197±35mg/l (5.1±0.9 mmol/l) HDL Asian: 46±15mg/l (1.2±0.4 mmol/l) TC Caucasian: 209±46 mg/dl (5.4±1.2 mmol/l) HDL Caucasian: 54±19 mg/dl (1.4±0.5 mmol/l) | Asian: 128 ±21/80±11 mmHg Caucasian: 134±25/80±11 mmHg | Relative with diabetes: Asian: 70% Caucasian: 37% BMI: Asian: 26.88±4.4 kg/m^2^ Caucasian: 28.5+5.6 kg/m^2^ | OGTT to assess diabetes status To access anxiety: SSAI-SF, Emotional Stability Scale of the Big Five Inventory 44, and 3 scales from the Diabetes Illness Representations Questionnaire (modified for interviews) | Anxiety measured at time of screening | Anxiety | No effect of family history of diabetes ethnic group, or recruitment methods on anxiety 45% of participants reported “little to moderate” amounts of anxiety (mean 35.5, SD 11.6) Emotional stability was significantly (negatively) associated with anxiety (r=-0.45; n=930; p<0.001), with females describing themselves as less emotionally stable than males (t=4.49; df=577; p<0.001) There were no other variables significantly associated with anxiety | NR | Participants with a first-degree relative with diabetes were more likely to agree that diabetes was hereditary (t=3.22, p<0.001) South Asians were more likely than Caucasians to agree that diabetes is hereditary (t=3.59; p<0.001) and caused by poor medical care (t=4.11; p<0.001), and less likely to agree that it is a chronic condition (t=3.38; p<0.001) 64% of responders thought diabetes was caused by diet 61% of responders thought diabetes was caused by hereditary factors 12% of responders thought that diabetes was serious, shortens life, and causes complications Other outcomes relate to perceived causes of diabetes, duration of diabetes, and impact on diabetes on life | Cannot locate original STAR study [underlined: Issue with analysis, lost 150 datasets]: “Because of problems with recording the ID number on questionnaires, a number of questionnaires could not be linked to results of standardized health assessment. Therefore, where data are reported that combines data from health assessment and the questionnaire, # of participants in analysis is substantially reduced.” Authors described ethnically mixed population as 75% Caucasian 21% Asian; 4% Other | NR

Abbreviations: ADA, American Diabetes Association; ADDITION Study, Anglo-Danish-Dutch Study of Intensive Treatment and Complication Prevention in Type 2 Diabetic Patients Identified by Screening in Primary Care; BG, blood glucose; BMI, body mass index; C, control group; CHD, coronary heart disease; CVD, cardiovascular disease; DM, diabetes; DM2, type 2 diabetes mellitus; DSC-Type 2, Diabetes Symptom Checklist - Type 2 diabetes; FBG, fasting blood glucose; FPG, fasting plasma glucose; GPDM, general practice-diagnosed diabetes; HADS, Hospital Anxiety and Depression Scale; HAI, Health Anxiety Inventory; HDL, high density lipoprotein; HMO, Health Maintenance Organization; HRQoL, Health Related Quality of Life questionnaire; I, intervention group; IF, intensive follow-up group; IFG, impaired fasting glucose; IGT, impaired glucose tolerance; LF, limited follow-up group; m, months; MCS, Mental Component Score; NA, not applicable; nonDM, without diabetes; NR, not reported; NS, not significant; NSD, no significant difference; NWB, negative well-being subscale; OGTT, oral glucose tolerance test; PCS, Physical Component Score; SD, standard deviation; SDM, screening-detected diabetes; SES, socioeconomic status; SF, short form; SRQ, Symptom Risk Questionnaire; SSAI-SF, Spielburger State-Trait Anxiety Inventory-Short Form; STAR, Screening those at Risk; TC, total cholesterol; w, week; WBQ-12, Well-being Questionnaire-12; WHO, World Health Organization; y, years.