# Appendix A Definitions and Abbreviations

## Appendix A1. Diabetes Definitions

Asymptomatic type 2 diabetes mellitus:

Persons without:

- Symptoms directly related to hyperglycemia such as polyuria or polydipsia
- Symptoms related to conditions known to be associated with diabetes such as foot ulcers, ischemic heart disease, or infections

Pre-diabetes:^*^

* Reference: American Diabetes Association. Diagnosis and Classification of Diabetes Mellitus — Position Statement. Diabetes Care. 2007;30(Suppl 1):S42–S47.

- [underlined: Impaired fasting glucose (IFG)]: An intermediate group of subjects whose glucose levels, although not meeting criteria for diabetes, are nevertheless too high to be considered normal. This group is defined as having fasting plasma glucose levels ≥ 100 mg/dl (5.6 mmol/l) but <126 mg/dl (7.0 mmol/l).
- [underlined: Impaired glucose tolerance (IGT)]: An intermediate group of subjects whose glucose levels, although not meeting criteria for diabetes, are nevertheless too high to be considered normal. This group is defined as having 2-h values of the 75-gram oral glucose tolerance test (OGTT) of ≥ 140 mg/dl (7.8 mmol/l) but < 200 mg/dl (11.1 mmol/l).

Type 2 diabetes mellitus (previously referred to as non-insulin dependent diabetes or adult-onset diabetes):^*^

A metabolic disease characterized by hyperglycemia resulting from a combination of resistance to insulin action and an inadequate compensatory insulin secretory response. Criteria for diagnosis are any of the following:

- Symptoms of diabetes plus causal plasma glucose ≥ 200 mg/dl
- Fasting plasma glucose ≥ 126 mg/dl
- 2-hour post 75-gram oral glucose tolerance test plasma glucose ≥ 200 mg/dl

In the absence of unequivocal hyperglycemia, these criteria should be confirmed by repeat testing on a different day.

## Appendix A2. Abbreviations and Acronyms

Abbreviation | Terminology
AA | African-American
AASK | AASK, African-American Study of Kidney Disease and Hypertension Trial
ACCORD | Action to Control Cardiovascular Risk in Diabetes trial
ACE | Angiotensin-converting enzyme
ACE-I | Angiotensin-converting enzyme inhibitors
ADA | American Diabetes Association
AEs | Adverse events/effects
AFCAPS/TexCAPS | Air Force/Texas Coronary Atherosclerosis Prevention Study
AGI | Alpha-glucosidase inhibitor
AIIRA | Angiotensin II receptor antagonists
ALLHAT | Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial
ALLHAT-LLA | Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial-Lipid Lowering Arm
ALT | Alanine aminotransferase
AMI | Acute myocardial infarction
ARBs | Angiotensin II receptor blocker
ARR | Absolute risk reduction
ASCOT-LLA | Anglo-Scandinavian Cardiac Outcomes Trial-Lipid Lowering Arm
AST | Aspartate aminotransferase
AUC | Area under the curve
BG | Blood glucose
bid | Two times daily
BIP | Bezafibrate Infarction Prevention Trial
BMI | Body mass index
BP | Blood pressure
BPLTTC | Blood Pressure Lowering Treatment Trialists' Collaboration
C | Control group
CABG | Coronary artery bypass graft
CARDS | Collaborative AtoRvastatin Diabetes Study
CD | Controlled diet
CDC | Center for Disease Control and Prevention
CDE | Conventional dietary education
CE | Cost effectiveness
CHD | Coronary heart disease
CHF | Congestive heart failure
COER | Controlled-onset extended-release
CONVINCE | Controlled ONset Verapamil Investigation of Cardiovascular Endpoints Trial
CORE | Center for Outcomes REsearch
CVD | Cardiovascular disease
DBP | Diastolic blood pressure
DBT | Target blood pressure
DCCT | Diabetes Control and Complications Trial
DM | Diabetes
DM1 | Type 1 diabetes mellitus
DM2 | Type 2 diabetes mellitus
DPP | Diabetes Prevention Program
DPS | Finnish Diabetes Prevention Study
DREAM | Diabetes Reduction Assessment with Ramipril and Rosiglitazone Medication
DSC-Type 2 | Diabetes Symptom Checklist - Type 2
EF | Ejection fraction
EKG (or ECG) | Electrocardiogram
ESRD | End-stage renal disease
FBG | Fasting blood glucose
Fin-D2D | National Type 2 Diabetes Prevention Program in Finland
FPG | Fasting plasma glucose
GI | Glucose intolerance
GPDM | General practitioner group with diabetes
HADS | Hospital Anxiety and Depression Scale
HAI | Health Anxiety Inventory
HCTZ | Hydrochlorothiazide;
HDL | High density lipoprotein
HMO | Health maintenance organization
HOPE | Heart Outcomes Prevention Evaluation study
HOT | Hypertension Optimal Treatment
HPS | Heart Protection Study
HR | Hazard ratio
HRQoL | Health Related Quality of Life questionnaire
HT | Hypertension
Hx | History
I | Intervention group
IDNT | Irbesartan Diabetic Nephropathy Trial
IGT | Impaired glucose tolerance
IFG | Impaired fasting glucose
ITT | Intention to treat analysis
JMIC-B | Japan Multi-center Investigation for Cardiovascular Diseases-B
LDL | Low density lipoprotein
LE | Life expectancy
LEA | Lower extremity amputation
LFT | Liver function test
LIFE | Losartan Intervention for Endpoint Reduction Trial
LIPID | Long-term Intervention with Pravastatin in Ischaemic Disease
LSM | Lifestyle Modification
LTPA | Leisure time physical activity
LVEF | Left ventricular ejection fraction
LVH | Left ventricular hypertrophy
LY | Life year
m | Months
MCS | Mental Component Score
MI | Myocardial infarction
NA | Not applicable
NCEP | National Cholesterol Education Project
NDE | New dietary education
NFG | Normal fasting glucose
NG | Normoglycemic
NGT | Nondiabetic or normal glucose tolerance
NHANES | National Health and Nutrition Examination Survey
NICOLE | Nisoldipine In Coronary Artery Disease in Leuven
nonDM | Without diabetes
NNT | Number needed to treat
NR | Not reported
NSD | Not significant
NSD | No significant difference
NYHA | New York Heart Association
OGTT | Oral glucose tolerance test
OP | Outpatient
OR | Odds ratio
PA | Physical activity
PAID | Problem Areas in Diabetes scale
PART2 | Prevention of Atherosclerosis with Ramipril Therapy
PCS | Physical Component Score
preDM | Prediabetes
PPG | Postprandial plasma glucose
PPP | Primary Prevention Project trial
PREVENT | Prospective Randomized Evaluation of the Vascular Effects of Norvasc Trial
PROGRESS | Perindopril Protection Against Recurrent Stroke Study
PROSPER | Prospective Study of Pravastatin in the Elderly at Risk trial
QALE | Quality-adjusted life expectancy
QALY | Quality-adjusted life year
q | Every
qd | Daily
QOL | Quality of life
RCT | Randomized controlled trial
RD | Risk difference
RENAAL | Randomized Evaluation of Non-Insulin-Dependent Diabetes Mellitus with the Angiotensin II Antagonist Losartan
RF | Reduced fat
RR | Relative risk
RRR | Relative risk reduction
RTI | Research Triangle International
SBP | Systolic blood pressure
SCOPE | Study on Cognition and Prognosis in the Elderly
SD | Standard deviation
SDM | Screened group with diabetes
SF-12 | Medical Outcomes Study Short Form 12
SF-36 | Medical Outcomes Study Short Form 36
SRQ | Symptom Risk Questionnaire
SSAI-SF | Spielburger State-Trait Anxiety Scale-Short Form
STOP-NIDDM | Study TO Prevent Non-Insulin-Dependent Diabetes Mellitus
SYST-EUR | Systolic Hypertension-Europe trial
TC | Total cholesterol
TG | Triglycerides
TIA | Transient ischemic attack
tid | Three times daily
TZDs | Thiazolidinediones
UAP | Unstable angina pectoris
UKPDS | United Kingdom Prospective Diabetes Study
ULN | Upper limit of normal
W | White
WBQ-12 | Well-being Questionnaire 12
WHI | Women's Health Initiative
WHO | World Health Organization
wks | Weeks
WOSCOS | West of Scotland Coronary Prevention Study
XENDOS | Xenical in the Prevention of Diabetes in Obese Subjects
y | Year