# Acknowledgements

We are grateful for the feedback and guidance provided by our expert consultant and reviewers: David J. Pettitt, MD (consultant); Marie-Aline Charles, MD; David Hadden, MD; Boyd Metzger, MD; and Catherine Spong, MD.