# References

1) Diagnosis and classification of diabetes mellitus. Diabetes Care 2006; 29 Suppl 1:S43–S48.
2) American College of Obstetricians and Gynecologists Committee on Practice Bulletins-. ACOG Practice Bulletin. Clinical management guidelines for obstetrician-gynecologists. Number 30, September 2001 (replaces Technical Bulletin Number 200, December 1994). Gestational diabetes. Obstetrics & Gynecology 98(3):525–38, 2001.
3) Metzger BE, Coustan DR. Summary and recommendations of the Fourth International Workshop-Conference on Gestational Diabetes Mellitus. The Organizing Committee. Diabetes Care. 1998;21(Suppl 2):B161-B167. [pmid: 9704245].
4) Jovanovic L, Pettitt DJ. Gestational diabetes mellitus. JAMA. 2001;286(20):2516-8. [pmid: 11722247].
5) Brody SC, Harris R, Lohr K. Screening for gestational diabetes: a summary of the evidence for the U.S. Preventive Services Task Force. Obstet Gynecol. 2003;101(2):380-392. [pmid: 12576264].
6) U.S.Preventive Services Task Force. Scrrening for diabetes mellitus. In: Office Disease Prevention and Health Promotion, editor. Guide to Clinical Preventive Services. Washington, D.C.: U.S. Government Printing Office, 1996: 193–208.
7) Ben Haroush A, Yogev Y, Hod M. Epidemiology of gestational diabetes mellitus and its association with Type 2 diabetes. Diabetic Medicine 21(2):103–13, 2004.
8) Ahluwalia IB, Mack KA, Mokdad A. Report from the CDC. Changes in selected chronic disease-related risks and health conditions for nonpregnant women 18–44 years old BRFSS. J Womens Health (Larchmt ). 2005;14(5):382-386. [pmid: 15989409].
9) Dabelea D, Snell-Bergeon JK, Hartsfield CL, Bischoff KJ, Hamman RF, McDuffie RS. Increasing prevalence of gestational diabetes mellitus (GDM) over time and by birth cohort: Kaiser Permanente of Colorado GDM Screening Program. Diabetes Care. 2005;28(3):579-584. [pmid: 15735191].
10) Ferrara A, Kahn HS, Quesenberry CP, Riley C, Hedderson MM. An increase in the incidence of gestational diabetes mellitus: Northern California, 1991-2000. Obstetrics & Gynecology 103(3):526–33, 2004.
11) Mean Body Weight, Height, and Body Mass Index (BMI) 1960-2002 http://origin.cdc.gov/nchs/data/ad/ad347.pdf
12) Moum KR, Holzman GS, Harwell TS, Parsons SL, Adams SD, Oser CS, et al. Increasing rate of diabetes in pregnancy among American Indian and white mothers in Montana and North Dakota, 1989-2000. Maternal & Child Health Journal. 2004;8(2):71-6. [pmid: 15198174].
13) Griffin ME, Coffey M, Johnson H, Scanlon P, Foley M, Stronge J, et al. Universal vs. risk factor-based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabetic Medicine. 2000;17(1):26-32. [pmid: 10691156].
14) Aldrich CJ, Moran PA, Gillmer MD. Screening for gestational diabetes in the United Kingdom: a national survey. J Obstet Gynaecol. 1999;19(6):575-579. [pmid: 15512404].
15) Luke C, Kemper I, Henschen S, Buhling KJ. [Diagnosis and therapy of gestational diabetes—comparison of two surveys of established gynecologists in Berlin and Saxonia-Anhalt ]. Z Geburtshilfe Neonatol. 2005;209(6):219-222. [pmid: 16395638].
16) Touzet S, Rocher L, Dureau-Drevard E, Poncet B, Colin C, Orgiazzi J, et al. [Patterns physicians use to screen for gestational diabetes: descriptive analysis in a cohort of 701 women]. J Gynecol Obstet Biol Reprod (Paris). 2002;31(3):248-255. [pmid: 12016403].
17) Rumbold AR, Crowther CA. Guideline use for gestational diabetes mellitus and current screening, diagnostic and management practices in Australian hospitals. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2001;41(3):285-90. [pmid: 11592542].
18) Gabbe SG, Gregory RP, Power ML, Williams SB, Schulkin J. Management of diabetes mellitus by obstetrician-gynecologists. Obstetrics & Gynecology. 2004;103(6):1229-34. [pmid: 15172857].
19) Alberti KG, Zimmet PZ. Definition, diagnosis and classification of diabetes mellitus and its complications. Part 1: diagnosis and classification of diabetes mellitus provisional report of a WHO consultation. Diabet Med. 1998;15(7):539-553. [pmid: 9686693].
20) Esakoff TF, Cheng YW, Caughey AB. Screening for gestational diabetes: different cut-offs for different ethnicities?. Am J Obstet Gynecol. 2005;193(3 Pt 2):1040-1044. [pmid: 16157108].
21) Friedman S, Khoury-Collado F, Dalloul M, Sherer DM, Abulafia O. Glucose challenge test threshold values in screening for gestational diabetes among black women. American Journal of Obstetrics & Gynecology 194;(5):e46–e48.
22) Gabbe SG, Niebyl JR, Simpson JL. Obstetrics, Normal and Problem Pregnancies. 4th ed. New York: Churchill Livingston, 2002.
23) Metzger BE PLPR. Diabetes Mellitus and Pregnancy. In: DeGroot LJ, editor. Endocrinology. Philadelphia, PA: W.B. Saunders Company, 1995: 1464–1481.
24) Unger RH FD. Diabetes Mellitus. In: Wilson JD FDKHLP, editor. William's Textbook of Endocrinology. Philadelphia, PA: W.B. Saunders Company, 1998: 973–1059.
25) Langer O. Management of gestational diabetes: pharmacologic treatment options and glycemic control. Endocrinology & Metabolism Clinics of North America 35(1):53–78, vi, 2006.
26) Schaefer-Graf UM, Buchanan TA, Xiang A, Songster G, Montoro M, Kjos SL. Patterns of congenital anomalies and relationship to initial maternal fasting glucose levels in pregnancies complicated by type 2 and gestational diabetes. American Journal of Obstetrics & Gynecology. 2000;182(2):313-320. [pmid: 10694330].
27) Confidential Enquiry into Maternal and Child Health: Pregnancy in Women with Type 1 and Type 2 diabetes in 2002-03, England, Wales and Northern Ireland. CEMACH, editor. 2005. London. Ref Type: Report
28) Cundy T, Gamble G, Townend K, Henley PG, MacPherson P, Roberts AB. Perinatal mortality in Type 2 diabetes mellitus. Diabetic Medicine. 2000;17(1):33-39. [pmid: 10691157].
29) Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine 1920;(3 Suppl):21–35.
30) Turok DK, Ratcliffe SD, Baxley EG. Management of gestational diabetes mellitus. American Family Physician. 2003;68(9):1767-72. [pmid: 14620596].
31) Schwartz ML, Ray WN, Lubarsky SL. The diagnosis and classification of gestational diabetes mellitus: is it time to change our tune?. Am J Obstet Gynecol. 1999;180(6 Pt 1):1560-1571. [pmid: 10368504].
32) Deerochanawong C, Putiyanun C, Wongsuryrat M, Serirat S, Jinayon P. Comparison of National Diabetes Data Group and World Health Organization criteria for detecting gestational diabetes mellitus. Diabetologia. 1996;39(9):1070-1073. [pmid: 8877291].
33) de Sereday MS, Damiano MM, Gonzalez CD, Bennett PH. Diagnostic criteria for gestational diabetes in relation to pregnancy outcome. J Diabetes Complications. 2003;17(3):115-119. [pmid: 12738394].
34) Sacks DA, Abu-Fadil S, Greenspoon JS, Fotheringham N. How reliable is the fifty-gram, one-hour glucose screening test?. Am J Obstet Gynecol. 1989;161(3):642-645. [pmid: 2782346].
35) Harlass FE, Brady K, Read JA. Reproducibility of the oral glucose tolerance test in pregnancy. American Journal of Obstetrics & Gynecology. 1991;164(2):564-8. [pmid: 1992702].
36) Schmidt MI, Duncan BB, Reichelt AJ, Branchtein L, Matos MC, Costa e Forti, et al. Gestational diabetes mellitus diagnosed with a 2-h 75-g oral glucose tolerance test and adverse pregnancy outcomes. Diabetes Care. 2001;24(7):1151-1155. [pmid: 11423494].
37) Bito T, Nyari T, Kovacs L, Pal A. Oral glucose tolerance testing at gestational weeks < or =16 could predict or exclude subsequent gestational diabetes mellitus during the current pregnancy in high risk group. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):51-55. [pmid: 15989984].
38) Bancroft K, Tuffnell DJ, Mason GC, Rogerson LJ, Mansfield M. A randomised controlled pilot study of the management of gestational impaired glucose tolerance. BJOG. 2000;107(8):959-963. [pmid: 10955425].
39) Crowther CA, Hiller JE, Moss JR, McPhee AJ, Jeffries WS, Robinson JS, et al. Effect of treatment of gestational diabetes mellitus on pregnancy outcomes. New England Journal of Medicine. 2005;352(24):2477-86. [pmid: 15951574].
40) de Veciana M, Major CA, Morgan MA, Asrat T, Toohey JS, Lien JM, et al. Postprandial versus preprandial blood glucose monitoring in women with gestational diabetes mellitus requiring insulin therapy. N Engl J Med. 1995;333(19):1237-1241. [pmid: 7565999].
41) Jovanovic L, Ilic S, Pettitt DJ, Hugo K, Gutierrez M, Bowsher RR, et al. Metabolic and immunologic effects of insulin lispro in gestational diabetes. Diabetes Care. 1999;22(9):1422-1427. [pmid: 10480503].
42) Langer O. A comparison of glyburide and insulin in women with gestational diabetes mellitus. N Engl J Med. 2000;343(16):1134-1138. [pmid: 11036118].
43) Nachum Z, Ben Shlomo I, Weiner E, Shalev E. Twice daily versus four times daily insulin dose regimens for diabetes in pregnancy: randomised controlled trial. BMJ. 1999;319(7219):1223-1227. [pmid: 10550081]. [pmcid: 28269].
44) O'Sullivan JB, Gellis SS, Dandrow RV, Tenney BO. The potential diabetic and her treatment in pregnancy. Obstetrics & Gynecology. 1966;27:683-689. [pmid: 5936737].
45) Bartha JL, Martinez-Del-Fresno P, Comino-Delgado R. Gestational diabetes mellitus diagnosed during early pregnancy.[see comment]. American Journal of Obstetrics & Gynecology. 2000;182(2):346-50. [pmid: 10694335].
46) Crowther C. Personal Communication. 7-25-2006.
47) Langer O, Yogev Y, Xenakis EM, Rosenn B. Insulin and glyburide therapy: dosage, severity level of gestational diabetes, and pregnancy outcome. American Journal of Obstetrics & Gynecology 2005;(1):134–139.
48) U.S.Census Bureau. Staistical Abstract of the United States. 2006. 125th ed. Washington, D.C.: 2005.
49) Rumbold AR, Crowther CA. Women's experiences of being screened for gestational diabetes mellitus.[see comment]. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2002;42(2):131-7. [pmid: 12069138].
50) Spirito A, Williams C, Ruggiero L, Bond A, McGarvey ST, Coustan D. Psychological impact of the diagnosis of gestational diabetes. Obstet Gynecol. 1989;73(4):562-566. [pmid: 2648224].
51) Daniells S, Grenyer BF, Davis WS, Coleman KJ, Burgess JA, Moses RG. Gestational diabetes mellitus: is a diagnosis associated with an increase in maternal anxiety and stress in the short and intermediate term?. Diabetes Care. 2003;26(2):385-389. [pmid: 12547867].
52) Marteau TM, Bekker H. The development of a six-item short-form of the state scale of the Spielberger State-Trait Anxiety Inventory (STAI). Br J Clin Psychol. 1992;31(Pt 3):301-306. [pmid: 1393159].
53) Cox JL, Holden JM, Sagovsky R. Detection of postnatal depression. Development of the 10-item Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1987;150:782-786. [pmid: 3651732].
54) Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30(6):473-483. [pmid: 1593914].
55) Williams Obstetrics. 22nd ed. New York: McGraw Hill, 2005.
56) Langer N, Langer O. Emotional adjustment to diagnosis and intensified treatment of gestational diabetes. Obstet Gynecol. 1994;84(3):329-334. [pmid: 8058225].
57) Wickstrom G, Bendix T. The “Hawthorne effect”—what did the original Hawthorne studies actually show?. Scand J Work Environ Health. 2000;26(4):363-367. [pmid: 10994804].
58) Ruta D, Garratt A, Abdalla M, Buckingham K, Russell I. The SF 36 health survey questionnaire. A valid measure of health status. BMJ. 1993;307(6901):448-9. [pmid: 8374477].
59) McHorney CA, Ware JE Jr, Rogers W, Raczek AE, Lu JF. The validity and relative precision of MOS short- and long-form health status scales and Dartmouth COOP charts. Results from the Medical Outcomes Study. Medical Care. 1992;30(5 Suppl):MS253-65. [pmid: 1583937].
60) Stewart AL, Greenfield S, Hays RD, Wells K, Rogers WH, Berry SD, et al. Functional status and well-being of patients with chronic conditions. Results from the Medical Outcomes Study. [erratum appears in JAMA 1989 Nov 10;262(18):2542]. JAMA. Nov 10. 1989;262(7):907-13. [pmid: 2754790].
61) Montori VM, Busse JW, Permanyer-Miralda G, Ferreira I, Guyatt GH. How should clinicians interpret results reflecting the effect of an intervention on composite endpoints: should I dump this lump?. ACP Journal Club. 2005;143(3):A8. Dec. [pmid: 15989296].
62) O'Sullivan JB, Mahan CM. Criteria for the oral glucose tolerance test in pregnancy. Diabetes. 1964;13:278-285. [pmid: 14166677].
63) O'Sullivan JB. Establishing criteria for gestational diabetes. Diabetes Care. 1980;3(3):437-9. Jun. [pmid: 7389559].
64) Prevalence of Overweight and Obesity Among Adults: United States, 1999-2002 http://www.cdc.gov/nchs/products/pubs/pubd/hestats/obese/obse99.htm 8-23-2006
65) Mokdad AH, Serdula MK, Dietz WH, Bowman BA, Marks JS, Koplan JP. The spread of the obesity epidemic in the United States, 1991-1998. JAMA. 1999;282(16):1519-22. [pmid: 10546690].
66) Mokdad AH, Ford ES, Bowman BA, Nelson DE, Engelgau MM, Vinicor F, et al. Diabetes trends in the U.S.: 1990-1998. Diabetes Care. 2000;23(9):1278-83. [pmid: 10977060].
67) Hillier TA, Pedula KL. Characteristics of an adult population with newly diagnosed type 2 diabetes: the relation of obesity and age of onset. Diabetes Care. 2001;24(9):1522-7. [pmid: 11522693].
68) Harris MI, Flegal KM, Cowie CC, Eberhardt MS, Goldstein DE, Little RR, et al. Prevalence of diabetes, impaired fasting glucose, and impaired glucose tolerance in U.S. adults. The Third National Health and Nutrition Examination Survey, 1988-1994. Diabetes Care. 1998;21(4):518-524. [pmid: 9571335].
69) Coustan DR. Making the diagnosis of gestational diabetes mellitus. Clinical Obstetrics & Gynecology. 2000;43(1):99-105. [pmid: 10694992].
70) Classification and diagnosis of diabetes mellitus and other categories of glucose intolerance. Diabetes Data Group. Diabetes 1979; 28(12):1039–1057.
71) Carpenter MW, Coustan DR. Criteria for screening tests for gestational diabetes. Am J Obstet Gynecol. 1982;144(7):768-773. [pmid: 7148898].
72) Diabetes mellitus. Report of a WHO Study Group. World Health Organ Tech Rep Ser 1985; 727:1–113.
73) DeGroot LJ. Endocrinology. Philadelphia, PA: W.B. Saunders Company, 1995.
74) Gabbe SG. The gestational diabetes mellitus conferences. Three are history: focus on the fourth. Diabetes Care. 1998;21(Suppl 2):B1-B2. [pmid: 9538961].
75) Kjos SL, Buchanan TA, Greenspoon JS, Montoro M, Bernstein GS, Mestman JH. Gestational diabetes mellitus: the prevalence of glucose intolerance and diabetes mellitus in the first two months post partum. American Journal of Obstetrics & Gynecology. 1990;163(1 Pt 1):93-8. [pmid: 2375376].
76) Dornhorst A, Rossi M. Risk and prevention of type 2 diabetes in women with gestational diabetes. Diabetes Care. 1998;21(Suppl 2):B43-9. [pmid: 9704226].
77) Dorner G, Mohnike A. Further evidence for a predominantly maternal transmission of maturity-onset type diabetes. Endokrinologie. 1976;68(1):121-124. [pmid: 1001263].
78) Eckert JE, Gatford KL, Luxford BG, Campbell RG, Owens PC. Leptin expression in offspring is programmed by nutrition in pregnancy. J Endocrinol. 2000;165(3):R1-R6. [pmid: 10750030].
79) Freinkel N. Banting Lecture 1980. Of pregnancy and progeny. Diabetes. 1980;29(12):1023-1035. [pmid: 7002669].
80) Levin BE, Govek E. Gestational obesity accentuates obesity in obesity-prone progeny. Am J Physiol. 1998;275(4 Pt 2):R1374-R1379. [pmid: 9756571].
81) Levin BE. The obesity epidemic: metabolic imprinting on genetically susceptible neural circuits. Obes Res. 2000;8(4):342-347. [pmid: 10933311].
82) Martorell R, Stein AD, Schroeder DG. Early nutrition and later adiposity. J Nutr. 2001;131(3):874S-880S. [pmid: 11238778].
83) Pettitt DJ, Knowler WC. Long-term effects of the intrauterine environment, birth weight, and breast-feeding in Pima Indians. Diabetes Care. 1998;21(Suppl 2):B138-B141. [pmid: 9704241].
84) Pettitt DJ, Baird HR, Aleck KA, Bennett PH, Knowler WC. Excessive obesity in offspring of Pima Indian women with diabetes during pregnancy. N Engl J Med. 1983;308(5):242-245. [pmid: 6848933].
85) Pettitt DJ, Aleck KA, Baird HR, Carraher MJ, Bennett PH, Knowler WC. Congenital susceptibility to NIDDM. Role of intrauterine environment. Diabetes. 1988;37(5):622-628. [pmid: 3360218].
86) Silverman BL, Rizzo T, Green OC, Cho NH, Winter RJ, Ogata ES, et al. Long-term prospective evaluation of offspring of diabetic mothers. Diabetes. 1991;40(Suppl 2):121-125. [pmid: 1748240].
87) Silverman BL, Metzger BE, Cho NH, Loeb CA. Impaired glucose tolerance in adolescent offspring of diabetic mothers. Relationship to fetal hyperinsulinism. Diabetes Care. 1995;18(5):611-617. [pmid: 8585997].
88) Vohr BR, McGarvey ST, Tucker R. Effects of maternal gestational diabetes on offspring adiposity at 4–7 years of age. Diabetes Care. 1999;22(8):1284-1291. [pmid: 10480772].
89) Boney CM, Verma A, Tucker R, Vohr BR. Metabolic syndrome in childhood: association with birth weight, maternal obesity, and gestational diabetes mellitus. Pediatrics. 2005;115(3):e290-e296. [pmid: 15741354].
90) Langer O, Rodriguez DA, Xenakis EM, McFarland MB, Berkus MD, Arrendondo F. Intensified versus conventional management of gestational diabetes. Am J Obstet Gynecol. 1994;170(4):1036-1046. [pmid: 8166187].
91) Whitaker RC, Pepe MS, Seidel KD, Wright JA, Knopp RH. Gestational diabetes and the risk of offspring obesity. Pediatrics. 1998;101(2):E9. [pmid: 9445519].
92) Boyd KL. Personal Communication 2006.
93) HAPO Study Cooperative Research Group. The Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. International Journal of Gynaecology & Obstetrics. 2002;78(1):69-77. [pmid: 12113977].
94) Landon MB, Vickers S. Fetal surveillance in pregnancy complicated by diabetes mellitus: is it necessary?. Journal of Maternal-Fetal & Neonatal Medicine. 2002;12(6):413-6. [pmid: 12683653].
95) National Institute of Child Health and Human Development Maternal Fetal Medicine Units Network http://www.bsc.gwu.edu/mfmu/Projects/brieftrl.cgi 10-22-2006
96) Austrailian Clinical Trials Registry http://www.actr.org.au/ 10-22-2006