# Discussion

## Summary of Review Findings

The details of each included study are available in the Evidence Tables, and results are synthesized in Table 4. The best new evidence comes from a good quality RCT, ACHOIS,^39^ which is the first RCT to compare treatment of mild GDM to no treatment. ACHOIS found that treatment improved outcomes in mild GDM (severe levels of hyperglycemia in the pre-existing diabetes range were excluded), with a statistically significant reduction in both serious neonatal (as a composite outcome) and maternal outcomes. There was no evidence of harm to mother or infant with treatment. In a sub-set of participants who responded to a post-partum questionnaire, mothers treated for GDM were significantly less depressed and, on a few measures that differed by treatment group, had better quality-of-life three months post-partum; these post-partum data have some limitations.

In a review by the American College of Physicians' Journal Club, the major criticism in was that the ACHOIS investigators' use of a composite outcome given the rare individual neonatal events. While this composite outcome was significantly improved, the Journal Club review commented that it was not reasonable to combine mortality with the range of morbidities, particularly since the more-prevalent shoulder dystocia was driving the overall results.^61^ While it is true that these outcomes differ in severity, all of the serious rare outcomes (death, bone fracture, nerve palsy) occurred in zero cases of the treated group and ranged from one to five events for each outcome in the non-treated group. In particular, although perinatal and neonatal mortality are rare, there were zero deaths with treatment, compared to five deaths without treatment (three stillbirths, two neonatal deaths). The causes of the five deaths in the untreated group with mild GDM were: two stillbirths (unexplained intrauterine deaths at term of appropriately grown infants), one stillbirth at 35 weeks gestation associated with pre-eclampsia and intrauterine growth restriction, one death from asphyxia during labor without antepartum hemorrhage, and one lethal congenital anomaly. It would be ideal to know how glycemic control differed between the two groups in order to discern any relative contribution of improved glycemic control compared to the diminished weight gain in pregnancy that resulted from treatment. Nevertheless, regardless of mechanism, treatment of mild GDM improved neonatal and maternal outcomes.

This new evidence adds to the evidence that began with O'Sullivan's RCT findings of a reduction in macrosomia with GDM treatment compared to no treatment.^44^ With the results of the ACHOIS trial, there is additional evidence that benefits may be extended beyond macrosomia to other maternal outcomes and a composite neonatal outcome. Several of the treatment comparison trials that achieved differences in glycemic control also suggest that improved glycemic control with intensified management (whether postprandial monitoring or four times daily) reduces perinatal complications. Overall, the evidence suggests that the improved outcomes observed with GDM treatment occur without apparent harm, including no evidence of worsened significant maternal hypoglycemia with treatment. Finally, available evidence suggests that diagnosis and treatment of GDM does not worsen maternal quality-of-life-except possibly transiently for the first few weeks after diagnosis. As early as six weeks after diagnosis continuing to at least three months post-partum women treated for GDM may have improved self-rated quality-of-life, including half the risk of post-partum depression compared to women not treated for GDM. Although this evidence has limitations in establishing a benefit to maternal quality-of-life with treatment, there is no evidence of harm in this domain with treatment of GDM.

## Contextual Issues

### Background of Increasing Obesity in US population

When O'Sullivan conducted the first RCT of GDM screening and treatment,^44^ obesity was rare in the US and type 2 diabetes was virtually unseen in young women of child-bearing age. Less than 30 percent of women diagnosed with GDM in O'Sullivan's study were more than 120 percent of their ideal body weight.^44^ In a separate cohort study by O'Sullivan of 752 GDM women in the 1960s, only 2 percent of women who tested positive for GDM had persistent diabetes immediately after pregnancy, but the remainder had a 16-year cumulative risk of developing type 2 diabetes of over 60 percent.^62,63^ Currently, two-thirds of all US adults are estimated to be overweight or obese,^64^ and there has been a parallel epidemic of type 2 diabetes in US adults, with young adults, especially females, representing the fastest growing group for obesity and type 2 diabetes.^65^–^67^ For every two adults diagnosed with diabetes in the US, one remains undiagnosed.^68^ Thus, against a background of increasing obesity and type 2 diabetes, increasing rates of previously unrecognized diabetes during pregnancy are an increasingly important issue in current clinical practice. The recent US obesity epidemic also makes it increasingly important to distinguish the effect of obesity and previously unrecognized diabetes in pregnancy (also classified as GDM) from diabetes with transient onset during pregnancy when evaluating the evidence for GDM screening and treatment. In the ACHOIS results reported by Crowther and colleagues, the median BMIs of the treated and untreated groups were similar after randomization (26.8 and 26.0 kg/m2, respectively). By designing the study to include only mild GDM (fasting plasma glucose of < 7.8 mmol/l and 2 hour post OGTT 7.8–11.0 mmol/l), tested at a median of 29 weeks gestation, the ACHOIS investigators excluded severe pre-existing but unrecognized diabetes.

### Different International Diagnostic Standards for Gestational Diabetes

In the United States, a two-step approach to screening and diagnosis of GDM (1-hour 50 g GCT, followed by a 100 g diagnostic OGTT) has been the most common method of GDM diagnosis for over 4 decades, based on early work by O'Sullivan in which he demonstrated the relation between the 100 g, 3 hour OGTT in 752 pregnant women and their subsequent long-term risk of developing type 2 diabetes.^62^ His original work was based on testing of whole blood. Serum and plasma glucose values—which became the new technique of measuring glucose—are approximately 14 percent higher than whole blood values.^69^ To account for this change between whole blood and plasma glucose measures, both the National Diabetes Data Group (NDDG) in 1979 and Carpenter and Coustan (C&C) in 1982 developed slightly different criteria based on mathematical conversions of the original O'Sullivan data.^69^–^71^ The most recently published Fourth International Workshop Conference on Gestational Diabetes Mellitus recommended using the C&C criteria—which yield a higher prevalence of GDM—based on data presented at the meeting that the women who met the lower C&C threshold “were at similar risk for perinatal morbidity, including macrosomia.”^3^ These C&C criteria for the 100 g OGTT are currently diagnostic for the ADA,^1^ and ACOG uses both NDDG and C&C.^2^ The initial screening 50 g GCT, also evaluated by O'Sullivan, had an initial non-fasting 1-hour cutoff of 130 mg/dl using whole blood glucose values;^62,63^ this was also later revised to a 140 mg/dl 1-hour cutoff to compensate for the higher values in plasma or serum compared to whole blood.^69^ Both a 140 mg/dl and 130 mg/dl plasma or serum 1 hour cutoff value are recommended with the 2 step approach in current US clinical recommendations.^1,2^

In the US, while the 2 hour 75 g OGTT is also now recognized as an acceptable method of diagnosing GDM,^1^–^3^ it is most commonly used for diagnosis of diabetes outside of pregnancy. In contrast, the WHO diagnostic criterion for GDM is the 2 hour 75 g OGTT, which is used for GDM diagnosis by most countries outside the US. When the ACHOIS was initiated, WHO distinguished mild GDM (2 hour plasma glucose after the 75 g OGTT > 7.8 mmol/l [140 mg/dl] but less than 11.0 mmol/l [200 mg/dl]) as “glucose intolerance of pregnancy.”^72^ In 1998, WHO revised the criteria to consider any glucose value > 7.8 mmol/l 2 hours after the 75 g OGTT during pregnancy as diagnostic of GDM.^19^ Thus, the recently published ACHOIS results provide a unique opportunity to evaluate the evidence for outcomes with mild GDM treatment versus non-treatment. The ACHOIS design likely could not be replicated today, as most Institutional Review Boards that govern research in human subjects would consider it unethical not to treat gestational diabetes with current practice standards. ACHOIS findings also provide the first good RCT evidence of improved perinatal and maternal outcomes with treatment versus non-treatment of mild GDM. These results in GDM diagnosed by a 75 g OGTT will likely intensify the conundrum of the best clinical criteria for diagnosis of GDM. The ACHOIS screening method represents a mix of several current approaches, as the first step was the 50 g GCT or risk factors (93 percent were positive on the GCT). The second step was the diagnostic 75 g OGTT. However, it is the charge of the USPSTF to evaluate and present the evidence, and despite the added controversy on the best screening method, the ACHOIS findings provide us with important good-quality new evidence on maternal and perinatal outcomes with treatment versus no treatment of GDM.

### Timing of Gestational Screening

During a normal pregnancy, glucose values will decrease during the first trimester, before they begin to rise higher than in non-pregnancy during the second trimester due to physiologic insulin resistance that results from pregnancy-related hormones.^25,^,^23,73^ This insulin resistance stabilizes glucose levels for the rapidly growing fetus between its mother's meals. That is, pregnancy is the only condition in which developing a diabetogenic state is normal physiology.^23^

The purpose of GDM screening is to identify women who have an excessive (pathologic) increase in glucose while they became transiently insulin resistant in the second trimester (and reduce related complications). This is the basis for the original recommendations to time GDM screening between the 24^th^ and 28^th^ week of gestation.^74^ O'Sullivan found only 2 percent of his sample had persistent diabetes after pregnancy, although the 16-year cumulative incidence of developing diabetes again after pregnancy was 60 percent.^63^ A study in 1990 found that 9 percent of women with GDM had persistent type 2 diabetes after pregnancy, and an additional 10 percent had impaired glucose tolerance.^75^ With the markedly increased US rates of obesity and type 2 diabetes in the last decade, previously unrecognized diabetes - also classified as GDM - that persists after pregnancy is likely now even higher. Thus, identifying women at high risk for unrecognized type 2 diabetes early in pregnancy (also classified as GDM) is increasing against the background of increasing prevalence of type 2 diabetes among women of child-bearing age in the US.

Clinical practice has changed based on clinical practice recommendations to also consider screening for previously unrecognized diabetes (defined as GDM if first recognized during pregnancy) in very high-risk women at the first prenatal visit.^1^ In addition to the 1-step and 2-step OGTT diagnostic test, a fasting plasma glucose > 126 mg/dl or a random plasma glucose > 200 mg/dl on two occasions is also part of practice guidelines for diagnosing previously unrecognized diabetes in the first trimester.^1^

The timing of diagnosis in pregnancy must be considered when evaluating the evidence, as those who can be diagnosed in the first trimester (previously unrecognized diabetes) represent a different group than those women who meet criteria beginning in the second trimester (onset of diabetes in pregnancy). Although we searched extensively, we found no good-quality evidence that evaluated screening or treatment of gestational diabetes early in pregnancy. The one fair-quality included RCT for screening by O'Sullivan did not specify the mean age of diagnosis, but over 97 percent of women with GDM had normal glucose tolerance within six months of delivery,^44^ the population is certainly one with onset of diabetes during pregnancy. All but one of the studies that met inclusion criteria for evidence of treatment were also in women diagnosed ≥ 24 weeks gestation (Table 2). Thus, current evidence about screening for GDM is limited to screening at 24 weeks or more gestation.

## Additional Considerations

### Are there other positive outcomes of screening for mother and/or infant?

We did not systematically review the evidence for potential long-term benefits to a mother or her future child that could arise from screening for GDM during pregnancy. Likewise, none of the included studies in this review evaluated these long-term outcomes. However, we will briefly summarize these potential long-term benefits. It is well recognized that women who develop GDM during pregnancy have an increased risk of future type 2 diabetes after pregnancy.^76^ O'Sullivan's original evaluation of a cohort of GDM women, on which current diagnostic criteria for the OGTT are based, used the sensitivity and specificity of the OGTT as it related to future type 2 diabetes in the mother, not to macrosomia or other neonatal outcomes.^62,^,^63,69^ In the 1960s, type 2 diabetes was primarily a future risk. As the prevalence of type 2 diabetes in young adults (and women) rises, screening for GDM has the increasing additional benefit of identifying women with previously unrecognized type 2 diabetes - in addition to those at future risk of developing it.

A plethora of recent work has studied the possibility that a hyperglycemic intrauterine environment may adversely program, or imprint, the metabolic system of the fetus for increased risk of future obesity and type 2 diabetes. While a parental history of diabetes increases a person's risk of type 2 diabetes, the “metabolic imprinting” of a diabetes pregnancy increases the child's risk of obesity and type 2 diabetes more than would be predicted from genetics alone.^77^–^83^ Diabetes in pregnancy has been associated with an increased rate of childhood obesity, impaired glucose tolerance, the Metabolic Syndrome, and type 2 diabetes in the offspring;^84^–^89^ Pettit et al found that obesity in Pima offspring of women with diabetes (ODM) was independently associated with maternal diabetes in pregnancy after controlling for maternal obesity.^84^ Pettit and colleagues subsequently showed that by age 20–24, 45 percent of ODM had developed type 2 diabetes in the Pima population, compared to 8.6 percent of offspring of women who did not have diabetes during pregnancy but developed type 2 diabetes after pregnancy, and only 1.4 percent of offspring had developed type 2 diabetes by age 20–24 if their mother had not had GDM or later type 2 diabetes.^85,90^ These data suggest that the metabolic milieu in women with diabetes in pregnancy alters the metabolic make-up of the offspring beyond that expected by genetics alone. Pre-existing (diagnosed) diabetes was not distinguished from GDM in most of these studies of diabetes in pregnancy, so it is difficult to evaluate the independent effect that GDM would have on childhood obesity or type 2 diabetes risk. One cohort study evaluating obesity in offspring associated with mild, diet-treated GDM found no difference in obesity risk at age 5–10 years in 58 children of mothers with mild GDM compared to 257 children whose mothers did not have GDM.^91^ In summary, the data on long-term risk to the offspring of GDM women remain limited at this time.

### Does treatment for GDM affect intermediate outcomes (cesarean section/operative delivery, induction of labor, perineal lacerations, macrosomia)?

Although these intermediate outcomes were not systematically reviewed, if they were reported in the studies included for other key questions (and primary outcomes), they were also abstracted and summarized under the key questions (Appendix C).

### If screening for GDM is found to be effective, what are the cost implications?

We did not systematically review the evidence for cost implications. Similarly, cost-effective analyses were beyond the scope of this update.

## Limitations

We found no evidence base for trials of screening programs to test screened versus unscreened populations. However, both current clinical practice patterns for GDM and ethical constraints on research in human subjects would now likely preclude such a study in the US. Thus, the available evidence base comprises studies in screen-detected populations diagnosed with GDM and randomized to treatment versus no treatment.

Evaluating the potential benefit and harms of screening and treatment of GDM is limited by lack of a consistent standard for screening or diagnosis, multiple potential outcomes for two individuals (mother and baby) that are not unique outcomes to GDM. To have consistency in interpreting potential benefits and harms, the Task Force limited this review to current national and international standard criteria for diagnosis of GDM. Use of this consistent definition of GDM resulted in eliminating some studies considered in other reviews.

Available evidence, including the ACHOIS RCT of screen-detected treated versus non-treated women with GDM did not reveal evidence of harm. However, there is little information available on harms of treatment as these are relatively rare outcomes and may not be evident in trials.

Antepartum surveillance (e.g., ultrasound and non-stress test evaluations of the pregnancy to determine if delivery should be induced) was specifically restricted from the scope of this review by the Task Force. However, it is possible that increased antepartum surveillance of women diagnosed with GDM could result in harms that were not evaluated with this review.

## Emerging Issues/Next Steps

There is increasing need to evaluate screening and treatment of GDM for very high-risk women in the first trimester (previously unrecognized type 2 diabetes), but currently no high quality evidence is available to guide us. Both conditions that GDM encompasses (previously unrecognized type 2 diabetes and the transient abnormality of glucose tolerance during pregnancy) are important to evaluate—but separately—for their impact on maternal and neonatal outcomes. Larger observational studies and clinical trials in medical care settings are needed to assess this emerging issue.

Despite the recent good-quality evidence from ACHOIS that treating GDM can reduce a composite perinatal morbidity and mortality outcome, the trial does not address the issues of how glycemic level may relate to outcomes, and what an ideal diagnostic threshold may be. Also, ACHOIS does not provide evidence to validate the current 2-step diagnostic method most commonly used in the US; two large studies are now under way that address these issues. The HAPOprospective cohort study of 25,000 pregnant women in 10 countries is nearing completion and preliminary results may be available next year.^92^ Women in HAPO are screened at 24–32 weeks gestation with a 75 g OGTT, and enrolled to be observed untreated with mild GDM, with results blinded to the women and their caregivers if they do not have glucose values that are outside predefined levels (FPG >105 mg/dl and/or 2-hr OGTT glucose >200mg/dl, random plasma glucose at 34–37 weeks > 160 mg/dl, or a value any time < 45 mg/dl). The aim is to determine how differing levels of glucose relate to outcomes, and if this relationship is continuous or has an ideal cut-point. The primary outcomes assessed in the trial are cesarean rates (with blinded providers), fetal size (macrosomia/LGA/obesity), neonatal hypoglycemia, and fetal hyperinsulinism.^93^ The blinding of this study is an important design in this cohort study, as many prior studies that have compared outcomes in general populations to the consequences of GDM, or to outcomes of pregnancies that are complicated by GDM, did not address the likely provider bias that diagnosis and treatment of the GDM potentially has in making obstetrical decisions. Thus they are not able to separate the impact on hyperglycemia per se on these outcomes. Also, a multi-center RCT, conducted by the academic centers participating in the Maternal-Fetal Medicine Unit network (MFMU), and sponsored by NICHD—is still recruiting, so results are more than several years from being available. This multi-center US trial is designed to test outcomes with treatment versus no treatment of mild GDM detected by a 2-step approach (with 1-hour 50 g GCT values of 135 mg to 200 mg/dl, and for the 3-hour 100 g OGTT a normal fasting level of < 95 mg/dl and two of the three remaining post-challenge measurements abnormal.^94,95^ There is also a RCT comparing treatment of metformin to insulin which is under way in Australia, the Metformin in Pregnancy (MiG) trial, that will provide the first evidence of metformin treatment in GDM.^96^

## Future Research

Several important gaps in current evidence need further research. Prospective studies evaluating the prevalence, sensitivity, and specificity of current diagnostic tests as they relate to primary outcomes of GDM would help with the conundrum about the best way to screen and diagnose GDM. Research is also strongly needed evaluating early screening of GDM in the first trimester—both to determine the best screening method for this high-risk group, but also to determine the additional value of early screening compared to current screening practices at 24–28 weeks gestation.

## Conclusions

When considering the final evidence to guide GDM screening recommendations, it is important to weigh the evidence in light of the unique screening circumstances that screening and treatment one individual has the potential to benefit or harm two individuals (mother and baby).

Our systematic review found very limited evidence for screening and treatment of GDM diagnosed less than 24 weeks gestation—one fair-quality prospective cohort study, which suggests that an early diagnosis of GDM may represent pre-gestational diabetes as women diagnosed early were more likely to require insulin and had a higher proportion of perinatal deaths and neonatal hypoglycemia than those diagnosed late. More research is needed to evaluate screening for GDM prior to 24 weeks gestation.

Our systematic review also found new good-quality evidence for treatment improving outcomes in mild GDM in both the mother and baby in women diagnosed with GDM at 24 weeks gestation or later, compared to no treatment among a population similar to the US in ethnicity and obesity. Other randomized trials comparing different treatments of GDM suggest that improving glycemic control improves outcomes. We found limited evidence for a possible short-term worsened anxiety and psychological distress in the mother for the first several weeks after screening, and the same limited evidence suggested this does not persist throughout the pregnancy or post-partum. We found no evidence to suggest other serious harms to the mother or infant with treatment of GDM including to maternal quality-of-life. In contrast, findings from one randomized trial (in a subgroup analysis) that women treated for GDM may have less depression and improved general health perceptions up to three months post-partum compared to women not treated for GDM.