# Methods Summary

This section briefly details the methods used for conducting this review. These methods were based primarily on published USPSTF methods for systematic reviews.^29^ Appendix A includes a more detailed description of our methods.

We developed an analytic framework and five key questions (Figure 1) after consultation and final approval from the USPSTF liaisons. The scope of this report differs from the 2003 USPSTF evidence report in several important ways:

1) We evaluated screening for gestational diabetes at any time during pregnancy so that we could capture evidence of screening before 24 weeks gestation.
2) The Task Force separated final health outcomes from intermediate outcomes for GDM, such as macrosomia and delivery (induction or cesarean). Intermediate outcomes, though of interest, were not systematically reviewed. Although macrosomia is mediated by elevated maternal glucose, which stimulates the baby to produce excess insulin (increasing fetal growth), it is also an intermediate outcome. Therefore, we only reviewed studies addressing specified health outcomes such as perinatal mortality, brachial plexus injury, and clavicular fracture (see analytic framework, Figure 1). We present evidence about macrosomia and other intermediate outcomes for included studies, if reported.
3) We did not systematically review studies of GDM's natural history (only describing outcomes of untreated women).
4) We did not perform a systematic review of antenatal surveillance for women with GDM.
5) We only included studies that used current accepted diagnostic standards for GDM.^1,^,^2,19^

Figure 1. Analytic Framework

We conducted five database searches of MedLine, Cochrane Central Registry of Controlled Trials, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effectiveness, Health Technology Assessment, and National Institute for Health and Clinical Excellence from 2000 to September 2006, supplemented by a search for screening prior to 24 weeks gestation from 1966-99 (Appendix A Table 2). Articles were also obtained from outside experts and through reviewing bibliographies of other relevant articles and systematic reviews. We also considered all articles cited in the 2003 Evidence Synthesis^5^ for inclusion. Two investigators reviewed the 2003 USPSTF report's reference list, relevant abstracts, and full articles (168 total), to ensure we were reviewing all prior literature using the updated criteria. Two investigators reviewed 1403 abstracts and 277 articles against inclusion and exclusion criteria for each key question. Discrepancies were resolved by consensus.

Table 2 Summary characteristics of treatment trials (Key Question 3)

Author/Yr | N | Treatment | Setting | Population | BMI | Gestational age at screening, wks | Screening test used | Quality Rating
Treated vs. Untreated
Crowther 2005^39^ | 1000 | Treatment of mild GDM vs. No treatment | Australia, UK | White 75 % Asian 16 % Other 8 % | IG: 26.8 (23.3–31.2) † CG: 26.0 (22.9–30.9) † | IG: 29.1 (28.2–30.0) † CG: 29.2 (28.2–30.0) † | Step 1: RF or 50 g GCT (≥7.8 mmol/L) 1-hr cut-off (93% were positive with 50-g) Step 2: 75 g OGTT (1) Fasting <7.8 mmol/L and (2) 2-hour value 7.8 to 11.0 mmol/L | Good
O'Sullivan 1966^44^ | 943 | Positive screen treated vs. Positive screen control vs. Negative screen control | Boston, MA | NR | ≥ 20 % over ideal body weight IG: 27.7% CG: 30.5% | NR | Step 1: 50 g GCT whole blood > 130 mg/dL Step 2: 100 g OGTT with ≥ 2 abnormal glucose values | Fair
Treatment Comparisons
Langer 2000, 2005^42,47^ | 404 | Glyburide vs. Insulin treatment | San Antonio, TX | 83 % Hispanic 12 % White 5 % Black | BMI ≥ 27.3 prior to pregnancy N (%) IG_INS_: 141 (70) IG_GLY_: 132 (65) | Mean±SD IG_INS_: 24±7 CG_GLY_: 25±7 | Step 1: 50 g GCT > 130 mg/dL Step 2: 100 g OGTT with ≥ 2 abnormal glucose values by C&C criteria | Good
Bancroft 2000^38^ | 68 | Diet+Intensive glucose monitoring vs. Diet+Standard clinic glucose monitoring | UK | Asian: 31% Caucasian: 69% | Mean (SD) IG_DietgluM_: 32.2(6.7) IG_Diet_: 27.5(6.1) | Median (range) IG_DietgluM_: 31(24–38) IG_Diet_: 32(15–37) wks | Step 1: <7.0 mmol/L Step 2: 75 g OGTT 2-hour value 7.8 to 11.0 mmol/L GTT done at the discretion of individual clinicians. | Fair
Jovanovic 1999^41^ | 42 | NPH+Lispro insulin vs. NPH+Regular insulin treatment | California | Hispanic IG_ana_: 89% IG_reg_: 100% | Mean±SEM IG_ana_: 31.5±1.1 IG_reg_: 33.3±1.2 NS | At enrollment, Mean±SEM IG_ana_: 27.3±1.4 IG_reg_: 25.6±1.3 NS | NDDG Criteria (2-step 50 g GCT, then 100 g OGTT) | Fair
Nachum 1999^43^ | 274 | 4× daily insulin vs. 2× daily insulin treatment | Israel | Jewish IG_4X_: 57% CG_2X_: 55% | IG_4X_: 27.9±2.6 CG_2X_: 27.8±2.7 | At diagnosis IG_4X_: 25.9±2.6 CG_2X_: 26.3±7.2 Initiated treatment IG_4X_: 27.4±6.8 CG_2X_: 28.0±6.9 | 100 g OGTT with ≥2 serum glucose concentrations ≥5.9, 10.6, 9.2, 8.1 mmol/L at 0, 1, 2, and 3 hrs respectively. | Fair
De Veciana 1995^40^ | 66 | Pre-prandial vs. Post-prandial monitoring of glucose to inform treatment decisions | California | Hispanic: 85% White: 11% Black/Asian: 5% | IG_pre_: 29.0±3.2 IG_post_: 28.4±3.8 NS | At diagnosis IG_pre_: 22.9±7.5 IG_post_: 21.8±6.5 NS Initiated treatment IG_pre_: 24.3±5.2 IG_post_: 25.1±5.1 NS | Step 1: One-hour 50 g GCT > 140 mg/dL, but <190 mg/dL; those >190 mg/dL started insulin immediately. Step 2: 3-hour 100 g OGTT with ≥ 2 abnormal glucose values (fasting > 105 mg/dL, 1 hr > 190 mg/dL, 2 hrs > 165 mg/dL, 3 hrs > 145 mg/dL). | Fair

† Median (interquartile range)

IG-intervention group; CG-control group; NS-not significant; OGTT-oral glucose tolerance test; GCT-glucose challenge test.

We included only randomized trials that used the currently accepted one-step and two-step diagnostic criteria to evaluate GDM screening and treatment for assessing potential benefit of GDM screening and treatment. We considered prospective cohort studies if RCT evidence was not available. Any study design was considered for potential harms, and inclusion criteria were less stringent for study harms. For example, articles that used standard methods, but not standard cut-off criteria, were accepted. The actual glucose levels used to define GDM were considered less important in assessing the harms of screening than the process used for GDM screening and the receipt of a diagnosis. Details for inclusion and exclusion criteria are provided in Appendix A Table 3. Ninety of the potentially included articles were excluded for study design and 12 for poor quality.

We found no RCTs of screening for KQ1 or studies for KQ2 that reported sensitivity, specificity, and yield rates using one of the three acceptable screening methods (Table 1) for specified health outcomes (Figure 1). We included the following articles that met final inclusion and quality-rating criteria: seven RCTs reported in eight publications that test interventions that alter glycemic control and reported specified health outcomes in women diagnosed at 24 weeks gestation or later for KQ3a; one prospective study addressing treatment of women diagnosed with GDM prior to 24 weeks gestation for KQ3b; three studies reporting harms of screening for GDM were found for KQ4; one additional article, along with six of the eight articles included in KQ3, reported adverse effects of treatment for KQ5. Tables of excluded articles and reason for exclusion are provided in Appendix D. Using the USPSTF's study design-specific criteria (Appendix B), two investigators critically appraised and rated the quality of all included articles as well as those articles excluded for quality reasons only.

## USPSTF Involvement

The authors worked with four USPSTF members at key points throughout the review process to develop and refine the analytic framework and key questions and resolve issues involving the scope, treatment modalities, and health outcomes. This research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project and reviewed and assisted with the external review of the draft evidence synthesis.

## Table 1. Screening strategies

Three screening tests with generally accepted criteria are frequently used for the diagnosis of GDM with a one- or two-step method. These are typically performed between 24 and 28 weeks' gestation and are defined as follows:

1 [underlined: 50 g Initial Screening Test:] A two-step method using an initial 1-hr 50 g oral glucose challenge test (GCT) and followed by a diagnostic 75 or 100 g oral glucose tolerance test (OGTT) if the GCT is positive. The GCT has two criteria accepted as a positive result, depending on the level of sensitivity desired: ^1,2^
  - ≥130 mg/dL (identifies 90 percent of women with GDM)^1^
  - ≥140 mg/dL (identifies 80 percent of women with GDM)^1^
2 [underlined: 100 g Diagnostic Test:] A one-step or a two-step method using a 3-hour 100 g diagnostic OGTT. This test is defined as positive if two or more of the hourly plasma glucose levels meet or exceed the following values:

Criteria for Abnormal Result on 100 g, Three-Hour Oral Glucose Tolerance Tests in Pregnant Women^1,30^

[underlined: Blood sample] | [underlined: National Diabetes Data Group Criteria] | [underlined: Carpenter and Coustan Criteria]
Fasting | 105 mg/dL (5.8 mmol/L) | 95 mg/dL (5.3 mmol/L)
1-hour | 190 mg/dL (10.5 mmol/L) | 180 mg/dL (10.0 mmol/L)
2-hour | 165 mg/dL (9.2 mmol/L) | 155 mg/dL (8.6 mmol/L)
3-hour | 145 mg/dL (8.0 mmol/L) | 140 mg/dL (7.8 mmol/L)

3 [underlined: 75 g Diagnostic Test:] A one-step or two-step method using a 75 g diagnostic oral glucose tolerance test (OGTT). This test is defined as positive if two or more of the hourly plasma glucose levels meet or exceed the following values (different criteria apply based upon WHO or ADA recommendations):

Criteria for Abnormal Result on 75-g Oral Glucose Tolerance Test in Pregnant Women^1,2^

Blood Sample | ADA mg/dL | ADA mmol/l | WHO* mmol/l
Fasting | 95 | 5.3 | 7.0
1-hour | 180 | 10.0
2-hour | 155 | 8.6 | 7.8

* Note 7.0 mmol/l=126 mg/dl and 7.8 mmol/L=140 mg/dl)