# Appendix D: Excluded Studies

## References

Aberg A, Rydhstroem H, Frid A. Impaired glucose tolerance associated with adverse pregnancy outcome: a population-based study in southern Sweden. American Journal of Obstetrics & Gynecology. 2001;184(2):77-83. Excluded for Study Design. [pmid: 11174484].
Aberg A, Westbom L. Association between maternal pre-existing or gestational diabetes and health problems in children. Acta Paediatrica. 2001;90(7):746-50. Does not address one of the key questions. [pmid: 11519976].
Adams KM, Li H, Nelson RL, Ogburn PL Jr, Danilenko-Dixon DR. Sequelae of unrecognized gestational diabetes. Am J Obstet Gynecol. 1998;178(6):1321-1332. Excluded for Study Design. [pmid: 9662318].
Agardh CD, Aberg A, Norden NE. Glucose levels and insulin secretion during a 75 g glucose challenge test in normal pregnancy. Journal of Internal Medicine. 1996;240(5):303-9. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 8946813].
Agarwal MM, Dhatt GS, Punnose J, Koster G. Gestational diabetes in a high-risk population: using the fasting plasma glucose to simplify the diagnostic algorithm. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2005;75(1):37-41. Does not address morbidity and/or mortality.
Agarwal MM, Dhatt GS, Punnose J, Koster G. Gestational diabetes: a reappraisal of HBA1c as a screening test. Acta Obstet Gynecol Scand. 2005;84(12):1159-1163. Did not use designated diagnostic test or diagnostic criteria. [pmid: 16305701].
Agarwal MM, Dhatt GS, Punnose J, Koster G. Gestational diabetes: dilemma caused by multiple international diagnostic criteria. Diabet Med. 2005;22(12):1731-1736. Prevalence outside U.S. [pmid: 16401320].
Agarwal MM, Hughes PF, Ezimokhai M. Screening for gestational diabetes in a high-risk population using fasting plasma glucose. International Journal of Gynaecology & Obstetrics. 2000;68(2):147-8. Excluded for Study Design. [pmid: 10717820].
Agarwal MM, Hughes PF, Punnose J, Ezimokhai M. Fasting plasma glucose as a screening test for gestational diabetes in a multi-ethnic, high-risk population. Diabetic Medicine. 2000;17(10):720-6. Does not address morbidity and/or mortality. [pmid: 11110505].
Agarwal MM, Punnose J, Dhatt GS. Gestational diabetes: implications of variation in post-partum follow-up criteria. Eur J Obstet Gynecol Reprod Biol. 2004;113(2):149-153. Does not address one of the key questions. [pmid: 15063951].
Agrawal RK, Lui K, Gupta JM. Neonatal hypoglycaemia in infants of diabetic mothers. Journal of Paediatrics & Child Health. 2000;36(4):354-6. Excluded for Study Design. [pmid: 10940170].
Al Mahroos S, Nagalla DS, Yousif W, Sanad H. A population-based screening for gestational diabetes mellitus in non-diabetic women in Bahrain. Annals of Saudi Medicine. 2005;25(2):129-33. Apr. Did not use designated diagnostic test or diagnostic criteria. [pmid: 15977691].
Alberico S, Strazzanti C, De Santo D, De Seta F, Lenardon P, Bernardon M, et al. Gestational diabetes: universal or selective screening?. Journal of Maternal-Fetal & Neonatal Medicine. 2004;16(6):331-7. Natural history only. [pmid: 15621551].
Baliutaviciene D, Petrenko V, Zalinkevicius R. Selective or universal diagnostic testing for gestational diabetes mellitus. International Journal of Gynaecology & Obstetrics. 2002;78(3):207-11. Excluded for Study Design. [pmid: 12384265].
Barahona MJ, Sucunza N, Garcia-Patterson A, Hernandez M, Adelantado JM, Ginovart G, et al. Period of gestational diabetes mellitus diagnosis and maternal and fetal morbidity. Acta Obstetricia et Gynecologica Scandinavica. 2005;84(7):622-7. Excluded for Study Design. [pmid: 15954869].
Barden A, Singh R, Walters BN, Ritchie J, Roberman B, Beilin LJ. Factors predisposing to pre-eclampsia in women with gestational diabetes. Journal of Hypertension. 2004;22(12):2371-8. Excluded for Study Design. [pmid: 15614032].
Bartha JL, Martinez-Del-Fresno P, Comino-Delgado R. Early diagnosis of gestational diabetes mellitus and prevention of diabetes-related complications. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2003;75(1):37-41. Excluded for Study Design.
Beischer NA, Wein P, Sheedy MT, Steffen B. Identification and treatment of women with hyperglycaemia diagnosed during pregnancy can significantly reduce perinatal mortality rates. Australian & New Zealand Journal of Obstetrics & Gynaecology. 1996;36(3):239-47. Did not use designated diagnostic test or diagnostic criteria. [pmid: 8883743].
Benjamin F, Wilson SJ, Deutsch S, Seltzer VL, Droesch K, Droesch J. Effect of advancing pregnancy on the glucose tolerance test and on the 50-g oral glucose load screening test for gestational diabetes. Obstetrics & Gynecology. 1986;68(3):362-5. Prevelence only data. [pmid: 3737059].
Berger H, Crane J, Farine D, Armson A, De La RS, Keenan-Lindsay L, et al. Screening for gestational diabetes mellitus. J Obstet Gynaecol Can. 2002;24(11):894-912. Non-systematic review. [pmid: 12417905].
Berkowitz GS, Roman SH, Lapinski RH, Alvarez M. Maternal characteristics, neonatal outcome, and the time of diagnosis of gestational diabetes. American Journal of Obstetrics & Gynecology. 1992;167(4 Pt 1):976-82. Excluded for Study Design. [pmid: 1415436].
Berkus MD, Langer O, Piper JM, Luther MF. Efficiency of lower threshold criteria for the diagnosis of gestational diabetes. Obstet Gynecol. 1995;86(6):892-896. Does not address one of the key questions. [pmid: 7501334].
Berkus MD, Langer O. Glucose tolerance test: degree of glucose abnormality correlates with neonatal outcome. Obstet Gynecol. 1993;81(3):344-348. Does not address one of the key questions. [pmid: 8437783].
Bertini AM, Silva JC, Taborda W, Becker F, Lemos Bebber FR, Zucco Viesi JM, et al. Perinatal outcomes and the use of oral hypoglycemic agents. Journal of Perinatal Medicine. 2005;33(6):519-23. Poor Quality. [pmid: 16318615].
Bhattacharya SM. Fasting or two-hour postprandial plasma glucose levels in early months of pregnancy as screening tools for gestational diabetes mellitus developing in later months of pregnancy. Journal of Obstetrics & Gynaecology Research. 2004;30(4):333-6. Excluded for Study Design. [pmid: 15238113].
Bhattacharya SM. Glucose screening test results in first and early third trimester of pregnancy: is there any correlation?. Journal of Obstetrics & Gynaecology Research. 2002;28(6):304-7. Excluded for Study Design, Does not address morbidity and/or mortality. [pmid: 12512927].
Bito T, Nyari T, Kovacs L, Pal A. Oral glucose tolerance testing at gestational weeks < or =16 could predict or exclude subsequent gestational diabetes mellitus during the current pregnancy in high risk group. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):51-55. Not generalizable to US population. [pmid: 15989984].
Bo S, Menato G, Signorile A, Bardelli C, Lezo A, Gallo ML, et al. Obesity or diabetes: what is worse for the mother and for the baby?. Diabetes & Metabolism. 2003;29(2 Pt 1):175-8. Excluded for Study Design. [pmid: 12746640].
Boriboonhirunsarn D, Sunsaneevithayakul P, Nuchangrid M. Incidence of gestational diabetes mellitus diagnosed before 20 weeks of gestation. Journal of the Medical Association of Thailand. 2004;87(9):1017-21. Does not address morbidity and/or mortality. [pmid: 15516000].
Buchanan TA, Xiang AH, Kjos SL, Trigo E, Lee WP, Peters RK. Antepartum predictors of the development of type 2 diabetes in Latino women 11–26 months after pregnancies complicated by gestational diabetes. Diabetes. 1999;48(12):2430-2436. Does not address one of the key questions. [pmid: 10580433].
Buchbinder A, Miodovnik M, Khoury J, Sibai BM. Is the use of insulin lispro safe in pregnancy?. Journal of Maternal-Fetal & Neonatal Medicine. 2002;11(4):232-7. Non-systematic review. [pmid: 12375676].
Calle-Pascual AL, Bagazgoitia J, Calle JR, Charro A, Maranes JP. Use of insulin lispro in pregnancy. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2000;13(3):173-7. Non-systematic review.
Carpenter MW, Coustan DR. Criteria for screening tests for gestational diabetes. Am J Obstet Gynecol. 1982;144(7):768-773. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 7148898].
Carr CA. Evidence-based diabetes screening during pregnancy. J Midwifery Womens Health. 2001;46(3):152-158. Non-systematic review. [pmid: 11480747].
Catalano PM, Thomas A, Huston-Presley L, Amini SB. Increased fetal adiposity: a very sensitive marker of abnormal in utero development. American Journal of Obstetrics & Gynecology. 2003;189(6):1698-704. Does not address one of the key questions. [pmid: 14710101].
Chan BC, Lao TT. Gestational diabetes mellitus in women in the fourth decade—is treatment worthwhile?. Gynecologic & Obstetric Investigation. 2005;60(2):112-6. Excluded for Study Design. [pmid: 15886486].
Chen X, Scholl TO, Stein TP. Association of elevated serum ferritin levels and the risk of gestational diabetes mellitus in pregnant women: the camden study. Diabetes Care. 2006;29(5):1077-1082. Does not address one of the key questions. [pmid: 16644640].
Cheung NW, Byth K. Population health significance of gestational diabetes. Diabetes Care. 2003;26(7):2005-2009. Does not address one of the key questions. [pmid: 12832303].
Contreras-Soto J, Forsbach G, Vazquez-Rosales J, Alvarez-Garcia C, Garcia G. Noninsulin dependent diabetes mellitus and pregnancy in Mexico. International Journal of Gynaecology & Obstetrics. 1991;34(3):205-10. Did not use established screening criteria, Prevalence outside U.S. [pmid: 1673935].
Conway DL, Gonzales O, Skiver D. Use of glyburide for the treatment of gestational diabetes: the San Antonio experience. Journal of Maternal-Fetal & Neonatal Medicine. 2004;15(1):51-5. Excluded for Study Design. [pmid: 15101612].
Coomarasamy A, Connock M, Thornton J, Khan KS. Accuracy of ultrasound biometry in the prediction of macrosomia: a systematic quantitative review. BJOG. 2005;112(11):1461-1466. Does not address one of the key questions. [pmid: 16225563].
Coustan DR, Imarah J. Prophylactic insulin treatment of gestational diabetes reduces the incidence of macrosomia, operative delivery, and birth trauma. American Journal of Obstetrics & Gynecology. 1984;150(7):836-42. Excluded for Study Design. [pmid: 6391174].
Coustan DR. Management of gestational diabetes mellitus: a self-fulfilling prophecy?. JAMA. 1996;275(15):1199-1200. Editorials, comments and letters. [pmid: 8609690].
Culligan PJ, Myers JA, Goldberg RP, Blackwell L, Gohmann SF, Abell TD. Elective cesarean section to prevent anal incontinence and brachial plexus injuries associated with macrosomia—a decision analysis. Int Urogynecol J Pelvic Floor Dysfunct. 2005;16(1):19-28. Does not address one of the key questions. [pmid: 15647962].
Cundy T, Gamble G, Townend K, Henley PG, MacPherson P, Roberts AB. Perinatal mortality in Type 2 diabetes mellitus. Diabetic Medicine. 2000;17(1):33-39. Excluded for Study Design. [pmid: 10691157].
Dabelea D, Snell-Bergeon JK, Hartsfield CL, Bischoff KJ, Hamman RF, McDuffie RS. Increasing prevalence of gestational diabetes mellitus (GDM) over time and by birth cohort: Kaiser Permanente of Colorado GDM Screening Program. Diabetes Care. 2005;28(3):579-584. Prevalence only data. [pmid: 15735191].
Dang K, Homko C, Reece EA. Factors associated with fetal macrosomia in offspring of gestational diabetic women. J Matern Fetal Med. 2000;9(2):114-117. Does not address one of the key questions. [pmid: 10902825].
Davey RX, Hamblin PS. Selective versus universal screening for gestational diabetes mellitus: an evaluation of predictive risk factors. Medical Journal of Australia. 2001;174(3):118-21. Excluded for Study Design. [pmid: 11247613].
De M X. Perinatal complications of gestational diabetes: the influence of the timing of the diagnosis. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1984;75(1):37-41. Excluded for Study Design.
de Sereday MS, Damiano MM, Gonzalez CD, Bennett PH. Diagnostic criteria for gestational diabetes in relation to pregnancy outcome. J Diabetes Complications. 2003;17(3):115-119. Does not report sensitivity and specificity criterion to assess specified health outcomes. [pmid: 12738394].
Deerochanawong C, Putiyanun C, Wongsuryrat M, Serirat S, Jinayon P. Comparison of National Diabetes Data Group and World Health Organization criteria for detecting gestational diabetes mellitus. Diabetologia. 1996;39(9):1070-1073. Does not report sensitivity and specificity criterion to assess specified health outcomes. [pmid: 8877291].
Di Cianni G, Benzi L, Bottone P, Volpe L, Orsini P, Murru S et al. Neonatal outcome and obstetric complications in women with gestational diabetes: effects of maternal body mass index. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity 1996;(5):445–449. Excluded for Study Design
Di Cianni G, Miccoli R, Volpe L, Lencioni C, Ghio A, Giovannitti MG, et al. Maternal triglyceride levels and newborn weight in pregnant women with normal glucose tolerance. Diabetic Medicine. 2005;22(1):21-5. Does not address one of the key questions. [pmid: 15606686].
Di Cianni G, Volpe L, Lencioni C, Miccoli R, Cuccuru I, Ghio A, et al. Prevalence and risk factors for gestational diabetes assessed by universal screening. Diabetes Research & Clinical Practice. 2003;62(2):131-7. Excluded for Study Design, Prevalence outside U.S. [pmid: 14581150].
Dong ZG, Beischer NA, Wein P, Sheedy MT. Value of early glucose tolerance testing in women who had gestational diabetes in their previous pregnancy. Australian & New Zealand Journal of Obstetrics & Gynaecology. 1993;33(4):350-7. Excluded for Study Design. [pmid: 8179539].
Dornan T, Hollis S. Critical appraisal of published research evidence: treatment of gestational diabetes. Diabet Med 2001; Suppl 3:1–5. Editorials, comments and letters
Dornhorst A, Frost G. The principles of dietary management of gestational diabetes: reflection on current evidence. J Hum Nutr Diet. 2002;15(2):145-156. Non-systematic review. [pmid: 11972744].
Dornhorst A. A comparison of glyburide and insulin in women with gestational diabetes mellitus. Diabetic Medicine Suppl 3:12–4, 2001. Editorials, comments and letters
Drexel H, Bichler A, Sailer S, Breier C, Lisch HJ, Braunsteiner H, et al. Prevention of perinatal morbidity by tight metabolic control in gestational diabetes mellitus. Diabetes Care. 1988;11(10):761-768. Excluded for Study Design. [pmid: 3073066].
El Sayed YY, Lyell DJ. New therapies for the pregnant patient with diabetes. Diabetes Technology & Therapeutics. 2001;3(4):635-40. Non-systematic review. [pmid: 11911177].
Erem C, Cihanyurdu N, Deger O, Karahan C, Can G, Telatar M. Screening for gestational diabetes mellitus in northeastern Turkey (Trabzon City). European Journal of Epidemiology. 2003;18(1):39-43. Excluded for Study Design. [pmid: 12705622].
Ertunc D, Tok E, Dilek U, Pata O, Dilek S. The effect of carbohydrate intolerance on neonatal birth weight in pregnant women without gestational diabetes mellitus. Annals of Saudi Medicine. 2004;24(4):280-3. Aug. Does not address one of the key questions. [pmid: 15387495].
Esakoff TF, Cheng YW, Caughey AB. Screening for gestational diabetes: different cut-offs for different ethnicities?. Am J Obstet Gynecol. 2005;193(3 Pt 2):1040-1044. Does not report sensitivity and specificity criterion to assess specified health outcomes. [pmid: 16157108].
Fedele D, Lapolla A. A protocol of screening of gestational diabetes mellitus. Annali Dell'Istituto Superiore di Sanita. 1997;33(3):383-7. Prevelence only data.
Feig DS, Chen E, Naylor CD. Self-perceived health status of women three to five years after the diagnosis of gestational diabetes: a survey of cases and matched controls. Am J Obstet Gynecol. 1998;178(2):386-393. Poor Quality. [pmid: 9500504].
Feig DS, Razzaq A, Sykora K, Hux JE, Anderson GM. Trends in deliveries, prenatal care, and obstetrical complications in women with pregestational diabetes: a population-based study in Ontario, Canada, 1996-2001. Diabetes Care. 2006;29(2):232-235. Does not address one of the key questions. [pmid: 16443865].
Ferrara A, Hedderson MM, Quesenberry CP, Selby JV. Prevalence of gestational diabetes mellitus detected by the national diabetes data group or the carpenter and coustan plasma glucose thresholds. Diabetes Care. 2002;25(9):1625-30. Prevelence only data. [pmid: 12196438].
Ferrara A, Kahn HS, Quesenberry CP, Riley C, Hedderson MM. An increase in the incidence of gestational diabetes mellitus: Northern California, 1991-2000. Obstetrics & Gynecology. 2004;103(3):526-33. Prevelence only data. [pmid: 14990417].
Fink K, Clark B. Screening for gestational diabetes mellitus. American Family Physician. 2004;69(5):1187-8. Does not address one of the key questions. [pmid: 15023021].
Fotinos C, Dodson S, French L. Clinical inquiries. Does tight control of blood glucose in pregnant women with diabetes improve neonatal outcomes?. Journal of Family Practice. 2004;53(10):838-41. Non-systematic review. [pmid: 15469784].
Gabbe SG, Mestman JG, Freeman RK, Anderson GV, Lowensohn RI. Management and outcome of class A diabetes mellitus. Am J Obstet Gynecol. 1977;127(5):465-469. Excluded for Study Design. [pmid: 836643].
Garcia-Patterson A, Erdozain L, Ginovart G, Adelantado JM, Cubero JM, Gallo G, et al. In human gestational diabetes mellitus congenital malformations are related to pre-pregnancy body mass index and to severity of diabetes. Diabetologia. 2004;47(3):509-514. Excluded for Study Design. [pmid: 14770278].
Garcia-Patterson A, Martin E, Ubeda J, Maria MA, de Leiva A, Corcoy R. Evaluation of light exercise in the treatment of gestational diabetes. Diabetes Care. 2001;24(11):2006-7. Excluded for Study Design. [pmid: 11679479].
Garner P, Okun N, Keely E, Wells G, Perkins S, Sylvain J, Belcher J. A randomized controlled trial of strict glycemic control and tertiary level obstetric care versus routine obstetric care in the management of gestational diabetes: a pilot study. Am J Obstet Gynecol. 1997;177(1):190-195. Did not use established screening criteria. [pmid: 9240606].
Gezer A, Esen F, Mutlu H, Ozturk E, Ocak V. Prognosis of patients with positive screening but negative diagnostic test for gestational diabetes. Archives of Gynecology & Obstetrics. 2002;266(4):201-4. Excluded for Study Design. [pmid: 12192479].
Gillman MW, Rifas-Shiman S, Berkey CS, Field AE, Colditz GA. Maternal gestational diabetes, birth weight, and adolescent obesity. Pediatrics. 2003;111(3):e221-6. Excluded for Study Design. [pmid: 12509584].
Giuffrida FM, Castro AA, Atallah AN, Dib SA. Diet plus insulin compared to diet alone in the treatment of gestational diabetes mellitus: a systematic review. Braz J Med Biol Res. 2003;36(10):1297-1300. Poor Quality. [pmid: 14502360].
Glueck CJ, Bornovali S, Pranikoff J, Goldenberg N, Dharashivkar S, Wang P. Metformin, pre-eclampsia, and pregnancy outcomes in women with polycystic ovary syndrome. Diabetic Medicine. 2004;21(8):829-36. Does not address one of the key questions. [pmid: 15270785].
Glueck CJ, Goldenberg N, Pranikoff J, Loftspring M, Sieve L, Wang P. Height, weight, and motor-social development during the first 18 months of life in 126 infants born to 109 mothers with polycystic ovary syndrome who conceived on and continued metformin through pregnancy. Human Reproduction. 2004;19(6):1323-1330. Does not address one of the key questions. [pmid: 15117896].
Glueck CJ, Wang P, Goldenberg N, Sieve-Smith L. Pregnancy outcomes among women with polycystic ovary syndrome treated with metformin. Human Reproduction. 2002;17(11):2858-64. Does not address one of the key questions. [pmid: 12407039].
Gokcel A, Bagis T, Killicadag EB, Tarim E, Guvener N. Comparison of the criteria forgestational diabetes mellitus by NDDG and Carpenter and Coustan, and the outcomes of pregnancy. Journal of Endocrinological Investigation. 2002;25(4):357-61. Excluded for Study Design. [pmid: 12030608].
Gonzalez C, Santoro S, Salzberg S, Di Girolamo G, Alvarinas J. Insulin analogue therapy in pregnancies complicated by diabetes mellitus. Expert Opinion on Pharmacotherapy. 2005;6(5):735-42. Non-systematic review. [pmid: 15934900].
Gray-Donald K, Robinson E, Collier A, David K, Renaud L, Rodrigues S. Intervening to reduce weight gain in pregnancy and gestational diabetes mellitus in Cree communities: an evaluation. CMAJ Canadian Medical Association Journal. 2000;163(10):1247-51. Excluded for Study Design.
Greene MF. Oral hypoglycemic drugs for gestational diabetes. New England Journal of Medicine. 2000;343(16):1178-9. Editorials, comments and letters. [pmid: 11036125].
Griffin ME, Coffey M, Johnson H, Scanlon P, Foley M, Stronge J, et al. Universal vs. risk factor-based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabetic Medicine. 2000;17(1):26-32. Poor Quality. [pmid: 10691156].
Gruendhammer M, Brezinka C, Lechleitner M. The number of abnormal plasma glucose values in the oral glucose tolerance test and the feto-maternal outcome of pregnancy. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2003;75(1):37-41. Excluded for Study Design.
Hadden D. Evidence-based screening for gestational diabetes?. Diabetic Medicine. 2000;17(5):402-4. Editorials, comments and letters. [pmid: 10872544].
Hague WM, Davoren PM, Oliver J, Rowan J. Contraindications to use of metformin. Metformin may be useful in gestational diabetes. BMJ 326(7392 ):762; author reply 762, 2003. Editorials, comments and letters
HAPO Study Cooperative Research Group. The Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. International Journal of Gynaecology & Obstetrics. 2002;78(1):69-77. Excluded for Study Design. [pmid: 12113977].
Harlass FE, Brady K, Read JA. Reproducibility of the oral glucose tolerance test in pregnancy. American Journal of Obstetrics & Gynecology. 1991;164(2):564-8. Poor Quality. [pmid: 1992702].
Hassan A. Screening of pregnant women for gestational diabetes mellitus. Journal of Ayub Medical College, Abbottabad: JAMC. 2005 Jun;17(2):54-8. Does not address morbidity and/or mortality.
Hedderson MM, Ferrara A, Sacks DA. Gestational diabetes mellitus and lesser degrees of pregnancy hyperglycemia: association with increased risk of spontaneous preterm birth. Obstetrics & Gynecology. 2003;102(4):850-6. Excluded for Study Design. [pmid: 14551018].
Hellmuth E, Damm P, Molsted-Pedersen L. Oral hypoglycaemic agents in 118 diabetic pregnancies. Diabetic Medicine. 2000;17(7):507-11. Does not address morbidity and/or mortality. [pmid: 10972579].
Hill JC, Krishnaveni GV, Annamma I, Leary SD, Fall CH. Glucose tolerance in pregnancy in South India: relationships to neonatal anthropometry. Acta Obstetricia et Gynecologica Scandinavica. 2005;84(2):159-65. Does not address morbidity and/or mortality. [pmid: 15683377].
Hiramatsu Y, Masuyama H, Mizutani Y, Kudo T, Oguni N, Oguni Y. Heavy-for-date infants: their backgrounds and relationship with gestational diabetes. Journal of Obstetrics & Gynaecology Research. 2000;26(3):193-8. Excluded for Study Design. [pmid: 10932981].
Homko CJ, Reece EA. To screen or not to screen for gestational diabetes mellitus. The clinical quagmire. Clinics in Perinatology. 2001;28(2):407-17. Non-systematic review. [pmid: 11499061].
Homko CJ, Sivan E, Reece AE. Is there a role for oral antihyperglycemics in gestational diabetes and type 2 diabetes during pregnancy?. Treat Endocrinol. 2004;3(3):133-139. Non-systematic review. [pmid: 16026109].
Homko CJ, Sivan E, Reece EA. The impact of self-monitoring of blood glucose on self-efficacy and pregnancy outcomes in women with diet-controlled gestational diabetes. Diabetes Educator. 2002;28(3):435-43. Jun. Not one of the included treatments. [pmid: 12073958].
Hong PL, Benjamin F, Deutsch S. First prenatal visit glucose screening. American Journal of Perinatology. 1989;6(4):433-6. Did not use designated diagnostic test or diagnostic criteria. [pmid: 2789541].
Hughes PF, Agarwal M, Newman P, Morrison J. Screening for gestational diabetes in a multi-ethnic population. Diabetes Research & Clinical Practice. 1995;28(1):73-8. Natural history only. [pmid: 7587916].
Hughes PF, Agarwal M, Newman P, Morrison J. Screening for gestational diabetes in a multi-ethnic population. Diabetes Research & Clinical Practice. 1995;28(1):73-8. Natural history only. [pmid: 7587916].
Hunger-Dathe W, Volk K, Braun A, Samann A, Muller UA, Peiker G, et al. Perinatal morbidity in women with undiagnosed gestational diabetes in northern thuringia in Germany. Experimental & Clinical Endocrinology & Diabetes. 2005;113(3):160-6. Excluded for Study Design. [pmid: 15789275].
Jacobson GF, Ramos GA, Ching JY, Kirby RS, Ferrara A, Field DR. Comparison of glyburide and insulin for the management of gestational diabetes in a large managed care organization. Am J Obstet Gynecol. 2005;193(1):118-124. Excluded for Study Design. [pmid: 16021069].
Jensen DM, Damm P, Sorensen B, Molsted-Pedersen L, Westergaard JG, Klebe J, et al. Clinical impact of mild carbohydrate intolerance in pregnancy: a study of 2904 nondiabetic Danish women with risk factors for gestational diabetes mellitus. American Journal of Obstetrics & Gynecology. 2001;185(2):413-9. Excluded for Study Design. [pmid: 11518901].
Jensen DM, Damm P, Sorensen B, Molsted-Pedersen L, Westergaard JG, Korsholm L, et al. Proposed diagnostic thresholds for gestational diabetes mellitus according to a 75-g oral glucose tolerance test. Maternal and perinatal outcomes in 3260 Danish women. Diabetic Medicine. 2003;1920(1):51-7. Excluded for Study Design.
Jensen DM, Damm P, Sorensen B, Molsted-Pedersen L, Westergaard JG, Ovesen P, et al. Pregnancy outcome and prepregnancy body mass index in 2459 glucose-tolerant Danish women. American Journal of Obstetrics & Gynecology. 2003;189(1):239-44. Excluded for Study Design. [pmid: 12861169].
Jensen DM, Molsted-Pedersen L, Beck-Nielsen H, Westergaard JG, Ovesen P, Damm P. Screening for gestational diabetes mellitus by a model based on risk indicators: a prospective study. Am J Obstet Gynecol. 2003;189(5):1383-1388. Does not address one of the key questions. [pmid: 14634573].
Jensen DM, Sorensen B, Feilberg-Jorgensen N, Westergaard JG, Beck-Nielsen H. Maternal and perinatal outcomes in 143 Danish women with gestational diabetes mellitus and 143 controls with a similar risk profile. Diabetic Medicine. 2000;17(4):281-6. Excluded for Study Design. [pmid: 10821294].
Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-Del-Castillo JD, Lardelli-Claret P, Garcia-Martin M, Galvez-Vargas R. Predictive value of a screen for gestational diabetes mellitus: influence of associated risk factors. Acta Obstetricia et Gynecologica Scandinavica. 2000;79(11):991-8. Does not address one of the key questions. [pmid: 11081686].
Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-del-Castillo JD, Garcia-Martin M, Lardelli-Claret P, Galvez-Vargas R. Impact of different levels of carbohydrate intolerance on neonatal outcomes classically associated with gestational diabetes mellitus. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2002;75(1):37-41. Excluded for Study Design.
Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-Del-Castillo JD, Garcia-Martin M, Lardelli-Claret P, Galvez-Vargas R. Prevalence of gestational diabetes mellitus: variations related to screening strategy used. European Journal of Endocrinology. 2002;146(6):831-7. Prevalence outside U.S. [pmid: 12039704].
Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-Del-Castillo JD, Lardelli-Claret P, Garcia-Martin M, Galvez-Vargas R. Predictive value of a screen for gestational diabetes mellitus: influence of associated risk factors. Acta Obstetricia et Gynecologica Scandinavica. 2000;79(11):991-8. Excluded for Study Design. [pmid: 11081686].
Joffe GM, Esterlitz JR, Levine RJ, Clemens JD, Ewell MG, Sibai BM, et al. The relationship between abnormal glucose tolerance and hypertensive disorders of pregnancy in healthy nulliparous women. Calcium for Preeclampsia Prevention (CPEP) Study Group. Am J Obstet Gynecol. 1998;179(4):1032-1037. Does not address one of the key questions. [pmid: 9790393].
Jorgensen LG, Schytte T, Brandslund I, Stahl M, Petersen PH, Andersen B. Fasting and post-glucose load—reference limits for peripheral venous plasma glucose concentration in pregnant women. Clinical Chemistry & Laboratory Medicine. 2003;41(2):187-99. Did not use designated diagnostic test or diagnostic criteria. [pmid: 12667006].
Jovanovic L, Knopp RH, Brown Z, Conley MR, Park E, Mills JL, et al. Declining insulin requirement in the late first trimester of diabetic pregnancy. Diabetes Care. 2001;24(7):1130-1136. Does not address one of the key questions. [pmid: 11423491].
Jovanovic L, Knopp RH, Kim H, Cefalu WT, Zhu XD, Lee YJ, et al. Elevated pregnancy losses at high and low extremes of maternal glucose in early normal and diabetic pregnancy: evidence for a protective adaptation in diabetes. Diabetes Care. 2005;28(5):1113-7. Does not address one of the key questions. [pmid: 15855575].
Kalter H. The non-teratogenicity of gestational diabetes. Paediatr Perinat Epidemiol. 1998;12(4):456-458. Excluded for Study Design. [pmid: 9805717].
Kerbel D, Glazier R, Holzapfel S, Yeung M, Lofsky S. Adverse effects of screening for gestational diabetes: a prospective cohort study in Toronto, Canada. J Med Screen. 1997;4(3):128-132. Poor Quality. [pmid: 9368868].
Keshavarz M, Cheung NW, Babaee GR, Moghadam HK, Ajami ME, Shariati M. Gestational diabetes in Iran: incidence, risk factors and pregnancy outcomes. Diabetes Research & Clinical Practice. 2005;69(3):279-86. Natural history only. [pmid: 16098925].
Kitzmiller JL, Elixhauser A, Carr S, Major CA, de Veciana M, Dang-Kilduff L, et al. Assessment of costs and benefits of management of gestational diabetes mellitus. Diabetes Care. 1998;21(Suppl 2):B123-B130. Does not address one of the key questions. [pmid: 9704239].
Kjos SL, Buchanan TA. Gestational diabetes mellitus. N Engl J Med. 1999;341(23):1749-1756. Non-systematic review. [pmid: 10580075].
Kjos SL, Schaefer-Graf U, Sardesi S, Peters RK, Buley A, Xiang AH, et al. A randomized controlled trial using glycemic plus fetal ultrasound parameters versus glycemic parameters to determine insulin therapy in gestational diabetes with fasting hyperglycemia. Diabetes Care. 2001;24(11):1904-10. Does not address one of the key questions. [pmid: 11679455].
Knopp RH, Magee MS, Raisys V, Benedetti T, Bonet B. Hypocaloric diets and ketogenesis in the management of obese gestational diabetic women. J Am Coll Nutr. 1991;10(6):649-667. Excluded for Study Design. [pmid: 1770194].
Ko GT, Chan JC, Tsang LW, Yeung VT, Chow CC, Cockram CS. Outcomes of screening for diabetes in high-risk Hong Kong Chinese subjects. Diabetes Care. 2000;23(9):1290-4. Does not address one of the key questions. [pmid: 10977020].
Kremer CJ, Duff P. Glyburide for the treatment of gestational diabetes . American Journal of Obstetrics & Gynecology 190;(5):1438–1439. Excluded for Study Design
Kumar KM. Current diagnostic criteria and their impact on outcome and management. Journal of the Indian Medical Association. 2002;100(3):149-52. Editorials, comments and letters. [pmid: 12408272].
Kvetny J, Poulsen HF. Incidence of gestational hypertension in gestational diabetes mellitus. Archives of Gynecology & Obstetrics. 2003;267(3):153-7. Natural history only. [pmid: 12552326].
Kyle CV, Cundy TF. Screening for gestational diabetes mellitus: can we be more efficient?. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2001;41(3):285-90. Excluded for Study Design, No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 11592542].
Landon MB, Thom E, Spong CY, Gabbe SG, Leindecker S, Johnson F, et al. A planned randomized clinical trial of treatment for mild gestational diabetes mellitus. Journal of Maternal-Fetal & Neonatal Medicine. 2002;11(4):226-31. Does not address one of the key questions. [pmid: 12375675].
Langer O, Anyaegbunam A, Brustman L, Divon M. Management of women with one abnormal oral glucose tolerance test value reduces adverse outcome in pregnancy. American Journal of Obstetrics & Gynecology. 1989;161(3):593-9. Does not address one of the key questions.
Langer O, Brustman L, Anyaegbunam A, Mazze R. The significance of one abnormal glucose tolerance test value on adverse outcome in pregnancy. Am J Obstet Gynecol. 1987;157(3):758-763. Does not address one of the key questions. [pmid: 3631178].
Langer O, Rodriguez DA, Xenakis EM, McFarland MB, Berkus MD, Arrendondo F. Intensified versus conventional management of gestational diabetes. Am J Obstet Gynecol. 1994;170(4):1036-1046. Excluded for Study Design. [pmid: 8166187].
Langer O, Yogev Y, Most O, Xenakis EM. Gestational diabetes: the consequences of not treating. American Journal of Obstetrics & Gynecology 192;(4):989–997. Excluded for Study Design
Langer O, Yogev Y, Xenakis EM, Brustman L. Overweight and obese in gestational diabetes: the impact on pregnancy outcome. American Journal of Obstetrics & Gynecology 192;(6):1768–1776. Excluded for Study Design
Lanni S, Barrett D. The predictive value of the 1-h 50-g glucose screen for diagnosing gestational diabetes mellitus in a high-risk population. Journal of Maternal-Fetal & Neonatal Medicine. 2004;15(6):375-9. Excluded for Study Design. [pmid: 15280108].
Lao TT, Tam KF. Gestational diabetes diagnosed in third trimester pregnancy and pregnancy outcome. Acta Obstetricia et Gynecologica Scandinavica. 2001;80(11):1003-8. Did not use designated diagnostic test or diagnostic criteria. [pmid: 11703196].
Lao TT, Wong KY. Perinatal outcome in large-for-gestational-age infants. Is it influenced by gestational impaired glucose tolerance?. Journal of Reproductive Medicine. 2002;47(6):497-502. Excluded for Study Design. [pmid: 12092021].
Lauenborg J, Hansen T, Jensen DM, Vestergaard H, Molsted-Pedersen L, Hornnes P, et al. Increasing incidence of diabetes after gestational diabetes: a long-term follow-up in a Danish population. Diabetes Care. 2004;27(5):1194-1199. Does not address one of the key questions. [pmid: 15111544].
Lauszus FF, Rasmussen OW, Henriksen JE, Klebe JG, Jensen L, Lauszus KS, et al. Effect of a high monounsaturated fatty acid diet on blood pressure and glucose metabolism in women with gestational diabetes mellitus. European Journal of Clinical Nutrition. 2001;55(6):436-43. Did not use designated diagnostic test or diagnostic criteria. [pmid: 11423920].
Lavin JP, Barden TP, Miodovnik M. Clinical experience with a screening program for gestational diabetes. Am J Obstet Gynecol. 1981;141(5):491-494. Does not address one of the key questions. [pmid: 7294074].
Leipold H, Worda C, Gruber CJ, Kautzky-Willer A, Husslein PW, Bancher-Todesca D. Large-for-gestational-age newborns in women with insulin-treated gestational diabetes under strict metabolic control. Wien Klin Wochenschr. 2005;117(1516):521-525. Did not use designated diagnostic test or diagnostic criteria. [pmid: 16160802].
Lemen PM, Wigton TR, Miller-McCarthey AJ, Cruikshank DP. Screening for gestational diabetes mellitus in adolescent pregnancies. Am J Obstet Gynecol. 1998;178(6):1251-1256. Does not address one of the key questions. [pmid: 9662309].
Li DF, Wong VC, O'Hoy KM, Yeung CY, Ma HK. Is treatment needed for mild impairment of glucose tolerance in pregnancy? A randomized controlled trial. British Journal of Obstetrics & Gynaecology. 1987;94(9):851-4. Poor Quality. [pmid: 3311138].
Livingston RC, Bachman-Carter K, Frank C, Mason WB. Diabetes mellitus in Tohon O'odham pregnancies. Diabetes Care. 1993;16(1):318-21. Excluded for Study Design. [pmid: 8422800].
Lu GC, Rouse DJ, DuBard M, Cliver S, Kimberlin D, Hauth JC. The effect of the increasing prevalence of maternal obesity on perinatal morbidity. Am J Obstet Gynecol. 2001;185(4):845-849. Excluded for Study Design. [pmid: 11641663].
Lucas MJ, Lowe TW, Bowe L, McIntire DD. Class A1 gestational diabetes: a meaningful diagnosis?. Obstet Gynecol. 1993;82(2):260-265. Excluded for Study Design. [pmid: 8336875].
MacNeill S, Dodds L, Hamilton DC, Armson BA, VandenHof M. Rates and risk factors for recurrence of gestational diabetes. Diabetes Care. 2001;24(4):659-662. Does not address one of the key questions. [pmid: 11315827].
Magee MS, Walden CE, Benedetti TJ, Knopp RH. Influence of diagnostic criteria on the incidence of gestational diabetes and perinatal morbidity. JAMA. 1993;269(5):609-615. Excluded for Study Design. [pmid: 8421365].
Manassakorn J, Wankrue P, Tantisirin P, Cheunwatana P, Intramax L. Oral glucose tolerance test at each trimester of pregnancy. Journal of the Medical Association of Thailand. 1988;71(1):25-8. Does not address morbidity and/or mortality, Does not address one of the key questions. [pmid: 3361252].
Mannucci E, Bardini G, Rotella CM. Effect of lower diagnostic thresholds on estimates of prevalence of impaired fasting glucose (IFG). Diabetic Medicine. 2005;22(3):353-4. Editorials, comments and letters. [pmid: 15717889].
Marquette GP, Klein VR, Niebyl JR. Efficacy of screening for gestational diabetes. Am J Perinatol. 1985;2(1):7-9. Does not address morbidity and/or mortality. [pmid: 3921038].
Massion C, O'Connor PJ, Gorab R, Crabtree BF, Nakamura RM, Coulehan JL. Screening for gestational diabetes in a high-risk population. J Fam Pract. 1987;25(6):569-575. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 3681218].
Mazze RS, Langer O. Primary, secondary, and tertiary prevention. Program for diabetes in pregnancy. Diabetes Care. 1988;11(3):263-8. Natural history only. [pmid: 3416681].
McDonald GW, Fisher GF, Burnham C. Reproducibility of the oral glucose tolerance test. Diabetes. 1965;14:473-480. Does not address one of the key questions. [pmid: 14334838].
McIntyre HD, Begg LM, Parry AF, Oats J. Audit of maternal and fetal outcomes in women treated for glucose intolerance during pregnancy. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2002;42(2):131-7. Excluded for Study Design. [pmid: 12069138].
McIntyre HD, Cheung NW, Oats JJ, Simmons D. Gestational diabetes mellitus: from consensus to action on screening and treatment. Medical Journal of Australia. 2005;183(6):288-9. Editorials, comments and letters. [pmid: 16167866].
Mecacci F, Carignani L, Cioni R, Bartoli E, Parretti E, La Torre P, et al. Maternal metabolic control and perinatal outcome in women with gestational diabetes treated with regular or lispro insulin: comparison with non-diabetic pregnant women. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):19-24. Poor Quality. [pmid: 14557006].
Mello G, Parretti E, Mecacci F, Lucchetti R, Cianciulli D, Lagazio C, et al. Anthropometric characteristics of full-term infants: effects of varying degrees of “normal” glucose metabolism. Journal of Perinatal Medicine. 1997;25(2):197-204. Does not address one of the key questions. [pmid: 9189841].
Mello G, Parretti E, Mecacci F, Lucchetti R, Lagazio C, Pratesi M, et al. Risk factors for fetal macrosomia: the importance of a positive oral glucose challenge test.[see comment]. European Journal of Endocrinology. 1997;137(1):27-33. Natural history only. [pmid: 9242198].
Meyer WJ, Carbone J, Gauthier DW, Gottmann DA. Early gestational glucose screening and gestational diabetes. Journal of Reproductive Medicine. 1996;41(9):675-9. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 8887193].
Miyakoshi K, Tanaka M, Matsumoto T, Hattori Y, Ueno K, Teranishi T, et al. Hypertensive disorders in Japanese women with gestational glucose intolerance. Diabetes Research & Clinical Practice. 2004;64(3):201-5. Excluded for Study Design. [pmid: 15126008].
Miyakoshi K, Tanaka M, Ueno K, Uehara K, Ishimoto H, Yoshimura Y. Cutoff value of 1 h, 50 g glucose challenge test for screening of gestational diabetes mellitus in a Japanese population. Diabetes Research & Clinical Practice. 2003;60(1):63-7. Excluded for Study Design, No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 12639767].
Montoro MN, Kjos SL, Chandler M, Peters RK, Xiang AH, Buchanan TA. Insulin resistance and preeclampsia in gestational diabetes mellitus. Diabetes Care. 2005;28(8):1995-2000. Does not address one of the key questions. [pmid: 16043744].
Moses RG, Griffiths RD. Can a diagnosis of gestational diabetes be an advantage to the outcome of pregnancy?. J Soc Gynecol Investig. 1995;2(3):523-525. Excluded for Study Design.
Moses RG, Mackay MT. Gestational diabetes: Is there a relationship between leg length and glucose tolerance?. Diabetes Care. 2004;27(5):1033-1035. Does not address one of the key questions. [pmid: 15111516].
Moses RG, Moses J, Davis WS. Gestational diabetes: do lean young caucasian women need to be tested?. Diabetes Care. 1998;21(11):1803-1806. Does not address one of the key questions. [pmid: 9802724].
Nahum GG, Huffaker BJ. Correlation between first- and early third-trimester glucose screening test results. Obstetrics & Gynecology. 1990;76(4):709-13. Poor Quality. [pmid: 2216208].
Nahum GG, Wilson SB, Stanislaw H. Early-pregnancy glucose screening for gestational diabetes mellitus. Journal of Reproductive Medicine. 2002;47(8):656-62. Did not use designated diagnostic test or diagnostic criteria. [pmid: 12216433].
Naylor CD, Sermer M, Chen E, Farine D. Selective screening for gestational diabetes mellitus. Toronto Trihospital Gestational Diabetes Project Investigators. N Engl J Med. 1997;337(22):1591-1596. Excluded for Study Design. [pmid: 9371855].
Naylor JL, Schraer CD, Mayer AM, Lanier AP, Treat CA, Murphy NJ. Diabetes among Alaska Natives: a review. International Journal of Circumpolar Health. 2003;62(4):363-87. Non-systematic review. [pmid: 14964764].
Nielsen IK, Vinther S, Birch K, Lange AP. Random blood glucose sampling as an early antenatal screening test for diabetes mellitus. Diabetes Research. 1988;8(1):31-3. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 3066564].
Nordin NM, Wei JW, Naing NN, Symonds EM. Comparison of maternal-fetal outcomes in gestational diabetes and lesser degrees of glucose intolerance. Journal of Obstetrics & Gynaecology Research. 2006;32(1):107-14. Excluded for Study Design. [pmid: 16445535].
Olefsky JM, Reaven GM. Insulin and glucose responses to identical oral glucose tolerance tests performed forty-eight hours apart. Diabetes. 1974;23(5):449-453. Excluded for Study Design. [pmid: 4830180].
Omori Y, Minei S, Uchigata Y, Shimizu M, Sanaka M, Honda M, et al. Comparison of diagnostic criteria of IGT, borderline, and GDM. Blood glucose curve and IRI response. Diabetes. 1991;40(Suppl 2):30-4. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 1748262].
Oppermann W, Camerini-Davalos RA. Early diabetes during pregnancy. Diabetes Care. 1980 Jun;3(3):465-7. Excluded for Study Design. [pmid: 6993161].
Ostlund I, Hanson U, Bjorklund A, Hjertberg R, Eva N, Nordlander E, et al. Maternal and fetal outcomes if gestational impaired glucose tolerance is not treated. Diabetes Care. 2003;26(7):2107-2111. Excluded for Study Design. [pmid: 12832321].
Ostlund I, Hanson U. Repeated random blood glucose measurements as universal screening test for gestational diabetes mellitus. Acta Obstetricia et Gynecologica Scandinavica. 2004;83(1):46-51. Did not use designated diagnostic test or diagnostic criteria. [pmid: 14678085].
O'Sullivan JB, Charles D, Mahan CM, Dandrow RV. Gestational diabetes and perinatal mortality rate. American Journal of Obstetrics & Gynecology. 1973;116(7):901-4. Natural history only. [pmid: 4718217].
O'Sullivan JB, Mahan CM. Criteria for the oral glucose tolerance test in pregnancy. Diabetes. 1964;13:278-285. Does not address one of the key questions. [pmid: 14166677].
O'Sullivan JB. Establishing criteria for gestational diabetes. Diabetes Care. 1980;3(3):437-9. Jun. Poor Quality. [pmid: 7389559].
O'Sullivan JB. Gestational diabetes. Unsuspected, asymptomatic diabetes in pregnancy. New England Journal of Medicine. 1961;264:1082-5. Prevelence only data. [pmid: 13730123].
Peled Y, Perri T, Chen R, Pardo J, Bar J, Hod M. Gestational diabetes mellitus—implications of different treatment protocols. Journal of Pediatric Endocrinology. 2004;17(6):847-52. Excluded for Study Design.
Pennison EH, Egerman RS. Perinatal outcomes in gestational diabetes: a comparison of criteria for diagnosis. American Journal of Obstetrics & Gynecology. 2001;184(6):1118-21. Excluded for Study Design, No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 11349174].
Pettitt DJ, Bennett PH, Hanson RL, Narayan KM, Knowler WC. Comparison of World Health Organization and National Diabetes Data Group procedures to detect abnormalities of glucose tolerance during pregnancy. Diabetes Care. 1994;17(11):1264-1268. Natural history only. [pmid: 7821165].
Pettitt DJ, Bennett PH, Hanson RL, Narayan KM, Knowler WC. Comparison of World Health Organization and National Diabetes Data Group procedures to detect abnormalities of glucose tolerance during pregnancy. Diabetes Care. 1994;17(11):1264-1268. Poor Quality. [pmid: 7821165].
Pettitt DJ, Bennett PH, Saad MF, Charles MA, Nelson RG, Knowler WC. Abnormal glucose tolerance during pregnancy in Pima Indian women. Long-term effects on offspring. Diabetes. 1991;40(Suppl 2):126-130. Does not address one of the key questions. [pmid: 1748241].
Pettitt DJ, Knowler WC, Baird HR, Bennett PH. Gestational diabetes: infant and maternal complications of pregnancy in relation to third-trimester glucose tolerance in the Pima Indians. Diabetes Care. 1980;3(3):458-464. Natural history only. [pmid: 7389563].
Phung H, Bauman A, Tran M, Young L, McDonald J, Michell L, et al. Factors that influence special care nursery admissions to a district hospital in South-western Sydney. Journal of Paediatrics & Child Health. 2005;41(3):119-24. Excluded for Study Design. [pmid: 15790322].
Poyhonen-Alho M, Teramo K, Kaaja R. Treatment of gestational diabetes with short- or long-acting insulin and neonatal outcome: a pilot study. Acta Obstetricia et Gynecologica Scandinavica. 2002;81(3):258-9. Did not use designated diagnostic test or diagnostic criteria. [pmid: 11966484].
Poyhonen-Alho M, Teramo K, Kaaja R. Treatment of gestational diabetes with short- or long-acting insulin and neonatal outcome: a pilot study. Acta Obstetricia et Gynecologica Scandinavica. 2002;81(3):258-9. Did not use designated diagnostic test or diagnostic criteria. [pmid: 11966484].
Ramadhani TA, Canfield MA, Waller DK, Case AP. Medical records vs. interview responses: a comparative analysis of selected variables for linked birth defect cases. Birth Defects Research. 2004;70(9):592-6. Excluded for Study Design. [pmid: 15368558].
Ramirez-Torres MA, Rodriguez-Pezino J, Zambrana-Castaneda M, Lira-Plascencia J, Parra A. Gestational diabetes mellitus and glucose intolerance among Mexican pregnant adolescents. Journal of Pediatric Endocrinology. 2003;16(3):401-5. Does not address morbidity and/or mortality, No information on yield (prevalence), sensitivity/specificity or reliability.
Ratzon N, Greenbaum C, Dulitzky M, Ornoy A. Comparison of the motor development of school-age children born to mothers with and without diabetes mellitus. Phys Occup Ther Pediatr. 2000;20(1):43-57. Does not address one of the key questions. [pmid: 11293914].
Ray JG. Screening and active management reduced perinatal complications more than routine care in gestational diabetes. ACP J Club. 2005;143(3):65. Editorials, comments and letters. [pmid: 16262222].
Reece EA. Synopsis of the North American Diabetes in Pregnancy Study Group Conference in Little Rock, Arkansas, May 2003. Journal of Maternal-Fetal & Neonatal Medicine. 2004;15(1):1-5. Editorials, comments and letters. [pmid: 15101605].
Ricart W, Bach C, Fernandez-Real JM, Sabria J. Major fetal complications in optimised progestational diabetes mellitus. Diabetologia. 2000;43(8):1077-8. Editorials, comments and letters. [pmid: 10990089].
Ricart W, Lopez J, Mozas J, Pericot A, Sancho MA, Gonzalez N, et al. Body mass index has a greater impact on pregnancy outcomes than gestational hyperglycaemia. Diabetologia. 2005;48(9):1736-1742. Natural history only. [pmid: 16052327].
Ricart W, Lopez J, Mozas J, Pericot A, Sancho MA, Gonzalez N, et al. Potential impact of American Diabetes Association (2000) criteria for diagnosis of gestational diabetes mellitus in Spain. Diabetologia. 2005;48(6):1135-41. Natural history only. [pmid: 15889233].
Rizzo TA, Dooley SL, Metzger BE, Cho NH, Ogata ES, Silverman BL. Prenatal and perinatal influences on long-term psychomotor development in offspring of diabetic mothers. Am J Obstet Gynecol. 1995;173(6):1753-1758. Excluded for Study Design. [pmid: 8610757].
Roberts RN, Moohan JM, Foo RL, Harley JM, Traub AI, Hadden DR. Fetal outcome in mothers with impaired glucose tolerance in pregnancy. Diabet Med. 1993;10(5):438-443. Excluded for Study Design. [pmid: 8334823].
Rouse DJ, Owen J, Goldenberg RL, Cliver SP. The effectiveness and costs of elective cesarean delivery for fetal macrosomia diagnosed by ultrasound. JAMA. 1996;276(18):1480-1486. Does not address one of the key questions. [pmid: 8903259].
Rouse DJ, Owen J. Prophylactic cesarean delivery for fetal macrosomia diagnosed by means of ultrasonography—A Faustian bargain?. Am J Obstet Gynecol. 1999;181(2):332-338. Does not address one of the key questions. [pmid: 10454678].
Rudge MV, Calderon IM, Ramos MD, Abbade JF, Rugolo LM. Perinatal outcome of pregnancies complicated by diabetes and by maternal daily hyperglycemia not related to diabetes. A retrospective 10-year analysis. Gynecologic & Obstetric Investigation. 2000;50(2):108-12. Excluded for Study Design. [pmid: 10965194].
Rust OA, Bofill JA, Andrew ME, Kincaid TA, Stubbs TM, Miller EH, et al. Lowering the threshold for the diagnosis of gestational diabetes. Am J Obstet Gynecol. 1996;175(4 Pt 1):961-965. Excluded for Study Design. [pmid: 8885755].
Sacks DA, Abu-Fadil S, Greenspoon JS, Fotheringham N. Do the current standards for glucose tolerance testing in pregnancy represent a valid conversion of O'Sullivan's original criteria?. Am J Obstet Gynecol. 1989;161(3):638-641. Does not address one of the key questions. [pmid: 2782345].
Sacks DA, Abu-Fadil S, Greenspoon JS, Fotheringham N. How reliable is the fifty-gram, one-hour glucose screening test?. Am J Obstet Gynecol. 1989;161(3):642-645. Poor Quality. [pmid: 2782346].
Sacks DA, Abu-Fadil S, Karten GJ, Forsythe AB, Hackett JR. Screening for gestational diabetes with the one-hour 50-g glucose test. Obstetrics & Gynecology. 1987;70(1):89-93. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 3601272].
Sacks DA, Chen W, Wolde-Tsadik G, Buchanan TA. Fasting plasma glucose test at the first prenatal visit as a screen for gestational diabetes. Obstetrics & Gynecology. 2003;101(6):1197-203. Did not use established screening criteria. [pmid: 12798525].
Sacks DA, Greenspoon JS, Abu-Fadil S, Henry HM, Wolde-Tsadik G, Yao JF. Toward universal criteria for gestational diabetes: the 75-gram glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1995;172(2 Pt 1):607-614. Does not address one of the key questions. [pmid: 7856693].
Sacks DA, Liu AI, Wolde-Tsadik G, Amini SB, Huston-Presley L, Catalano PM. What proportion of birth weight is attributable to maternal glucose among infants of diabetic women? American Journal of Obstetrics & Gynecology 194;(2):501–507. Excluded for Study Design
Saldana TM, Siega-Riz AM, Adair LS, Savitz DA, Thorp JM Jr. The association between impaired glucose tolerance and birth weight among black and white women in central North Carolina. Diabetes Care. 2003;26(3):656-61. Natural history only. [pmid: 12610017].
Sameshima H, Kamitomo M, Kajiya S, Kai M, Furukawa S, Ikenoue S. Early glycemic control reduces large-for-gestational-age infants in 250 Japanese gestational diabetes pregnancies. American Journal of Perinatology. 2000;17(7):371-6. Excluded for Study Design. [pmid: 12141524].
Santini DL, Ales KL. The impact of universal screening for gestational glucose intolerance on outcome of pregnancy. Surg Gynecol Obstet. 1990;170(5):427-436. Excluded for Study Design. [pmid: 2326724].
Sarkar S, Watman J, Seigel WM, Schaeffer HA. A prospective controlled study of neonatal morbidities in infants born at 36 weeks or more gestation to Women with diet-controlled gestational diabetes (GDM-class Al). J Perinatol. 2003;23(3):223-228. Does not address one of the key questions. [pmid: 12732860].
Schafer-Graf UM, Dupak J, Vogel M, Dudenhausen JW, Kjos SL, Buchanan TA, et al. Hyperinsulinism, neonatal obesity and placental immaturity in infants born to women with one abnormal glucose tolerance test value. J Perinat Med. 1998;26(1):27-36. Does not address one of the key questions. [pmid: 9595364].
Schmidt MI, Duncan BB, Reichelt AJ, Branchtein L, Matos MC, Costa e Forti, et al. Gestational diabetes mellitus diagnosed with a 2-h 75-g oral glucose tolerance test and adverse pregnancy outcomes. Diabetes Care. 2001;24(7):1151-1155. Natural history only. [pmid: 11423494].
Schwartz ML, Ray WN, Lubarsky SL. The diagnosis and classification of gestational diabetes mellitus: is it time to change our tune?. Am J Obstet Gynecol. 1999;180(6 Pt 1):1560-1571. Does not report sensitivity and specificity criterion to assess specified health outcomes. [pmid: 10368504].
Schytte T, Jorgensen LG, Brandslund I, Petersen PH, Andersen B. The clinical impact of screening for gestational diabetes. Clin Chem Lab Med. 2004;42(9):1036-1042. Did not use designated diagnostic test or diagnostic criteria. [pmid: 15497470].
Scott DA, Loveman E, McIntyre L, Waugh N. Screening for gestational diabetes: a systematic review and economic evaluation. Health Technol Assess. 2002;6(11):1-161. SER used as source document. [pmid: 12433317].
Sermer M, Naylor CD, Farine D, Kenshole AB, Ritchie JW, Gare DJ, et al. The Toronto Tri-Hospital Gestational Diabetes Project. A preliminary review. Diabetes Care. 1998;21(Suppl 2):B33-B42. Did not use designated diagnostic test or diagnostic criteria. [pmid: 9704225].
Sermer M, Naylor CD, Gare DJ, Kenshole AB, Ritchie JW, Farine D, et al. Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1995;173(1):146-156. Did not use designated diagnostic test or diagnostic criteria. [pmid: 7631672].
Sermer M, Naylor CD, Gare DJ, Kenshole AB, Ritchie JW, Farine D, et al. Impact of time since last meal on the gestational glucose challenge test. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1994;171(3):607-616. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 8092205].
Shamsuddin K, Mahdy ZA, Siti RI, Jamil MA, Rahimah MD. Risk factor screening for abnormal glucose tolerance in pregnancy. Int J Gynaecol Obstet. 2001;75(1):27-32. Does not address one of the key questions. [pmid: 11597616].
Sheffield JS, Butler-Koster EL, Casey BM, McIntire DD, Leveno KJ. Maternal diabetes mellitus and infant malformations. Obstetrics & Gynecology. 2002;100(5 Pt 1):925-30. Excluded for Study Design. [pmid: 12423854].
Silverman BL, Rizzo T, Green OC, Cho NH, Winter RJ, Ogata ES, et al. Long-term prospective evaluation of offspring of diabetic mothers. Diabetes. 1991;40(Suppl 2):121-125. Does not address one of the key questions. [pmid: 1748240].
Simmons D, Thompson CF, Conroy C, Scott DJ. Use of insulin pumps in pregnancies complicated by type 2 diabetes and gestational diabetes in a multiethnic community. Diabetes Care. 2001;24(12):2078-82. Did not use designated diagnostic test or diagnostic criteria. [pmid: 11723086].
Simmons D, Thompson CF, Conroy C. Incidence and risk factors for neonatal hypoglycaemia among women with gestational diabetes mellitus in South Auckland. Diabetic Medicine. 2000;17(12):830-4. Excluded for Study Design. [pmid: 11168324].
Simpson RW, Kast SJ. Management of gestational diabetes with a conservative insulin protocol. Medical Journal of Australia. 2000;172(11):537-40. Did not use designated diagnostic test or diagnostic criteria. [pmid: 10920751].
Siribaddana SH, Deshabandu R, Rajapakse D, Silva K, Fernando DJ. The prevalence of gestational diabetes in a Sri Lankan antenatal clinic. Ceylon Medical Journal. 1998;43(2):88-91. Prevalence outside U.S. [pmid: 9704548].
Sjogren B, Robeus N, Hansson U. Gestational diabetes: a case-control study of women's experience of pregnancy, health and the child. J Psychosom Res. 1994;38(8):815-822. Poor Quality. [pmid: 7722961].
Skitek M. Screening for gestational diabetes mellitus. Clinical Chemistry & Laboratory Medicine. 2005;43(6):664-6. Editorials, comments and letters. [pmid: 16006265].
Soonthornpun S, Soonthornpun K, Aksonteing J, Thamprasit A. A comparison between a 75-g and 100-g oral glucose tolerance test in pregnant women. International Journal of Gynaecology & Obstetrics. 2003;81(2):169-73. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 12706274].
Southwick RD, Wigton TR. Screening for gestational diabetes mellitus in adolescent Hispanic Americans. Journal of Reproductive Medicine. 2000;45(1):31-4. Excluded for Study Design. [pmid: 10664944].
Stamilio DM, Olsen T, Ratcliffe S, Sehdev HM, Macones GA. False-positive 1-hour glucose challenge test and adverse perinatal outcomes. Obstetrics & Gynecology. 2004;103(1):148-56. Excluded for Study Design. [pmid: 14704259].
Suhonen L, Teramo K. Hypertension and pre-eclampsia in women with gestational glucose intolerance. Acta Obstet Gynecol Scand. 1993;72(4):269-272. Excluded for Study Design. [pmid: 8389513].
Sunsaneevithayakul P, Boriboohirunsarn D, Sutanthavibul A, Ruangvutilert P, Kanokpongsakdi S, Singkiratana D, et al. Risk factor-based selective screening program for gestational diabetes mellitus in Siriraj Hospital: result from clinical practice guideline. Journal of the Medical Association of Thailand. 2003;86(8):708-14. Excluded for Study Design. [pmid: 12948268].
Super DM, Edelberg SC, Philipson EH, Hertz RH, Kalhan SC. Diagnosis of gestational diabetes in early pregnancy. Diabetes Care. 1991;14(4):288-94. Did not use designated diagnostic test or diagnostic criteria. [pmid: 2060431].
Sutton L, Sayer GP, Bajuk B, Richardson V, Berry G, Henderson-Smart DJ. Do very sick neonates born at term have antenatal risks? 2. Infants ventilated primarily for lung disease. Acta Obstetricia et Gynecologica Scandinavica. 2001;80(10):917-25. Excluded for Study Design. [pmid: 11580736].
Svare JA, Hansen BB, Molsted-Pedersen L. Perinatal complications in women with gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2001;80(10):899-904. Excluded for Study Design. [pmid: 11580734].
Tanir HM, Sener T, Gurer H, Kaya M. A ten-year gestational diabetes mellitus cohort at a university clinic of the mid-Anatolian region of Turkey. Clinical & Experimental Obstetrics & Gynecology. 2005;32(4):241-4. Excluded for Study Design.
Taylor JS, Kacmar JE, Nothnagle M, Lawrence RA. A systematic review of the literature associating breastfeeding with type 2 diabetes and gestational diabetes. J Am Coll Nutr. 2005;24(5):320-326. Does not address one of the key questions. [pmid: 16192255].
Tuffnell DJ, West J, Walkinshaw SA. Treatments for gestational diabetes and impaired glucose tolerance in pregnancy. Cochrane Database of Systematic Reviews 2006;(1). SER used as source document
Turok DK, Ratcliffe SD, Baxley EG. Management of gestational diabetes mellitus. American Family Physician. 2003;68(9):1767-72. Non-systematic review. [pmid: 14620596].
Vaidyanathan B, Menon PS. Insulin analogues and management of diabetes mellitus. Indian Journal of Pediatrics. 2000;67(6):435-41. Excluded for Study Design. [pmid: 10932964].
van Hoorn J, Dekker G, Jeffries B. Gestational diabetes versus obesity as risk factors for pregnancy-induced hypertensive disorders and fetal macrosomia. Aust N Z J Obstet Gynaecol. 2002;42(1):29-34. Excluded for Study Design. [pmid: 11926638].
Vanky E, Salvesen KA, Heimstad R, Fougner KJ, Romundstad P, Carlsen SM. Metformin reduces pregnancy complications without affecting androgen levels in pregnant polycystic ovary syndrome women: results of a randomized study. Human Reproduction 2004;(8):1734–1740. Does not address one of the key questions
Vidaeff AC, Yeomans ER, Ramin SM. Gestational diabetes: a field of controversy. Obstetrical & Gynecological Survey. 2003;58(11):759-69. Non-systematic review. [pmid: 14581827].
Vogel N, Burnand B, Vial Y, Ruiz J, Paccaud F, Hohlfeld P. Screening for gestational diabetes: variation in guidelines. Eur J Obstet Gynecol Reprod Biol. 2000;91(1):29-36. Does not address one of the key questions. [pmid: 10817875].
Walkinshaw SA. Dietary regulation for ‘gestational diabetes’. Cochrane Database of Systematic Reviews 2006;(1). Does not address one of the key questions
Walkinshaw SA. Very tight versus tight control for diabetes in pregnancy. Cochrane Database of Systematic Reviews 2006;(1). Does not address one of the key questions
Watson WJ. Serial changes in the 50-g oral glucose test in pregnancy: implications for screening. Obstetrics & Gynecology. 1989;74(1):40-3. No information on yield (prevalence), sensitivity/specificity or reliability. [pmid: 2733939].
Weijers RN, Bekedam DJ, Smulders YM. Determinants of mild gestational hyperglycemia and gestational diabetes mellitus in a large dutch multiethnic cohort. Diabetes Care. 2002;25(1):72-7. Non-systematic review. [pmid: 11772904].
Wein P, Dong ZG, Beischer NA, Sheedy MT. Factors predictive of recurrent gestational diabetes diagnosed before 24 weeks' gestation. American Journal of Perinatology. 1995;12(5):352-6. Excluded for Study Design. [pmid: 8540942].
Weiner CP, Fraser MM, Burns JM, Schnoor D, Herrig J, Whitaker LA. Cost efficacy of routine screening for diabetes in pregnancy: 1-h versus 2-h specimen. Diabetes Care. 1986;9(3):255-259. Does not address one of the key questions. [pmid: 3089747].
Weiss JL, Malone FD, Emig D, Ball RH, Nyberg DA, Comstock CH et al. Obesity, obstetric complications and cesarean delivery rate—a population-based screening study. American Journal of Obstetrics & Gynecology 190;(4):1091–1097. Does not address one of the key questions
Weissman A, Solt I, Zloczower M, Jakobi P. Hypoglycemia during the 100-g oral glucose tolerance test: incidence and perinatal significance. Obstetrics & Gynecology. 2005;105(6):1424-8. Excluded for Study Design. [pmid: 15932839].
Wen SW, Liu S, Kramer MS, Joseph KS, Levitt C, Marcoux S et al. Impact of prenatal glucose screening on the diagnosis of gestational diabetes and on pregnancy outcomes. American Journal of Epidemiology 152(11):1009 –14; discussion 1015 –6, 2000. Excluded for Study Design
Wong L, Tan AS. The glucose challenge test for screening gestational diabetes in pregnant women with no risk factors. Singapore Medical Journal. 2001;42(11):517-21. Does not address morbidity and/or mortality. [pmid: 11876377].
Wood SL, Jick H, Sauve R. The risk of stillbirth in pregnancies before and after the onset of diabetes. Diabetic Medicine 1920;(9):703–7, 2003. Excluded for Study Design
Wyatt PR, Owolabi T, Meier C, Huang T. Age-specific risk of fetal loss observed in a second trimester serum screening population. American Journal of Obstetrics & Gynecology 192;(1):240–246. Does not address one of the key questions
Yang X, Hsu-Hage B, Zhang H, Zhang C, Zhang Y, Zhang C. Women with impaired glucose tolerance during pregnancy have significantly poor pregnancy outcomes. Diabetes Care. 2002;25(9):1619-1624. Natural history only. [pmid: 12196437].
Yogev Y, Langer O, Brustman L, Rosenn B. Pre-eclampsia and gestational diabetes mellitus: does a correlation exist early in pregnancy?. J Matern Fetal Neonatal Med. 2004;15(1):39-43. Excluded for Study Design. [pmid: 15101610].
Yogev Y, Langer O, Xenakis EM, Rosenn B. Glucose screening in Mexican-American women. Obstetrics & Gynecology. 2004;103(6):1241-5. Prevalence only data. [pmid: 15172859].
Young C, Kuehl TJ, Sulak PJ, Allen SR. Gestational diabetes screening in subsequent pregnancies of previously healthy patients. American Journal of Obstetrics & Gynecology. 2000;182(5):1024-6. Excluded for Study Design. [pmid: 10819816].