# Appendix C: Evidence Tables

Table 1 Trials of Treatment for Gestational Diabetes Mellitus — Key Question 3

Author, Year | Type of trial | Length of trial | Study Setting | Primary Study Objectives/Outcomes | Inclusion/Exclusion Criteria | N, Subjects | BMI | Race/Ethnicity | Gravidity/Parity | Age | Screening Test/Mode of Diagnosis | Test preparation | Screening test results | Gestational age at screening | Previous GDM or macrosomic infant | Intervention | Control | Follow-up Measures Surveillance | Insulin required | Maternal hypoglycemia | Glycemic control/separation | Perineal injury | Maternal Wt change/separation | Induction/Delivery Mode | Preeclampsia/PIH | Death | Depression/Anxiety | QOL (ante & postpartum) | Stillbirth | Neonatal death | Shoulder dystocia/BPI | Clavicle FX | Respiratory distress | Hyperbilirubinemia/jaundice | Hypoglycemia/Hypocalcemia | NICU admission for treatment | Birth weight | %LGA/macrosomia | Other Outcomes | MV Analysis | Adverse Effects | Comments | Quality rating
Treated vs. Untreated
Crowther 2005^39^ ACHOIS | RCT | Screened 16–30 weeks f/u 3 mos. Post-partum | 18 centers: 14 Australia; 4 UK Initiated prior to change in WHO criteria Recruitment 9/93–6/03 | To assess whether treatment of GDM reduces perinatal complications; or has an effect on maternal outcomes; mood; or quality-of-life | Inclusion: Singleton or twin pregnancy 16–30 weeks gestation; RF for GDM or 50-g GCT (≥7.8 mmol/l) AND 75-g OGTT (24–34 weeks gestation) 2-hr plasma glucose 7.8–11.0 mmol/l with fasting plasma glucose <7.8 mmol/l Exclusion: Previously treated GDM; active chronic disease (except essential hypertension) | N=1,000 IG: 490 CG: 510 | Median (Interquartile range) IG: 26.8 (23.3–31.2) CG: 26.0 (22.9–30.9) | IG: 73% White 19% Asian 9% Other CG: 78% White 14% Asian 8% Other | Primiparous N (%) IG: 212 (43%) CG: 251 (49%) | Mean (SD) IG: 30.9 (5.4) CG: 30.1(5.5) | Two steps Step 1: RF or 50-g GCT (≥7.8 mmol/l) 1-hr cut-off (93% were positive with 50-g) Step 2: 75 g OGTT | 50-g GCT NR 75 g OGTT 48 hr normal diet; 8 hr overnight fast | Median (Interquartile range) [underlined: GCT, mmol/l] IG: 8.8 (8.2–9.7) CG: C: 8.8 (8.3–9.7) [underlined: 75-g OGTT, mmol/l] IG: 8.6 (8.1–9.3) CG: 8.5 (8.1–9.1) | Median (Interquartile range) IG: 29.1 weeks (28.2–30.0) CG: 29.2 weeks (28.2–30.0) | Previous pregnancy ending in perinatal death IG: 12/278 (4%) CG: 7/259 (3%) | IG: Replicated clinical care in which universal screening and treatment for GDM are available Received a slip indicating a diagnosis of glucose intolerance and the plan for intervention Intervention was individualized dietary advice from dietician; instructions to self-monitor glucose QID until within specified range for 2 weeks; insulin initiated if not in range and titrated to glucose range | CG: Replicated clinical care in which screening for GDM was not available Received a slip indicating they did not have gestational diabetes A proportion (not fewer than one in 5) had normal OGTT results assigned to routine care to help maintain blinding Glucose monitoring and insulin initiated at the discretion of the attending clinician | Visit with a dietician 453 (92%) IG vs. 51 (10%) CG. Visit with a diabetes educator 460 (94%) IG vs. 56 (11%) CG. Number of antetal visits (median) 5.0 IG vs. 5.2 CG. Number of MD visits after enrollment (median) 3 IG vs. 0 CG. | IG: 100 (20%) CG: 17 (3%) | NR | NR | Any perineal trauma, N (%) IG: 255 (52%) CG: 254 (50%) Adj RR: 1.05 (0.93 to 1.19) p=0.42 | Weight gain from first to last prenatal visit (kg; mean, sd) IG: 8.1 (0.3) CG: 9.8 (0.4) Adj p =0.01 | Adj RR Induction of Labor: 1.36 (1.15–1.62) p,0.001 C-section overall 0.97 (0.81–1.16) p=0.73 Also non-significant for elective and emergency c-section | Adj RR 0.70 (0.51–0.95) p=0.02 PIH def: BP ≥ 140/90 mmHg on 2 occasions more than 4 hours apart | NR | Depression Adj RR 0.46 (0.29–0.73) p=0.001 Defined as: Likely depressed (EPDS score >12) at 3 months post-partum Anxiety score Adj mean diff -0.3 (-0.9–0.4; p=0.41) | Antepartum: IG: SF-36 increased emotional role, overall physical component, health state utility 3 mos. Post-partum No sig diff | IG: 0 CG: 3 p=0.26 RR not calculated as zero in IG | IG: 0 CG: 2 p=0.50 RR not calculated as zero in IG | Shoulder Dys: Adj RR 0.460.19–1.10) p=0.08 Nerve palsy IG:0 CG: 3 p=0.11 RR not calculated as zero in IG | Bone Fracture* IG: 0 CG: 1 p=0.38 *RR not calculated as zero in IG | Adj RR 1.52 (0.86–2.71) p=0.15 RDS def: Needed oxygen >4 hrs. after birth | Adj RR 0.93 (0.63–1.37) p=0.72 Defined as: Requiring phototherapy | Adj RR 1.42 (0.87–2.32) p=0.16 Required IV therapy Adj mean diff 0.52 (0.05–5.69) p=1.0 Neonatal convulsions | NICU-NR “neonatal nursery” N(%) IG: 357(71) CG: 321(61) Adj RR 1.13 (1.03–1.23) p=0.01 | Adj mean diff -145 g; (-219 to -70; p<0.001) | LGA Adj RR 0.62 (0.47–0.81; p<0.001) LGA def: >90%ile Macrosomia Adj RR 0.47 (0.34–0.64; p<0.001) Macrosomia def: ≥ 4kg | Combined outcome for any serious perinatal complication (death, shoulder dystocia, bone fracture, nerve palsy) Adj RR 0.33 (0.14–0.75) | NR | Marginal QOL antepartum and postpartum improved for IG | Glucose values during pregnancy NR | Good
O'Sullivan 1966^44^ | RCT | 1954-1960 | Patients attending the Prenatal Metabolic Clinic at Boston City Hospital | Study relationship of maternal blood glucose to pregnancy (fetal) outcomes and assess effect of diet + insulin therapy | Inclusion: All pregnant women attending the clinic were screened with 50g GCT; Randomized to treatment versus no treatment if 3 hr. OGTT 100g with ≥2 values: Fasting ≥ 110 mg/dl; 1 hr ≥ 170 mg/dl; 2 hr ≥ 120 mg/dl; 3 hr ≥ 110 mg/dl (NOTE: This is whole blood and formed later basis of current criteria) Exclusion: Previous diabetes; blood sugar > 300 mg/dl; classic diabetes symptoms; clinic visit ≥ 37th week gestation | IG: 307 +CG: 308 -CG: 328 IG: defined as +OGTT, treated +CG: defined as +OGTT but not treated -CG: def as normal glucose tolerance | % Ideal Weight: N(%) [underlined: ≥ 20%] IG: 85 (27.7%) +CG: 94 (30.5%) -CG: 38 (11.6%) [underlined: 10–19%] IG: 49 (16%) +CG: 50 (16.2%) -CG: 48 (14.6%) [underlined: -09% to +09%] IG: 122 (39.7%) +CG: 121 (39.3%) -CG: 162 (49.4%) [underlined: ≤ -10%] IG: 51 (16.6%) +CG: 43 (14%) -CG: 80 (24.4%) | NR | Mean Parity: IG: 3.6 +CG: 3.7 -CG: 2.2 | Mean yrs: IG: 30.3 +CG: 31.2 -CG: 25.1 | Two Steps: Screen: venous whole blood ≥130 mg/dl with 50 g GCT or +RF Diagnosis: 100 g OGTT (3 hr). | 250 g carbohydrate daily diet × 3 days prior to OGTT; Fasting prior to test (length of time NR) | NR other than in the same range for randomization to treatment | NR; except “women who had normal glucose tolerance in one trimester received repeat tests in subsequent trimesters” and excluded if ≥ 37 weeks | RF to have OGTT included prior fetal death, neonatal death, congenital anomaly, baby weighing ≥ 9lb., prematurity (<5 lb 6 oz), or toxemia (excessive weight gain, HTN, or proteinuria) in 2 or more pregnancies; however frequency in this sample NR | IG: Individualized diet (40%CHO, 30cal/kg ideal body weight, 1.5–2g protein/kg ideal body weight) + AM NPH Insulin titrated to glucosuria (daily home testing or in clinic), starting dose 10 units | +CG; -CG: Routine OB and diet instructions | 2,701 post-prandial blood sugars in 432 patients, average of 6 blood draws per person , abnl values set arbitrarily at >100mg/dl fasting and 150 mg/dl 2hr pp)NOTE: Capillary home glucose monitroing was not feasible at the time of this study.) | IG: All given insulin +CG: NR -CG: NR | NR | Overall # abnormal values: IG and +CG “had significantly more abnormal blood sugars” than -CG but “were not significantly different from each other” p=NR Differences in mean glucose values: -CG “had significantly lower mean blood sugar levels for each pp time period” (p=NR) IG vs. +CG did not differ at 1/2–1, 2–3, 3–4 hrs pp (p=NR). mean (SD) Glucose at 1–2 hrs pp* IG: 88.8 (23.1) +CG: 92.6 (23.2) p<0.01 Glucose at >4 hr pp or fasting* IG: 69.1 (16.9) +CG: 74.3 (15.4) p<0.05 | NR | NR | NR | NR | NR | NR | NR | IG: 8 (2.6%) +CG: 8 (2.6%) -CG: 4 (1.2%) Defined: Death of viable fetus > 28 weeks | IG: 5 (1.6%) +CG: 7 (2.3%) -CG: 2 (0.6%) Total viable losses: IG: 13 (4.3%)*^†^ +CG: 15 (4.9%)* -CG: 6 (1.9%)*^†^ *p<0.01 for IG and +CG vs -CG^†^ p<0.05 for IG vs -CG | NR | NR | NR | NR | NR | NR | NR | IG: 13 (4.3%) +CG: 40 (13.1%)) -CG: 12 (3.7%) Note: overall p-value NR, but IG “showed a sig diff (from +CG) for all but weight >4.5–5.0 lb.” Def: ≥ 9lbs. -CG and IG “are not significantly different from each other” p=NR % with large babies by Maternal wt status ≤9%: IG: 2.3% +CG: 10.% -CG: 2.5% Maternal wt status ≥10%: IG: 7.6% +CG: 16.4% -CG: 7.0% | Congenital Abnormality: IG: 40 (13.1%) +CG: 49 (16%) -CG: 44 (13.6%) NS, p=NR Born Premature: IG: 26 (8.5%) +CG: 24 (7.8%) -CG: 25 (7.7%) NS, p=NR | NR | NR | Across all study groups, overweight women had higher % of large babies. In discussion section authors stated that 97% of IG and +CG had normal f/u OGTT postpartum, so true GDM . | Fair
Treatment Comparison
Langer 2000^42^ Langer 2005^47^ | RCT | Screened 11–33 weeks F/U to postpartum | Inner-city maternal health clinics in San Antonio, TX | To assess whether glyburide is an effective alternative to insulin for control of hyperglycemia during pregnancy; glycemic control; maternal and neonatal complications. | Inclusion: Singleton pregnancy 11–33 weeks; 50-g GCT > 130 mg/dL at 1 hr. AND 100-g OGTT with ≥ 2 abnormal glucose values by C&C criteria. Those with fasting plasma glucose <95 mg/dL were initially treated with diet and enrolled if levels increased to ≥95 mg/dL or postprandial levels were ≥ 120 mg/dL. Exclusion: NR | N=404 IG_GLY_: 201 IG_INS_: 203 | BMI ≥ 27.3 prior to pregnancy N (%) IG_GLY_: 141 (70) IG_INS_: 132 (65) Pre-pregnancy weight, kg IG_GLY_: 74±19 IG_INS_: 76±18 | 83% Hispanic 12% White 5% Black | Nulliparity N (%) IG_GLY_: 56 (28) IG_INS_: 59 (29) | yrs, Mean±SD IG_GLY_: 29±7 IG_INS_: 30±6 | Step 1: 50-g GCT > 130 mg/dL Step 2: 100-g OGTT with ≥ 2 abnormal glucose values by C&C criteria. | Fasting for OGTT | Screening plasma glucose mg/dL, mean±SD IG_GLY_: 169±28 IG_INS_: 169±31 OGTT mg/dL, mean±SD [underlined: Fasting] IG_GLY_: 97±14 IG_INS_: 98±16 [underlined: 1 hr] IG_GLY_: 197±31 IG_INS_: 201±30 [underlined: 2 hr] IG_GLY_: 174±31 IG_INS_: 174±29 [underlined: 3 hr] IG_GLY_: 140±37 IG_INS_: 134±37 | wks, mean±SD IG_GLY_: 24±7 IG_INS_: 25±7 | Previous GDM N(%) IG_GLY_: 24(12) IG_INS_: 22(11) Previous macrosomic infant N(%) IG_GLY_: 36(18) IG_INS_: 45(22) | IG_GLY_: Initial oral dose of 2.5 mg of glyburide in the morning, when indicated the dose increased the following week by 2.5 mg and thereafter by 5 mg up to a total of 20mg. All women were provided standard nutritional instruction for three meals and four snacks daily. | IG_INS_: Initial insulin dose of 0.7 unit/kg of body weight at admission given subcutaneously 3 times daily and increased weekly as necessary. All women were provided standard nutritional instruction for three meals and four snacks daily. | Number of clinic visits attended: mean±SD IG_GLY_: 11±5 IG_INS_: 12±6 Number of measurements of glucose/day: IG_GLY_: 4±2 IG_INS_ 4±2 Serum c-peptide IG_INS_: 3.8±2.3 IG_GLY_: 3.4±1.5 | IG_GLY_: 8 women (4%) did not achieve good glycemic control and were switched to insulin. | Number with blood glucose < 40 mg/dL: IG_GLY_: 4 IG_INS_: 41 (p=0.03) None had more than 6% of measurements below this value None reported severe symptoms with hypoglycemia | During treatment: blood glucose mg/dL, mean±SD [underlined: Fasting] IG_GLY_: 98±13 IG_INS_: 96±16 [underlined: Preprandial] IG_GLY_: 95±15 IG_INS_: 97±14 [underlined: Postprandial] IG_GLY_: 113±22 IG_INS_: 112±15 [underlined: Mean] IG_GLY_: 105±16 IG_INS_: 105±18 [underlined: Glycosylated Hemoglobin (%)] IG_GLY_: 5.5±0.7 IG_INS_: 5.4±0.6 None were sig diff | NR | Weight gain lb, mean±SD IG_GLY_: 21±17 IG_INS_: 21±15 Weight measured prior to pregnancy and week prior to delivery. | Cesarean IG_GLY_: 23% IG_INS_: 24% | Preeclampsia IG_GLY_: 6% IG_INS_: 6% | NR | NR | NR | N (%) IG_GLY_: 1(0.5) IG_INS_: 1(0.5) p=0.99 | N (%) IG_GLY_: 1(0.5) IG_INS_: 1(0.5) p=0.99 | NR | NR | N (%) IG_GLY_: 4(2) IG_INS_: 6(3) p=0.52 Needed support | N (%) IG_GLY_: 12(6) IG_INS_: 8(4) p=0.36 Defined: ≥ 12 mg/dL | Hypoglycemia N (%) IG_GLY_: 18(9) IG_INS_: 12(6) p=0.25 Defined: 2 consecutive values ≤ 40 mg/dL Hypocalcemia N (%) IG_GLY_: 2(1) IG_INS_: 2(1) p=0.99 Defined: ≤ 7.0 mg/dL | N (%) IG_GLY_: 12(6) IG_INS_: 14(7) p=0.68 | g, mean±SD IG_GLY_: 3256±543 IG_INS_: 3194±598 p=0.28 | N (%) IG_GLY_: 14(7) IG_INS_: 9(4) p=0.26 Defined as >4000g %LGA ≤95 mg/dL on OGTT _IGGLY_: 8.8% _IGINS_: 7.7% >95 mg/dL on OGTT _IGGLY_: 18.4% _IGINS_: 17.8% p=0.01 for the difference between low and high fasting glucose Defined as ≥90th %ile in their population | Congenital anomaly N (%) IG_GLY_: 5(2) IG_INS_: 4(2) p=0.74 | | None reported severe symptoms such as: confusion, poor coordination, double vision, headache, or combativeness, or inability to treat themselves with hypoglycemia (<40 mg/dL). | Glyburide not detected in cord blood of any infant. | Good
Bancroft 2000^38^ | RCT | | 2 specialist diabetes clinics in the UK. | To determine whether less intensive monitoring of blood glucose levels during pregnancy is feasible. Frequency of admission to specialty care baby unit; perinatal morbidity; maternal inconvenience. | Inclusion: Blood glucose levels-Fasting < 7.0 mmol/L and between 7.8–11.0 mmol/L 2 hrs after 75 g OGTT. Exclusion: NR | N=68 IG_DietgluM_ : 32 IG_Diet_:36 | Mean(SD) IG_DietgluM_: 31.2(6.7) IG_Diet_: 27.5(6.1) | N(%) IG_DietgluM_: Asian 10(31) Caucasian 22(69) IG_Diet_: Asian 11(31) Caucasian 25(69) | Parity Median (range) IG_DietgluM_: 2(0–6) IG_Diet_: 1(0–9) | At delivery Mean(SD) IG_DietgluM:_ 29.7(6.23) IG_Diet_: 31.9(5.17) | One step: 75 g OGTT < 7.0 mmol/L fasting and 7.8 to 11.0 mmol/L after 2 hours | NR | HbA1c Mean(SD) IG_DietgluM_: 5.3(0.83) IG_Diet_: 5.6(0.96) NS Fasting, mmol/L Median(range) IG_DietgluM_: 4.6(3.5–5.8) IG_Diet:_ 4.7(3.5–7.0) NS 2 hr glucose IG_DietgluM:_ 8.5(7.9–10.8) IG_Diet_: 8.9(7.8–11.0) p=0.025 | Median (range) IG_DietgluM_: 31(24–38) IG_Diet_: 32 (15–37) | NR | IG_DietgluM_: Standard dietary advice restricting carbohydrates to 185 g/day; diet sheet listing caloric values of common foods; glucose monitoring 1–2 hrs post meal 5×/week; glycosylated Hb monthly. Insulin introduced if ≥5 measurements > 7.0 mmol/L in 1 week. Care consisted of serial ultrasounds for growth, amniotic fluid levels and Doppler studies of umbilical artery. IG_Diet_: Dietary advice as above. Glycosylated Hb monthly with results not viewed within study period. If clinician became concerned, woman could be withdrawn at any time. | NA | Monthly glycosylated Hb measurements; serial ultrasound. | IG_DietgluM_: 6 (19%) IG_Diet_: 0 | NR | NR | NR | NR | Cesarean section N(%) IG_DietgluM_: 10(31) IG_Diet_: 11(31) | NR | None | NR | NR | None | None | IG_DietgluM_: 0 IG_Diet_: 1 | NR | NR | NR | Hypoglycemia N(%) IG_DietgluM_: 2(6) IG_Diet_: 6(17) NS (p=NR) | “special care baby unit” N(%) IG_DietgluM_: 2(6) IG_Diet_: 6(17) NS (p=NR) | kg, Mean(SD) IG_DietgluM_: 3.58(0.55) IG_Diet_: 3.62(0.55) NS (p=NR) | LGA N(%) IG_DietgluM_: 8(25) IG_Diet_: 7(19) Defined: >90th %ile for gestation | | | F/U on N=28 in each group Postnatal diabetes N(%) IG_DietgluM_: 0 IG_Diet:_ 2(7) Postnatal impaired glucose tolerance N(%) IG_DietgluM_: 2(7) IG_Diet_: 3(11) | | Fair
Jovanovic 1999^41^ | RCT | Women were diagnosed at 14–32 weeks and enrolled upon failure of dietary and exercise treatment. Followed until 6 weeks postpartum | California | To compare immunologic effects of insulin lispro with those of regular human insulin in patients with gestational diabetes. | Inclusion: Diagnosed at 14–32 weeks of gestation who failed to adequately control glucose with diet and exercise (defined as more than 70% of home glucose readings during one week did not meet the following criteria: fasting and preprandial <90mg/dl; 1 hr post-prandial <120 mg/dl). Ultrasound exam documented an anatomically normal fetus. Exclusion: Prior insulin treatment; had pregestational diabetes; demonstrated significant concurrent organic disease. | N= 42 IG_INSana_: 19 IG_INSreg_: 23 | Mean±SEM IG_INSana_: 31.5±1.1 IG_INSreg_: 33.3±1.2 NS | Caucasian, n IG_INSana_: 2 IG_INSreg_: 0 Hispanic, N IG_INSana_: 17 IG_INSreg_: 23 | Mean±SEM Parity IG_INSana_: 1.4±0.3 IG_INSreg_: 1.7±0.3 NS Gravidity IG_INSana_: 1.8±0.2 IG_INSreg_: 2.4±0.3 NS | Mean±SEM IG_INSana_: 34.2±1.3 IG_INSreg_: 29.8±1.0 p<0.01 | Diagnosed at 14–32 weeks of gestation who failed to adequately control glucose with diet and exercise (defined as more than 70% of home glucose readings during one week did not meet the following criteria: fasting and preprandial <90mg/dl; 1 hr post-prandial <120 mg/dl). Ultrasound exam documented an anatomically normal fetus. | NR | NR | At enrollment, Mean±SEM IG_INSana_: 27.3±1.4 IG_INSreg_: 25.6±1.3 NS | Previous GDM, N IG_INSana_: 1 IG_INSreg_: 1 | Patients were instructed to administer a recommended dosage of insulin lispro five minutes prior to three meals a day. Also received NPH insulin in the morning and evening. Self blood glucose monitoring at 0–30 minutes prior to meal and at 1 hour after the start of the meal. Test meal 20% of each woman's calculated caloric need. Insulin lispro injected 5 min, prior to test meal and plasma glucose, insulin, and c-peptide measured at 1, 2, and 3 hours after the meal. | Same as intervention group, but patients received regular human insulin instead of insulin lispro. For test meal, regular insulin injected 30 min prior to test meal. | Weekly visits to adjust insulin dosages, diet and exercise prescriptions. HbA_1C_ and insulin antibodies at week 6, delivery, and 6 weeks postpartum. Fetal well being monitored with ultrasounds and non-stress tests. | Per protocol | # of episodes at breakfast±SEM IG_INSana_: 0.65±0.13 IG_INSreg_: 0.93±1.04 p=0.025 | Area-under-the-curve with test meal Glucose IG_INSana_: 23.4 IG_INSreg_: 51.5 p=0.025 C-peptide IG_INSana_: 3.0 IG_INSreg_: 10.5 p<0.001 | NR | NR | Cesarean section, N(%) IG_INSana_: 7(36.8) IG_INSreg_: 6(27.3) NS | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | None | NR | grams, Mean±SEM IG_INSana_: 3098±202 IG_INSreg_: 3169±78 NS (p=NR) | None | | | NR | | Fair
Nachum 1999^43^ | RCT | NR | University-affiliated hospital, Israel Enrolled 9/93–12/97 | To compare perinatal outcome and glycemic control using two insulin regimens. | Inclusion: Singleton pregnancy in which insulin treatment initiated prior to 35 wks gestation. Diagnosed by 100-g OGTT with ≥2 serum glucose concentrations ≥5.9, 10.6, 9.2, 8.1 mmol/l at 0, 1, 2, and 3 hrs respectively. | N=274 IG_INS4X_: 138 IG_INS2X_ : 136 | IG_INS4X_: 27.9±2.6 IG_INS2X:_ 27.8±2.7 | Jewish/Non-Jewish IG_INS4X_: 78/60 IG_INS2X_: 75/61 | IG_INS4X_: 3.5±1.7 IG_INS2X_: 3.4±1.8 | IG_INS4X_: 33±5 IG_INS2X_: 33±5 | Diagnosed by 100-g OGTT with ≥2 serum glucose concentrations ≥5.9, 10.6, 9.2, 8.1 mmol/l at 0, 1, 2, and 3 hrs respectively (NDDG criteria). | NR | NR | [underlined: At diagnosis] IG_INS4X_: 25.9±7.1 IG_INS2X_: 26.3±7.2 [underlined: Initiated treatment] IG_INS4X_: 27.4±6.8 IG_INS2X_: 28.0±6.9 | NR | IG_INS4X_: Received four doses of insulin daily. Three doses containing regular insulin were given 30 min prior to meal. The fourth dose containing intermediate insulin was given before bedtime. Dietary recommendations included: 0.13–0.15 Mj/kg ideal body weight; 3 meals and 3 snacks daily; 55% carbohydrate, 20% protein, 25% fat; increased complex and decreased refined carbohydrates. | CG_INS2X_: A morning dose containing 2/3 of the total daily insulin and afternoon dose contained 1/3 total daily insulin. Morning dose comprised 1/3 regular insulin and 2/3 intermediate insulin. The afternoon dose comprised equal amounts of regular and intermediate insulin. Dietary recommendations same as IG_INS4X_. | F/U telephone calls as needed. Home glucose monitoring and hemoglobin A_1C_ monthly. | 100% both groups by design | Severe N(%) IG_INS4X_:1(0.7) IG_INS2X_: 1(0.7) Diff (95%CI):0 Defined: Severe enough to independently take oral glucose and requiring help from another person, | Adequate* N(%) IG_INS4X_: 126(91) IG_INS2X_: 101(74) Diff (95%CI): 17(18 to 26) *Defined: mean capillary glucose < 5.8 mmol/L Hb_A1C_ (%) IG_INS4X_: 5.5 (1.0) IG_INS2X_: 5.8 (1.0) Diff (95%CI): -0.3(-0.2 to -0.4) | NR | Weight gain, kg IG_INS4X_: 11.4±3.5 IG_INS2X_: 10.7±3.6 Diff (95%CI): -0.7(-1.5 to 0.1) | Cesarean N(%) IG_INS4X_: 39(28) IG_INS2X_: 38(28) Diff (95%CI):0 | N(%) IG_INS4X_: 11(8) IG_INS2X_: 12(9) Diff (95%CI): -1 (-11 to 9) Defined: NR | NR | NR | NR | NR | Perinatal Mortality, N(%) IG_INS4X_: 0 IG_INS2X_: 1(0.7) NS | NR | NR | NR | N(%) IG_INS4X_: 15(11) IG_INS2X_: 29(21) p=0.02 RR: 0.51(0.29 to 0.91) Defined: > 205 mmol/L at ≥34 weeks or >137 mmol/L at < 34 weeks | N(%) Hypoglycemia IG_INS4X_: 1(0.7) IG_INS2X_: 8(5.9) p=0.02 RR: 0.12(0.02 to 0.97) Defined:<1.9 mmol/L in term infants and <1.4 mmol/L in preterm infants ≥ 2 occasions. Hypocalcemia IG_INS4X_: 1(0.7) IG_INS2X_: 0 NS Defined: < 2.0 mmol/L | NR | g (SD) IG_INS4X_: 3437(587) IG_INS2X_: 3436(672) NS | N(%) LGA, ≥90th %ile IG_INS4X_: 36(26) IG_INS2X_: 41(30) NS Macrosomia, ≥4000g IG_INS4X_: 22(16) IG_INS2X_: 26(19) NS | N(%) Anomalies IG_INS4X_: 1(0.7) IG_INS2X_: 2(1.5) NS Overall neonatal morbidity IG_INS4X_: 24(17) IG_INS2X_: 40(29) RR 0.59(0.38 to 0.92) | | NR | | Fair
de Veciana 1995^40^ | RCT | NR | Medical center in California. | Comparing the efficacy of of postprandial and preprandial monitoring in achieving glycemic control in women with gestational diabetes. Perinatal outcomes | Inclusion: Diagnosed with gestational diabetes requiring insulin at or before 30 weeks gestation; singleton pregnancy; 50 g GCT > 140 mg/dL but < 190 mg/dL, then 3 hr OGTT by NDDG criteria. Exclusion: History of diabetes prior to pregnancy; pre-existing hypertension, renal disease, or autoimmune disorders. | N=66 IG_pre_: 33 IG_post_: 33 | IG_pre_: 29.0±3.2 IG_post_: 28.4±3.8 NS (p=NR) | IG_pre_, N Hispanic: 27 White: 4 Black/Asian: 2 IG_post_, N Hispanic: 29 White: 3 Black/Asian: 1 NS (p=NR) | IG_pre_: 4.3±3.0 IG_post_: 3.6±2.2 NS (p=NR) | IG_pre_: 31±6 IG_post_: 29±5 NS (p=NR) | Women with RF (>120% ideal body weight, ≥35 yrs, glycosuria on dipstick urinalysis (≥2+), history of diabetes in first-degree relative, previous unexplained stillbirth or miscarriage) were screened at initial prenatal visit. All others were screened between 24–28 weeks. Step 1: One-hour 50-g GCT > 140 mg/dL, but <190 mg/dL; those >190 mg/dL started insulin immediately. Step 2: 3-hour 100-g OGTT with ≥ 2 abnormal glucose values (fasting > 105 mg/dL, 1 hr > 190 mg/dL, 2 hrs > 165 mg/dL, 3 hrs > 145 mg/dL). Those with elevated fasting initiated insulin immediately, others were managed with diet until fasting >105 mg/dL or postprandial (1hr) >140 mg/dL. | Fasting | 50-g OCT, 1 hr IG_pre_: 216±56 IG_post_: 214±67 NS (p=NR) Fasting at 100-g OGTT IG_pre_: 137±38 IG_post_: 145±50 NS (p=NR) | At diagnosis IG_pre_: 22.9±7.5 IG_post_: 21.8±6.5 NS (p=NR) Initiated insulin IG_pre_: 24.3±5.2 IG_post_: 25.1±5.1 NS (p=NR) | NR | IG_pre_-Preprandial Monitoring: Required daily monitoring of fasting, preprandial and bedtime blood glucose levels. Diet: 30–35 kcal/kg of ideal body weight divided into 3 meals and 1–3 snacks; 40–45% carbohydrate; intake adjusted according to weight and blood glucose levels. Received split-dose insulin (Regular/NPH) | IG_post_-Postprandial Monitoring: Required daily monitoring of blood glucose levels before breakfast and one hour after each meal. Diet: Same as IG_pre_ Insulin: Same as IG_pre_ | Evaluated weekly by perinatal-diabetes team (OB, dietician, nurse educator, counselor) unless complications required more frequent visits. | NR | NR | Successful management, % IG_pre_: 86±4.1 IG_post_: 88±5.2 NS Insulin dose units/day IG_pre_: 76.8±21.4 IG_post_: 100.4±29.5 p=0.003 Final glycosylated Hb% IG_pre_: 8.1±2.2 IG_post_: 6.5±1.4 p=0.006 Change in glycosylated Hb% IG_pre_: -0.6±1.6 IG_post_: -3.0±2.2 p<0.001 | IG_pre_: 8(24) IG_post_: 3(9) p=0.16 RR 2.7(0.8 to 9.4) Defined: 3rd or 4th degree lacerations | Gain, kg IG_pre_: 10.7±5.4 IG_post_: 10.5±5.4 NS | Cesarean, N(%) IG_pre_: 13(39) IG_post_: 8(24) p=0.29 RR1.6 (0.8 to 3.4) For CPD IG_pre_: 12(36) IG_post_: 4(12) p=0.04 RR 3.0 (1.1 to 8.3) | N (%) IG_pre_: 2(6) IG_post_: 2(6) NS Defined: NR | NR | NR | NR | N (%) IG_pre_: 1(3) IG_post_: 0 NS | NR | N (%) IG_pre_: 6(18) IG_post_: 1(3) p=0.10 RR 6.0 (0.8 to 47.1) Defined: ≥1 maneuvers required to facilitate vaginal delivery | NR | Transient tachypnea IG_pre_: 2(6) IG_post_: 2(6) NS | N (%) IG_pre_: 4(12) IG_post_: 3(9) NS Defined: serum bilirubin >10 mg/dL if full-term or >15 mg/dL if delivered prior to 37 weeks | Hypoglycemia, N(%) IG_pre_: 7(21) IG_post_: 1(3) p=0.05 RR 7.0 (0.9 to 53.8) Defined: ≤30 mg/dL | NR | grams IG_pre_: 3848±434 IG_post_: 3469±668 p=0.01 | LGA, N(%) IG_pre_: 14(42) IG_post_: 4(12) p=0.01 RR 3.5 (1.3 to 9.5) Defined: ≥ 90%ile for California population Macrosomia IG_pre_: 12(36) IG_post_: 3(9) p=0.01 RR 4.1 (1.3–13.2) Defined: ≥4000g | NR | | NR | | Fair
Bartha, 2000^45^ | Prospective cohort study, comparison groups are women with early and late GDM diagnosis | March 1996–March 1998 | Puerto Real, Spain | Gestational hypertension, pre-eclampsia, polyhydramnios, PTL, fetal anomalies, oligohydramnios, gylcemic control, delivery mode, 1&5 min Apgars, SGA, macrosomia, hypolgycemia (fetal), perinatal death | Inclusion: 3986 women who presented consecutive-ly to the antenatal clinic in the University Hospital of Puerto Real, Spain Exclusion: delivery data not available | 3968 screened, 183 of 235 GDM patients included in analyses, data unavailable for 52 of the 235 since they delivered outside the university hospital (retention rate 77%) | Pregestational BMI E: 29.1 (6.9) L: 25.3 (3.8) p=0.00006 Gestational BMI E: 31.8 (6.5) L: 29.0 (3.8) p=0.001 | NR | Nulliparous E: 36 (55.4%) L: 94 (55.3%) p=NS | E: 33.6 (5.4) L: 32.6 (5.3) p=NS | Two-step: 50 g GCT (cut off >=140), 100 g GTT (NDDG) | None | 235/3968 (5.9%) diagnosed with GDM, 65 diagnosed early (first screen), 170 diagnosed late (24–28 weeks) | 50 g GCT at first antenatal visit, GTT if positive, repeated at 24–28 wks if negative. Mean (SD) gestational age (weeks) at hospitalization: E: 18.1 (6.5) L: 33.1 (3.9) p<0.000001 | NR | NA | NA | Women were hospitalized after diagnosis to assess glycemic profile, diet therapy if preprandial glc <105 mg/CL and 2 hour postprandial glc <120 mg/CL, otherwise insulin begun; fetal growth, glycemic control and test of fetal well-being monitored (visits at 16, 20, 24, 32, 34, 36, 38, 40 wks gestation) | E: 22 (33.9%) L: 12 (7.1%) p<0.00001 | NR | Fasting E: 91 (16) L: 80 (14) p<0.00001 2hr pp breakfast E: 105 (29) L: 96 (21) p=0.03 2hr pp lunch E: 103 (19) L: 92 (16) p=0.00009 2hr pp dinner E: 103 (26) L: 94 (17) p=0.01 mean glycemic profile E: 97 (15) L: 88 (10) p=0.00002 | NR | Total weight gain: E: 7 (4) L: 10 (4) p<0.000001 | Induction NR Vaginal E: 38 (76%) L:107 (81%) p=NS CS fetal distress E: 1 (8%) L: 2 (8%) p=NS CS CPD E: 4 (33%) L: 12 (46%) p=NS CS failed induction E: 1 (8%) L: 1 (4%) p=NS | (not defined) Gestational hypertension E: 1 (2%) L: 5 (3%) p=NS Pre-eclampsia E: 2 (3%) L: 0 (0%) p=0.07 Chronic htn E: 7 (11%) L: 4 (2%) p=0.01 Superimposed pre-eclampsia E: 2 (3%) L: 1 (1%) p=NS Hypertension (total) E: 12 (19%) L: 10 (6%) p=0.006 | none reported | NR | NR | Perinatal death E: 3 (6%) I: 0 (0%) p=0.02 One stillbirth at 24 weeks gestation occurred to a woman with a prior fetal loss. The second stillbirth at 35 weeks was toa women with chronic hypertension who used lithium for cyclic psychosis. The third case was a stillbirth at 38 weeks gestation. No fetal anomalies noted in any of the stillborn fetuses. The first two of the above three patients received insulin. | None | NR | NR | NR | NR | Hypoglycemia (not defined) E: 4 (8%) L: 0 (0%) p=0.005 | Special care unit admission (reason not specified) E: 5 (10%) L: 14 (11%) p=NS | E: 3420 +/- 643 g I: 3281 +/- 581 g p=NS | Macrosomia (>4000g) E: 7 (14%) L: 11 (8.3%) p=NS | The E and L groups did not differ significantly in proportion of twin gestations, previous spontaneous abortion, previous cesarean delivery nor in proportion of hydramnios, preterm labor, fetal anomalies, vaginal births, preterm births, 5-min Apgar < 7, 1 min Apgar < 6, small for gestational age, meconium passage, or low birth weight (2500g) or in gestational age at delivery. They differed in diagnosis of oligohydramnios: E= 0, I=11 (6.5%), p=0.02. | None | NR | | Fair

RCT-randomized controlled trial; GDM-gestational diabetes mellitus; OGTT-oral glucose tolerance test; IG-intervention group; CG-control group; NR-not reported; BMI-Body mass index; GCT-glucose challenge test; RF-risk factors; CHO-carbohydrate; OB-obstetrical; abnl-abnormal; pp-postprandial; SD-standard deviation; LGA-large for gestational age.

Table 2 Trials Addressing Harms of Screening — Key Question 4

Author/Year | Type of trial | Length of trial | Study Setting | Primary Study Objectives/Outcomes | Inclusion/ Exclusion Criteria | N, Subjects | BMI | Race/Ethnicity | Parity | Age | Screening Test/Mode of Diagnosis | Screening test results | Gestational age at screening | Instruments | Anxiety | Depression (EPDS = 12) | SF-36 health status by domain | | | SF-36 Health Rating | Maternal Health perception | Other | Experience of screening | Quality rating
Rumbold, 2002^49^ | Prospective cohort, survey study | NR | Women's and Children's Hospital, Adelaide, Australia | To survey women about their experiences of being screened for GDM and effect of screening on QOL | Inclusion: Any English-speaking women, aged 18 or older, attending the hopsital for antenatal care. Exclusion: Pre-existing diabetes | N=209, 158 enrolled prescreening, 51 women with positive GCT enrolled after screening | Mean, SD GCT neg: 27 (5) GCT pos, OGTT neg: 29 (6) GDM: 30 (7) p=NS | N (%) GCT neg: Caucasian 141 (94) Asian 3(2) Aboriginal 0 Other 6 (4) GCT pos, OGTT neg: Caucasian 29 (78) Asian 5(14) Aboriginal 0 Other 3 (8) GDM: Caucasian 20 (80) Asian 3(12) Aboriginal 1(4) Other 1 (4) p=NS | N (%) GCT neg: 0: 69 (46) 1 to 3: 79 (53) ≥4: 2(1) GCT pos, OGTT neg: 0: 19 (51) 1 to 3: 18 (49) >4: 0(0) GDM: 0: 10 (40) 1 to 3: 14 (56) >4: 1(4) p=NS | Mean (SD) GCT neg: 28 (5) GCT pos, OGTT neg: 30(4) GDM/GIP: 30(4) p<0.05 for GCT neg vs GCT pos/OGTT neg p<0.001 for GCT neg vs. GDM | Hospital protocol: 50 g GCT at 24–28 wks, 75 g GTT if screen positive, used 1985 WHO criteria for GDM and glucose intolerance of pregnancy | Of 158 women enrolled prescreening, data available for 135. GCT neg: 124/135 GCT pos: 11/135 GTT pos: 7/11 (64%) 7/135 (5%) Of 51 women enrolled after GCT pos: OGTT pos: 18/51 (35%) | 24–28 weeks | Spielberger State-Trait Anxiety Inventory; Edinburgh postnatal depression scale; SF-36; mother's perception of health and concern felt for health of newborn; adequacy of info given about test results; overall experience of being screened. Instruments were administered before screening, after screening, and late in pregnancy (at approx 36 wks) | Mean (SD) [underlined: Before screening] 10 (3) [underlined: After screening] GCT neg: 11(3) GCT pos: 11 (4) p=NS [underlined: Late in pregnancy] (approx 36 wks) GCT neg: 11(4) GCT pos, OGTT neg: 12 (4) GDM/GIP: 11 (4) p=NS | N (%) [underlined: Before screening] 33 (21) [underlined: After screening] GCT neg: 21(17) GCT pos: 11 (18) p=NS [underlined: Late in pregnancy] (approx 36 wks) GCT neg: 17 (18) GCT pos, OGTT neg: 6 (21) GDM/GIP: 4 (19) p=NS | Mean (SD) Social functioning [underlined: After screening] GCT neg: 76(19) GCT pos: 76 (20) p=NS [underlined: Late in pregnancy] (approx 36 wks) GCT neg: 75(21) GCT pos, OGTT neg: 66 (25) GDM/GIP: 69 (21) p<0.05 for neg GCT vs. pos GCT, neg OGTT | Vitality [underlined: After screening] GCT neg: 48 (19) GCT pos: 53 (17) p<0.05 [underlined: Late in pregnancy] (approx 36 wks) GCT neg: 47 (19) GCT pos, OGTT neg: 49 (16) GDM/GIP: 56 (17) p<0.05 for GCT neg vs. GDM/GIP | General Health Perceptions [underlined: After screening] GCT neg: 76 (17) GCT pos: 70 (18) p<0.05 [underlined: Late in pregnancy] (approx 36 wks) GCT neg: 75(21) GCT pos, OGTT neg: 69(18) GDM/GIP: 71(13) p=NS | Change in health compared to 1 yr ago After screening, GCT neg women were more likely than GCT pos women to say their health was much better than 1 year ago. N (%) GCT neg: 14 (11) GCT pos: 1 (2) p<0.05 No differences between groups late in pregnancy. | N (%) [underlined: After screening] GCT neg: Excellent 21 (17) Very good 8(63) *Fair 23 (19) Poor 1 (1) GCT pos: Excellent 8 (13) Very good 30 (48) *Fair 23 (37) Poor 1(2) *p≤ 0.01 [underlined: Late in pregnancy] GCT neg vs.GCT false pos vs. GDM/GIP. p=NS No differences in concern for baby's health at either assessment. | Request screening in future pregnancy- GCT neg: Yes 65 (52) No 20(16) Unsure 15 (12) GCT pos: Yes 32 (52) No 14 (23) Unsure 16 (26) p=NS GCT pos, OGTT neg: Yes 18 (62) No 5 (17) Unsure 5 (17) GDM/GIP: Yes 7(33) No 6 (29) Unsure 7 (33) p=NS | N (%) GCT neg: pos 96 (72)* neg 6(5) unsure 19(15)* GCT pos: pos 35 (57) neg 2(3) unsure 25 (40) *p<0.01 GCT pos, OGTT neg: pos 17 (59) neg 1(4) unsure 9 (31) GDM/GIP pos 11 (52) neg 3 (19) unsure 6 (29) p=NS | Fair
Spirito, 1989^50^ | Cross-sectional study | NR | Women and Infants Hospital of Rhode Island | Evaluate psychological impact of diagnosis of GDM, examine relationship between psychological status and metabolic control in GDM | Inclusion: English-speaking women with GDM referred to Woman and Infants hospital Exclusion: None noted | N=108 GDM: 68 Controls: 50 | NR | % GDM: White 87 Non-white 13 Controls: White 90 Non-white 10 p=NS | NR | Mean (SD)GDM: 28.5 (5.4)Controls: 27.3 (4.7) p=NS | 3 hr GTT C&C criteria | NA | 28 weeks | Profile of Mood States-Bipolar Form Mean (SD) Gestational age at administration GDM 35.5 (2.5) Controls 35.0 (4.0) p=NS | NA | NA | NA | | | NA | NA | NA | NA | Profile of Mood States Bipolar Form subscales. No significant differences between women with and without GDM. Results from this form were not predictive of blood glucose parameters.
Daniells, 2003^51^ | Prospective cohort, survey study | One year (Nov 2000–Nov 2001) | Wollongong, Australia | Examine anxiety levels at the beginning of the 3rd trimester, 36 wks, and 6 wks postpartum in women diagnosed with GDM compared to controls | Inclusion: Able to read and write English, singleton pregnancy, no previous history of GDM, tested after 26 wks gestation, seen in clinic within 1 wk of diagnosis and before 32 wks gestation | N=100 GDM: 50 Controls: 50 | Mean (SD) GDM: 27.4 (7.2) Controls: 24.6 (3.8) p=0.02 | Percent Australian born GDM: 66 Control: 86 p=0.02 | Mean (SD) GDM: 0.9 (1.1) Controls: 0.7 (1.2) p=NS | Mean (SD) GDM: 31.4 (5.0) Controls: 29.0 (4.8) p=0.02 | 2 hr 75 g GTT given in a fasting state, GDM diagnosed if fasting glucose ≥ 5.5 mmol/l (99mg%) and/or 2 hr glucose ≥ 8.0 mmol/l (144 mg%) | NA | 26+ Mean (SD) GDM: 28.4 (1.8) Control: 28.2 (0.6) p=NS | Mental Health Inventory-5 (MHI-5), Speilberger State-Trait anxiety Inventory (STAI), six questions regarding attiitudes towards testing rated on Likert scale | State anxiety (STAI) Mean (SD) GDM: Week 30 – 40.6 (13.3) Control: Week 30 – 34.2 (9.9) p=0.007 Women with GDM had higher state ofanxiety at week 30. No significant difference at weeks 36 and 6 wks postpartum. No differences in trait anxiety at 30 or 36 wks or postpartum. | NA | NA | | | Profile of Mood States Bipolar Form subscales. No significant differences between women with and without GDM. Results from this form were not predictive of blood glucose parameters. | NA | Fair | NA | Profile of Mood States Bipolar Form subscales. No significant differences between women with and without GDM. Results from this form were not predictive of blood glucose parameters.

EPDS-Edinburgh Postnatal Depression Scale; QOL-quality of life; GDM-gestational diabetes mellitus; DM-diabetes mellitus; SD-standard deviation; GCT-glucose tolerance test; neg-negative screen; pos-positive screen; OGTT-oral glucose tolerance test; GIP-glucose intolerance of pregnancy; GTT-glucose tolerance test; WHO-World Health Organization; NS-not significant; -appro-approximate; NR-not reported; C&C-Carpenter and Coustan criteria.

Table 3 Trials of Adverse Effects of Treatment for Gestational Diabetes Mellitus - Key Question 5

Study USPSTF Quality | Type of trial | Length of trial | Study Setting | Primary Study Objectives/Outcomes | Inclusion/ Exclusion Criteria | N, Subjects | Weight | Race/Ethnicity | Gravidity/Parity | Age | Screening Test/Mode of Diagnosis (1 or more steps) | Test preparation | Screening test results | Gestational age at diagnosis | Previous macrosomic infant | Previous fetal death | Gestational Age at Delivery | Intervention | Control | Depression/Anxiety
Study unique to KQ5
Langer, 1994^56^ Fair | Cohort | NR | Urban residents, low SES, attending maternal health clinics in San Antonio, TX | To determine the effect of intensified treatment on emotional status of women who are newly diagnosed with gestational diabetes mellitus. | Inclusion: English-speaking patients newly diagnosed with gestational diabetes mellitus. | N=301 IG_Diet_: 69 IG_INS_: 137 CG: 95 | % IG_Diet_: Obese 20.3 Non-obese 79.7 IG_INS_: Obese 50.4 Non-obese 49.6 CG: Obese 26.3 Non-obese 73.7 p<0.0003 Diet and control vs. insulin | %IG_Diet_: White 23.2 Hispanic 75.4 Black 1.4 IG_INS_: White 20.4 Hispanic 76.6 Black 2.9 CG: White 13.5 Hispanic 81.2 Black 5.3 NS | Parity, % IG_Diet_: Primipara 37.7 Multipara 62.3 IG_INS_: Primipara 24.8 Multipara 75.2 CG: Primipara 34.8 Multipara 65.2 NS | IG_Diet_: 29±6.7 IG_INS_: 29.5±6.1 CG: 24.6±6 CG vs IG_Diet_ & IG_INS_, p<0.001 | Diagnosed using the National Diabetes Data Group glucose threshold. One or more elevated values were considered abnormal. | NR | NR | wk, mean±SD IG_Diet_: 28.0±5.3 IG_INS_: 27.0±7.7 NS | % IG_Diet_: 28.9 IG_INS_: 32.1 CG: 5.3 p<0.001 CG vs. diet and insulin | % IG_Diet_: 8.7 IG_INS_: 7.2 CG: 2.1 NS | wks, mean±SD IG_Diet_: 39.4±1.9 IG_INS_: 39.0±2.0 CG: 39.0±3 NS | Women who are newly diagnosed with gestational diabetes. Women were first directed to try to achieve blood glucose control through diet if: Fasting <95 mg/dL; 2 hr postprandial <120mg/dL; mean glucose <100mg/dL. If diet did not control glucose levels, women were assigned to the insulin control group. They were instructed to take 3 injections/day of regular and intermediate insulin. Subjects were monitored through weekly clinic visits. Profile of Mood States-Bipolar Form administered at 37–38 weeks gestation. | Non-diabetic controls who were high-risk subjects recruited from the same maternal health clinics. Profile of Mood States-Bipolar Form administered 37–38 weeks gestation. | Mean±SD Composed-Anxious IG_Diet_: 47±9.25 IG_INS_: 46.7±9.5 CG: 47.2±7.6 Agreeable-Hostile IG_Diet_: 41.7±8.3 IG_INS_: 42.0±9.0 CG: 40.3±8.9 Elated-Depressed IG_Diet_: 45.1±7.5 IG_INS_: 45.5±8.3 CG: 43.9±9.0 Confident-Unsure IG_Diet_: 45.6±8.2 IG_INS_: 47.9±7.1 CG: 48.3±8.0 Energetic-Tired IG_Diet_: 46.9±6.6 IG_INS_: 47.8±6.7 CG: 45.8±6.7 Clearheaded-Confused IG_Diet_: 46.0±10 IG_INS_: 48.0±9.4 CG: 48.7±9.6 No significant differences
Treatment vs. no treatment
Crowther 2005^39^ ACHOIS Good | RCT | Screened 16–30 weeks f/u 3 mos. Post-partum | 18 centers: 14 Australia; 4 UK Initiated prior to change in WHO criteria Recruitment 9/93–6/03 | To assess whether treatment of GDM reduces perinatal complications; or has an effect on maternal outcomes; mood; or quality-of-life | Inclusion: Singleton or twin pregnancy 16–30 weeks gestation; RF for GDM or 50-g GCT (≥7.8 mmol/l) AND 75-g OGTT (24–34 weeks gestation) 2-hr plasma glucose 7.8–11.0 mmol/l with fasting plasma glucose <7.8 mmol/l Exclusion: Previously treated GDM; active chronic disease (except essential hypertension) | N=1,000 IG: 490 CG: 510 | Body Mass Index* Median (Interquartile Range) IG: 26.8 (23.3–31.2) CG: 26.0 (22.9–30.9) *weight in kilograms divided by the square of the height in meters. | IG: 73% White 19% Asian 9% Other CG: 78% White 14% Asian 8% Other | Primiparous N (%) IG: 212 (43%) CG: 251 (49%) | Mean (SD) IG: 30.9 (5.4) CG: 30.1(5.5) | Two steps Step 1: RF or 50-g GCT (≥7.8 mmol/l) 1-hr cut-off (93% were positive with 50-g) Step 2: 75 g OGTT | 50-g GCT NR 75 g OGTT 48 hr normal diet; 8 hr overnight fast | Median (Interquartile range) [underlined: GCT, mmol/l] IG: 8.8 (8.2–9.7) CG: C: 8.8 (8.3–9.7) [underlined: 75-g OGTT, mmol/l] IG: 8.6 (8.1–9.3) CG: 8.5 (8.1–9.1) | At entry Median (Interquartile range) IG: 29.1 weeks (28.2–30.0) CG: 29.2 weeks (28.2–30.0) | NR | Previous pregnancy ending in perinatal death IG: 12/278 (4%) CG: 7/259 (3%) | Median weeks (Interquartile Range) IG: 39.0 (38.1–40.0) CG: 39.3 (38.3–40.4) | IG: Replicated clinical care in which universal screening and treatment for GDM are available Received a slip indicating a diagnosis of glucose intolerance and the plan for intervention Intervention was individualized dietary advice from dietician; instructions to self-monitor glucose QID until within specified range for 2 weeks; insulin initiated if not in range and titrated to glucose range | CG: Replicated clinical care in which screening for GDM was not available Received a slip indicating they did not have gestational diabetes A proportion (not fewer than one in 5) had normal OGTT results assigned to routine care to help maintain blinding Glucose monitoring and insulin initiated at the discretion of the attending clinician | Depression Adj RR 0.46 (0.29–0.73) p=0.001 Defined as: Likely depressed (EPDS score >12) at 3 months post-partum Anxiety score Adj mean diff -0.3 (-0.9–0.4; p=0.41)
Treatment comparison
Langer 2000^42^ Good | RCT | Screened 11–33 weeks F/U to postpartum | Inner-city maternal health clinics in San Antonio, TX | To assess whether glyburide is an effective alternative to insulin for control of hyperglycemia during pregnancy; glycemic control; maternal and neonatal complications. | Inclusion: Singleton pregnancy 11–33 weeks; 50-g GCT > 130 mg/dL at 1 hr. AND 100-g OGTT with ≥ 2 abnormal glucose values by C&C criteria. Those with fasting plasma glucose <95 mg/dL were initially treated with diet and enrolled if levels increased to ≥95 mg/dL or postprandial levels were ≥ 120 mg/dL. Exclusion: NR | N=404 IG_GLY_: 201 IG_INS_: 203 | | 83% Hispanic 12% White 5% Black | Nulliparity N (%) IG_GLY_: 56 (28) IG_INS_: 59 (29) | yrs, Mean±SD IG_GLY_: 29±7 IG_INS_: 30±6 | Step 1: 50-g GCT > 130 mg/dL Step 2: 100-g OGTT with ≥ 2 abnormal glucose values by C&C criteria. | Fasting for OGTT | Screening plasma glucose mg/dL,mean±SD IG_GLY_: 169±28 IG_INS_: 169±31 OGTT mg/dL,mean±SD [underlined: Fasting] IG_GLY_: 97±14 IG_INS_: 98±16 [underlined: 1 hr] IG_GLY_: 197±31 IG_INS_: 201±30 [underlined: 2 hr] IG_GLY_: 174±31 IG_INS_: 174±29 [underlined: 3 hr] IG_GLY_: 140±37 IG_INS_: 134±37 | wks, mean±SD IG_GLY_: 24±7 IG_INS_: 25±7 | Previous GDM N(%) IG_GLY_: 24(12) IG_INS_: 22(11) Previous macrosomic infant N(%) IG_GLY_: 36(18) IG_INS_: 45(22) | NR | weeks, mean ± SD IG_INS_: 38.5+ 2.1 IG_GLY_:38.7+ 1.6 | IG_GLY_: Initial oral dose of 2.5 mg of glyburide in the morning, when indicated the dose increased the following week by 2.5 mg and thereafter by 5 mg up to a total of 20mg. All women were provided standard nutritional instruction for three meals and four snacks daily. | IG_INS_: Initial insulin dose of 0.7 unit/kg of body weight at admission given subcutaneously 3 times daily and increased weekly as necessary. All women were provided standard nutritional instruction for three meals and four snacks daily. | NR
Jovanovic 1999^41^ Fair | RCT | Women were diagnosed at 14–32 weeks and enrolled upon failure of dietary and exercise treatment. Followed until 6 weeks postpartum | California | To compare immunologic effects of insulin lispro with those of regular human insulin in patients with gestational diabetes. | Inclusion: Diagnosed at 14–32 weeks of gestation who failed to adequately control glucose with diet and exercise (defined as more than 70% of home glucose readings during one week did not meet the following criteria: fasting and preprandial <90mg/dl; 1 hr post-prandial <120 mg/dl). Ultrasound exam documented an anatomically normal fetus. Exclusion: Prior insulin treatment; had pregestational diabetes; demonstrated significant concurrent organic disease. | N= 42 IG_INSana_: 19 IG_INSreg_: 23 | IG_INSana_: 76.3kg ± 2.9 IG_INSreg_: 78.5kg ± 2.5 NS | Caucasian, n IG_INSana_: 2 IG_INSreg_: 0 Hispanic, N IG_INSana_: 17 IG_INSreg_: 23 | Mean±SEM Parity IG_INSana_: 1.4±0.3 IG_INSreg_: 1.7±0.3 NS Gravidity IG_INSana_: 1.8±0.2 IG_INSreg_: 2.4±0.3 NS | Mean±SEM IG_INSana_: 34.2±1.3 IG_INSreg_: 29.8±1.0 p<0.01 | Diagnosed at 14–32 weeks of gestation who failed to adequately control glucose with diet and exercise (defined as more than 70% of home glucose readings during one week did not meet the following criteria: fasting and preprandial <90mg/dl; 1 hr post-prandial <120 mg/dl). Ultrasound exam documented an anatomically normal fetus. | NR | NR | At enrollment, Mean±SEM IG_INSana_: 27.3±1.4 IG_INSreg_: 25.6±1.3 NS | Previous GDM, N IG_INSana_: 1 IG_INSreg_: 1 | NR | Weeks IG_INSana_: 38.8±0.3 IG_INSreg_: 38.8±0.2 | Patients were instructed to administer a recommended dosage of insulin lispro five minutes prior to three meals a day. Also received NPH insulin in the morning and evening. Self blood glucose monitoring at 0–30 minutes prior to meal and at 1 hour after the start of the meal. Test meal 20% of each woman's calculated caloric need. Insulin lispro injected 5 min, prior to test meal and plasma glucose, insulin, and c-peptide measured at 1, 2, and 3 hours after the meal. | Same as intervention group, but patients received regular human insulin instead of insulin lispro. For test meal, regular insulin injected 30 min prior to test meal. | NR
Bancroft 2000^38^ Fair | RCT | | 2 specialist diabetes clinics in the UK. | To determine whether less intensive monitoring of blood glucose levels during pregnancy is feasible. Frequency of admission to specialty care baby unit; perinatal morbidity; maternal inconvenience. | Inclusion: Blood glucose levels-Fasting < 7.0 mmol/L and between 7.8–11.0 mmol/L 2 hrs after 75 g OGTT. Exclusion: NR | N=68 IG_DietgluM_: 32 IG_Diet_: 36 | | N(%) IG_DietgluM_: Asian 10(31) Caucasian 22(69) IG_Diet_: Asian 11(31) Caucasian 25(69) | Parity Median (range) IG_DietgluM_: 2(0–6) IG_Diet_: 1(0–9) | At delivery Mean(SD) IG_DietgluM_: 29.7(6.23) IG_Diet_: 31.9(5.17) | One step: 75 g OGTT < 7.0 mmol/L fasting and 7.8 to 11.0 mmol/L after 2 hours | NR | HbA1c Mean(SD) IG_DietgluM_: 5.3(0.83) IG_Diet_: 5.6(0.96) NS Fasting, mmol/L Median(range) IG_DietgluM_: 4.6(3.5–5.8) IG_Diet:_ 4.7(3.5–7.0) NS 2 hr glucose IG_DietgluM:_ 8.5(7.9–10.8) IG_Diet_: 8.9(7.8–11.0) p=0.025 | At entry Median (range) IG_DietgluM_: 31(24–38) IG_Diet_: 32 (15–37) | NR | | | IG_DietgluM_: Standard dietary advice restricting carbohydrates to 185 g/day; diet sheet listing caloric values of common foods; glucose monitoring 1–2 hrs post meal 5×/week; glycosylated Hb monthly. Insulin introduced if ≥5 measurements > 7.0 mmol/L in 1 week. Care consisted of serial ultrasounds for growth, amniotic fluid levels and Doppler studies of umbilical artery. IG_Diet_: Dietary advice as above. Glycosylated Hb monthly with results not viewed within study period. If clinician became concerned, woman could be withdrawn at any time. | NA | NR
Nachum 1999^43^ Fair | RCT | NR | University-affiliated hospital, Israel Enrolled 9/93–12/97 | To compare perinatal outcome and glycemic control using two insulin regimens. | Inclusion: Singleton pregnancy in which insulin treatment initiated prior to 35 wks gestation. Diagnosed by 100-g OGTT with ≥2 serum glucose concentrations ≥5.9, 10.6, 9.2, 8.1 mmol/l at 0, 1, 2, and 3 hrs respectively. | N=274 IG_INS4X_: 138 IG_INS2X_: 136 | kg(SD) IG_INS4X_ : 73(15) IG_INS2X_ : 72(15) | Jewish/Non-Jewish IG_INS4X_: 78/60 IG_INS2X_: 75/61 | IG_INS4X_: 3.5±1.7 IG_INS2X_: 3.4±1.8 | IG_INS4X_: 33±5 IG_INS2X_: 33±5 | Diagnosed by 100-g OGTT with ≥2 serum glucose concentrations ≥5.9, 10.6, 9.2, 8.1 mmol/l at 0, 1, 2, and 3 hrs respectively (NDDG criteria). | NR | NR | [underlined: At diagnosis] IG_INS4X_: 25.9±7.1 IG_INS2X_: 26.3±7.2 [underlined: Initiated treatment] IG_INS4X_: 27.4±6.8 IG_INS2X_: 28.0±6.9 | NR | NR | Weeks(SD) IG_INS4X_: 38.9(1.6) IG_INS2X_: 38.6(1.9) | IG_INS4X_: Received four doses of insulin daily. Three doses containing regular insulin were given 30 min prior to meal. The fourth dose containing intermediate insulin was given before bedtime. Dietary recommendations included: 0.13–0.15 Mj/kg ideal body weight; 3 meals and 3 snacks daily; 55% carbohydrate, 20% protein, 25% fat; increased complex and decreased refined carbohydrates. | CG_INS2X_: A morning dose containing 2/3 of the total daily insulin and afternoon dose contained 1/3 total daily insulin. Morning dose comprised 1/3 regular insulin and 2/3 intermediate insulin. The afternoon dose comprised equal amounts of regular and intermediate insulin. Dietary recommendations same as IG_INS4X_. | NR
de Veciana 1995^40^ Fair | RCT | NR | Medical center in California. | Comparing the efficacy of of postprandial and preprandial monitoring in achieving glycemic control in women with gestational diabetes. Perinatal outcomes | Inclusion: Diagnosed with gestational diabetes requiring insulin at or before 30 weeks gestation; singleton pregnancy; 50 g GCT > 140 mg/dL but < 190 mg/dL, then 3 hr OGTT by NDDG criteria. Exclusion: History of diabetes prior to pregnancy; pre-existing hypertension, renal disease, or autoimmune disorders. | N=66 IG_pre_: 33 IG_post_: 33 | IG_pre_: 79kg±13 IG_post_: 77kg±13 | IG_pre_, N Hispanic: 27 White: 4 Black/Asian: 2 IG_post_, N Hispanic: 29 White: 3 Black/Asian: 1 NS (p=NR) | IG_pre_: 4.3±3.0 IG_post_: 3.6±2.2 NS (p=NR) | IG_pre_: 31±6 IG_post_: 29±5 NS (p=NR) | Women with RF (>120% ideal body weight, ≥35 yrs, glycosuria on dipstick urinalysis (≥2+), history of diabetes in first-degree relative, previous unexplained stillbirth or miscarriage) were screened at initial prenatal visit. All others were screened between 24–28 weeks. Step 1: One-hour 50-g GCT > 140 mg/dL, but <190 mg/dL; those >190 mg/dL started insulin immediately. Step 2: 3-hour 100-g OGTT with ≥ 2 abnormal glucose values (fasting > 105 mg/dL, 1 hr > 190 mg/dL, 2 hrs > 165 mg/dL, 3 hrs > 145 mg/dL). Those with elevated fasting initiated insulin immediately, others were managed with diet until fasting >105 mg/dL or postprandial (1hr) >140 mg/dL. | Fasting | 50-g OCT, 1 hr IG_pre_: 216±56 IG_post_: 214±67 NS (p=NR) Fasting at 100-g OGTT IG_pre_: 137±38 IG_post_: 145±50 NS (p=NR) | At diagnosis IG_pre_: 22.9±7.5 IG_post_: 21.8±6.5 NS (p=NR) Initiated insulin IG_pre_: 24.3±5.2 IG_post_: 25.1±5.1 NS (p=NR) | NR | NR | Weeks IG_pre_: 37.6±3.8 IG_post_: 37.9±1.4 NS | IG_pre_-Preprandial Monitoring: Required daily monitoring of fasting, preprandial and bedtime blood glucose levels. Diet: 30–35 kcal/kg of ideal body weight divided into 3 meals and 1–3 snacks; 40–45% carbohydrate; intake adjusted according to weight and blood glucose levels. Received split-dose insulin (Regular/NPH) | IG_post_-Postprandial Monitoring: Required daily monitoring of blood glucose levels before breakfast and one hour after each meal. Diet: Same as IG_pre_ Insulin: Same as IG_pre_ | NR

NS-not significant; IG-intervention group; CG-control group; INS-insulin; NR-not reported; wk(s)-week(s); SD-standard deviation; RCT-randomized control trial; f/u-follow up; WHO-World Health Organization; GDM-gestational diabetes mellitus; GCT-glucose challenge test; OGTT-oral glucose tolerance test; QID-four times daily; RR-relative risk; EPDS-Edinburgh post-natal depression scale; yrs-years; hr-hour; C&C-Carpenter & Coustan