# Appendix A: Methods

## Terminology

Terms used in this report are defined in Appendix A, Table 1.

## Key Questions and Analytic Framework

Using the USPSTF's^1^ methods we developed an analytic framework (Figure 1) and five key questions (KQs) to guide our literature search. KQ1 examined direct evidence addressing whether screening for GDM, during the first trimester or after 24 weeks, reduced perinatal morbidity and mortality for mother and/or infant. KQ2 looks at the sensitivities, specificities, reliabilities and yields of current screening tests for GDM. KQ 3 examined evidence dealing with the effectiveness of treatment during the first trimester or after 24 weeks. KQ 4 and 5 assess the harms of screening and the adverse effects of treatment respectively.

Figure 1. Search Results and Article Flow by Key Question

## Literature Search Strategy

We conducted six database searches (Appendix A, Table 2) of Medline, Cochrane Central Registry of Controlled Trials, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effectiveness, Health Technology Assessment, and the National Institute for Health and Clinical Excellence from 2000 to September 2006. The search regarding early screening searched 1966 to 2006 as this was not systematically reviewed for the 2003 report. Searches were extensively supplemented with the previous 2003 USPSTF^2^ review, outside source material from experts in the field, and from examining the bibliographies of other relevant systematic reviews.

## Inclusion and Exclusion

While we conducted five searches to cover the separate focus of each KQ, we dual-reviewed all abstracts for potential inclusion for any of the KQs, utilizing the inclusion/exclusion criteria described in Appendix A, Table 3. For KQ1 and 3, we limited study design to randomized controlled trials (RCT) and controlled clinical trials (CCT) and accepted prospective studies if no RCTs or CCTs were available. For KQ 2, 4, and 5 we accepted RCTs, CCTs, and good quality observational studies.

## Article Review and Data Abstraction

We reviewed a total of 1403 abstracts and 277 complete articles for all KQs. No RCTs comparing screening with no screening were located for KQ1. We found no articles for KQ2 that reported sensitivity, specificity, and yield rates in a US population using one of the three acceptable screening methods compared to an acceptable reference standard of the specified health outcomes. Seven studies reported in eight publications are included for KQ3a of which two are treatment versus no treatment. The remaining five studies are treatment comparisons. One prospective study evaluating early screening versus late screening and neonatal and maternal outcomes is included for KQ3b. Three trials reporting on the harms of screening were included for KQ4. Seven articles were found to address the harms of treatment (KQ5). Six of these seven also reported treatment outcomes in KQ3 and one is a unique reference.

Two investigators applied the inclusion/exclusion criteria to each article and marked articles for exclusion as soon as any one exclusion criteria was met. They then rated the quality of all articles meeting inclusion criteria, using the USPSTF's study-design specific criteria (Appendix B), which resulted in additional excluded articles for quality reasons. Listings of excluded articles along with the reason for exclusion are in Appendix D Table 1.

There are 13 studies included in this review: seven from the 2003 USPSTF review and six were located from searches or outside sources. One primary reviewer abstracted relevant information such as study setting, population, screening method, and outcomes into standardized evidence tables for each included article (Appendix C). A second reviewer checked the abstraction process for accuracy.

## Literature Synthesis

We were unable to conduct quantitative synthesis for any key question due to the heterogeneity of the screening methods and interventions. Instead, we qualitatively summarized our findings in the results text and summary tables. For KQ3, we stratified the evidence by those trials comparing treatment versus no treatment and trials comparing treatments.

## External Review Process

The USPSTF appointed four liaisons to guide the scope and reporting of this review. In addition, five outside experts provided feedback on a draft version of this evidence synthesis.

## Reference List

(1) Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
(2) Brody SC, Harris R, Lohr K. Screening for gestational diabetes: a summary of the evidence for the U.S. Preventive Services Task Force. Obstet Gynecol. 2003;101(2):380-392. [pmid: 12576264].

## Appendix A: Table 1. Glossary of Terms

ACHOIS: Australian Carbohydrate Intolerance Study in Pregnant Women

ADA: The American Diabetes Association

APGAR: The APGAR score is a quick test performed at 1 and 5 minutes after birth to determine the physical condition of the newborn. The rating is based on a scale of 1 to 10. Ten suggests the healthiest infant, and scores below 5 indicate that the infant needs immediate assistance in adjusting to his or her new environment (http://www.nlm.nih.gov/medlineplus/ency/article/003402.htm) Date Accessed 10-23-06

BMI: Body Mass Index (BMI). Your BMI estimates whether you are at a healthy weight for your height and is calculated as kg/m^2^. (http://www.nlm.nih.gov/medlineplus/ency/article/007196.htm) Date Accessed 10-23-06

DM2: Type 2 diabetes is a life-long disease marked by high levels of sugar in the blood. It occurs when the body does not respond correctly to insulin, a hormone released by the pancreas. Type 2 diabetes is the most common form of diabetes (http://www.nlm.nih.gov/medlineplus/ency/article/000313.htm) Date Accessed 10-23-06

FPG: Fasting Glucose Tolerance test. The fasting glucose tolerance test is the simplest and fastest way to measure blood glucose and diagnose diabetes. Fasting means that you have had nothing to eat or drink (except water) for 8 to 12 hours before the test

GCT: Oral Glucose Challenge Test. This is a screening test for GDM that is the first step in a two-step screening program. A 50-gram glucose drink is typically given irrespective of fasting state and blood glucose is measured one after the test. If the blood sugar exceeds a certain threshold (e.g. 140 mg/dl or 130 mg/dl) at 1 hour, then the second step of a diagnostic OGTT is performed.

LGA: The term “large for gestational age”, or LGA, means a fetus or infant is larger or more developed than normal for the baby's gestational age. Gestational age is a measure of the growth and development of the fetus in the uterus and the infant after birth. A fetus or infant larger than expected for the age and gender, or with a birth weight above the 90th percentile, is referred to as LGA. (http://www.nlm.nih.gov/medlineplus/ency/article/002248.htm) Date Accessed 10-23-06

NDDG: The National Diabetes Data Group (NDDG) serves as the major Federal focus for the collection, analysis, and dissemination of data on diabetes and its complications. Drawing on the expertise of the research, medical, and lay communities, the NDDG initiates efforts to 1) define the data needed to address the scientific and public health issues in diabetes; 2) foster and coordinate the collection of these data from multiple sources; 3) identify important data sources on diabetes, and analyze and promulgate the results of these analyses to the scientific and lay public; 4) promote the timely availability of reliable data to scientific, medical, and public organizations and individuals; 5) modify data reporting systems to identify and categorize more appropriately the medical and socioeconomic impact of diabetes; 6) promote the standardization of data collection and terminology in clinical and epidemiologic research; and 7) stimulate development of new investigator-initiated research programs in diabetes epidemiology. The NDDG developed diagnostic criteria for GDM with a OGTT test.

NICHD: National Institute of Child Health & Human Development. The NICHD, established by Congress in 1962, conducts and supports research on topics related to the health of children, adults, families, and populations. (http://www.nichd.nih.gov/about/) Date Accessed 10-23-06

NPH: NPH is a type of human insulin with intermediate onset of action. Insulin is a naturally-occurring hormone secreted by the pancreas. Insulin is required by the cells of the body in order for them to remove and use glucose from the blood. From glucose the cells produce the energy that they need to carry out their functions. Regular (rapid onset of action, short duration of action) and NPH (slower onset of action, longer duration of action) human insulin are the most commonly-used preparations. Regular insulin has an onset of action (begins to reduce blood sugar) within 30 minutes of injection, reaches a peak effect at 2–3 hours, and has effects that last up to about 6 hours. NPH insulin is an insulin with an intermediate duration of action. It has an onset of action starting about 2 hours following injection. It has a peak effect 4–12 hours after injection, and an effective duration of action about 12–18 hours. (http://www.diabetes.org/type-1-diabetes/basics.jsp) Date Accessed 10-23-06

OGTT: Oral Glucose Tolerance Test. This is a test to diagnose GDM that may be performed either following an abnormal GCT (in a two-step screening program) or as the initial screening and diagnostic test (one-step). Women have a fasting blood test (after fasting overnight), and then are given a glucose drink (either 75 gram or 100gram) and have hourly blood samples taken to measure glucose up to 3 hours after the drink. There are differing criteria internationally used for what glucose threshold defines GDM with the OGTT.

WHO: World Health Organization

## Appendix A: Table 2. Search Strategies

Systematic Review

Database: MedLine, DARE, CDSR, HTA

2000 to September 2006

1 “Diabetes, Gestational”[MeSH:NoExp]
2 “Fetal Macrosomia”[MeSH]
3 “gestational diabetes”[ti]
4 gdm[ti]
5 macrosomia[ti]
6 antepartum[tiab] AND surveillance[tiab]
7 1 OR 2 OR 3 OR 4 OR 5 OR 6
8 “gestational diabetes”[tiab]
9 “gestational diabetic*”[tiab]
10 gdm[tiab]
11 macrosomia[tiab]
12 8 OR 9 OR 10 OR 11
13 12 AND (in process[sb] OR publisher[sb])
14 7 OR 13
15 14 AND systematic[sb]
16 14 AND systematic[sb] Field: All Fields, Limits: Publication Date from 2000 to 2006, English

Screening

Database: MedLine

2000 to September 2006

1 Diabetes, Gestational/
2 gestational diabet$.ti,ab.
3 1 or 2
4 Mass Screening/
5 screen$.ti,ab.
6 4 or 5
7 3 and 6
8 Diabetes, Gestational/di [Diagnosis]
9 7 or 8
10 limit 9 to english language
11 limit 10 to humans
12 limit 10 to animals
13 12 not 11
14 10 not 13
15 limit 14 to yr=“2000 - 2006”

Early screening

Database: MedLine

1966 to 1999

1 Diabetes, Gestational/
2 gestational diabet$.ti,ab.
3 Pregnancy in Diabetics/
4 1 or 2 or 3
5 Mass Screening/
6 screen$.ti,ab.
7 5 or 6
8 4 and 7
9 Diabetes, Gestational/di [Diagnosis]
10 Pregnancy in Diabetics/di [Diagnosis]
11 8 or 9 or 10
12 Pregnancy Trimester, First/
13 first trimester.ti,ab.
14 first pregnancy trimester.ti,ab.
15 Pregnancy Trimester, Second/
16 second trimester.ti,ab.
17 second pregnancy trimester.ti,ab.
18 early.ti,ab.
19 earlier.ti,ab.
20 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21 11 and 20
22 limit 21 to english language
23 limit 22 to humans
24 limit 22 to animals
25 24 not 23
26 22 not 25
27 limit 26 to yr=“1966 - 1999”

Screening Tests

Database: MedLine

2000 to September 2006

1 Glucose Tolerance Test/
2 oral glucose tolerance.ti,ab.
3 ogtt.ti,ab.
4 glucose challenge test$.ti,ab.
5 Glucose Intolerance/
6 Blood Glucose/
7 Diabetes, Gestational/
8 gestational diabet$.ti,ab.
9 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10 Pregnancy/
11 pregnan$.ti,ab,hw.
12 10 or 11
13 9 and 12
14 “Sensitivity and Specificity”/
15 “Predictive Value of Tests”/
16 ROC Curve/
17 specificit$.ti,ab.
18 sensitiv$.ti,ab.
19 predictive value.ti,ab.
20 accurac$.ti,ab.
21 False Negative Reactions/
22 False Positive Reactions/
23 Diagnostic Errors/
24 exp “Reproducibility of Results”/
25 Reference Values/
26 Reference Standards/
27 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26
28 13 and 27
29 1 or 2 or 3 or 4
30 12 and 29
31 limit 30 to (clinical trial or controlled clinical trial or randomized controlled trial)
32 clinical trials/ or controlled clinical trials/ or randomized controlled trials/
33 double-blind method/ or random allocation/ or single-blind method/
34 random$.ti,ab.
35 32 or 33 or 34
36 30 and 35
37 Glucose Tolerance Test/st [Standards]
38 28 or 31 or 36 or 37
39 limit 38 to english language
40 limit 39 to humans
41 limit 39 to animals
42 41 not 40
43 39 not 42
44 limit 43 to yr=“2000 - 2006”

Clinical Trials

Database: MedLine, Cochrane Central Registry of Controlled Trials

2000 to September 2006

1 Diabetes, Gestational/
2 gestational diabet$.ti,ab.
3 1 or 2
4 limit 3 to (clinical trial or controlled clinical trial or randomized controlled trial)
5 clinical trials/ or controlled clinical trials/ or randomized controlled trials/
6 double-blind method/ or random allocation/ or single-blind method/
7 random$.ti,ab.
8 5 or 6 or 7
9 3 and 8
10 4 or 9
11 limit 10 to english language
12 limit 11 to humans
13 limit 11 to animals
14 13 not 12
15 11 not 14
16 limit 15 to yr=“2000 - 2006”

Treatment Harms

Database: MedLine

2000 to September 2006

1 Diabetes, Gestational/dh, dt, pc, th [Diet Therapy, Drug Therapy, Prevention & Control, Therapy]
2 Insulin/
3 Glyburide/
4 Metformin/
5 Sulfonylurea Compounds/
6 Hypoglycemic Agents/
7 (administration dosage or “therapeutic use”).fs.
8 treat$.ti,ab,hw.
9 therapy.ti,ab,hw.
10 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11 Diabetes, Gestational/
12 gestational diabet$.ti,ab.
13 11 or 12
14 10 and 13
15 1 or 14
16 (adverse effects or mortality or poisoning or toxicity).fs.
17 adverse effect$.ti,ab.
18 harm$.ti,ab.
19 Prenatal Exposure Delayed Effects/
20 Abnormalities, Drug-Induced/
21 anxiety.ti,ab,hw.
22 depression.ti,ab,hw.
23 Depressive Disorder/
24 labeling.ti,ab.
25 labelling.ti,ab.
26 labeled.ti,ab.
27 labelled.ti,ab.
28 Hypoglycemia/
29 Hypoglycemi$.ti,ab.
30 Hypoglycaemi$.ti,ab.
31 Acidosis/
32 Acidosis, Lactic/
33 acidosis.ti,ab.
34 Teratogens/
35 teratogen$.ti,ab.
36 pain.ti,ab,hw.
37 unnecessary.ti,ab,hw.
38 Pre-Eclampsia/
39 Pre-Eclamp$.ti,ab.
40 preeclamp$.ti,ab.
41 Hypertension, Pregnancy-Induced/
42 pregnancy induced hypertension.ti,ab.
43 gestational hypertension.ti,ab.
44 Hypertension/ and Pregnancy Complications, Cardiovascular/
45 Infant Mortality/
46 infant mortality.ti,ab.
47 neonatal mortality.ti,ab.
48 perinatal mortality.ti,ab.
49 hyperbilirubinemia, neonatal/ or jaundice, neonatal/
50 hyperbilirubin$.ti,ab.
51 Phototherapy/
52 phototherapy.ti,ab.
53 Polycythemia/
54 Polycythemi$.ti,ab.
55 Polycythaemi$.ti,ab.
56 Respiratory Distress Syndrome, Newborn/
57 Respiratory Distress.ti,ab.
58 Intensive Care, Neonatal/
59 neonatal intensive care.ti,ab.
60 nicu.ti,ab.
61 Infant, Small for Gestational Age/
62 Small for Gestational Age.ti,ab.
63 Fetal Growth Retardation/
64 Intrauterine Growth Retardation.ti,ab.
65 Intrauterine Growth Restriction.ti,ab.
66 IUGR.ti,ab.
67 Fetal Growth Retardation.ti,ab.
68 Fetal Growth Restriction.ti,ab.
69 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68
70 15 and 69
71 limit 70 to english language
72 limit 71 to humans
73 limit 71 to animals
74 73 not 72
75 71 not 74
76 limit 75 to yr=“2000 - 2006”

## Appendix A: Table 3. Inclusion and Exclusion Criteria for Key Questions

Inclusion Criteria:

Key Question 1

1 Study evaluates screening for gestational diabetes < 24 weeks or ≥ 24 weeks in a population relevant to primary care
2 Acceptable screening methods: one-step (75 g or 100 g); two step (50 g/100 g; 50 g/75 g); fasting glucose for <24 weeks
3 Positive screen includes:
  a 50 g: ≥130 mg/dL or ≥140 mg/dL
  b 75 g: Carpenter & Coustan; ADA; or WHO criteria
  c 100 g: Carpenter & Coustan; or NDDG criteria
4 Primary outcomes systematically identified
  a Maternal: mortality; pre-eclampsia/pregnancy induced hypertension
  b Perinatal outcomes: mortality; brachial plexus injury; fractured clavicle; admission to NICU for treatment of hypoglycemia, hyperbilirubinemia, or respiratory distress syndrome
  c Secondary or intermediate outcomes (not systematically included): macrosomia; cesarean section; induction of labor; pre-term birth; maternal 3^rd^ or 4^th^ degree perineal lacerations
5 Study Design: RCT, CCT or prospective cohort if no RCT available

Key Question 2

1 Study evaluates screening test sensitivity, specificity, reliability and yield
2 Acceptable screening methods: one-step (75 g or 100 g); two step (50 g/100 g; 50 g/75 g); fasting glucose for < 24 weeks
3 Positive screen includes:
  a 50 g: ≥130 mg/dL or ≥140 mg/dL
  b 75 g: Carpenter & Coustan; ADA; or WHO criteria
  c 100 g: Carpenter & Coustan; or NDDG criteria
4 Outcomes: sensitivity, specificity, yields, reliability
5 Study Design: RCT, CCT, Observational
6 Uses sensitivity and specificity criterion to assess primary health outcomes specified in the analytic framework

Key Question 3

1 Study evaluates treatment of gestational diabetes including glyburide, any sulfonylurea, metformin, insulin, diet and/or exercise therapy
2 Acceptable screening methods: one-step (75 g or 100 g); two step (50 g/100 g; 50 g/75 g); fasting glucose < 24 weeks
3 Positive screen includes:
  a 50 g: ≥130 mg/dL or ≥140 mg/dL
  b 75 g: Carpenter & Coustan; ADA; or WHO criteria
  c 100 g: Carpenter & Coustan; or NDDG criteria
4 Primary outcomes systematically identified
  a Maternal: mortality; pre-eclampsia/pregnancy induced hypertension
  b Perinatal outcomes: mortality; brachial plexus injury; fractured clavicle; admission to NICU for treatment of hypoglycemia, hyperbilirubinemia, or respiratory distress syndrome
  c Secondary or intermediate outcomes (not systematically identified): macrosomia; cesarean section; pre-term birth; maternal 3^rd^ or 4^th^ degree perineal lacerations
5 Study Design: RCT, CCT, or prospective cohort if no RCT available

Key Question 4

1 Study presents harms of screening tests accepted in KQ1 or KQ3
2 Acceptable screening methods: one-step (75 g or 100 g); two step (50 g/100 g; 50 g/75 g); fasting glucose < 24 weeks
3 Positive screen includes:
  a 50 g: ≥130 mg/dL or ≥140 mg/dL
  b 75 g: Carpenter & Coustan; ADA; or WHO criteria
  c 100 g: Carpenter & Coustan; or NDDG criteria
  d Exception allowed if used an accepted screening method and nonstandard cutoff criteria
4 Study design: RCT, CCT, or prospective cohort if no RCT available

Key Question 5

1 Study presents harms of treatment accepted in KQ3
2 Acceptable screening methods: one-step (75 g or 100 g); two step (50 g/100 g; 50 g/75 g); fasting glucose < 24 weeks
3 Positive screen includes:
  a 50 g: ≥130 mg/dL or ≥140 mg/dL
  b 75 g: Carpenter & Coustan; ADA; or WHO criteria
  c 100 g: Carpenter & Coustan; or NDDG criteria
  d Exception allowed if used an accepted screening method and nonstandard cutoff criteria
4 Study design: RCT, CCT, or prospective cohort if no RCT available

Exclusion Criteria:

1 Not an acceptable study design, including methodology of accepted study types or mixing GDM/IGT/Normal groups
2 Not generalizable to US population
3 Does not address morbidity and/or mortality
4 Not one of established screening criteria used (hgbA1c), or 50 gram OGTT used as a diagnostic test (non-standard) or 75/100 gram 100 gram OGTT diagnostic tests using different diagnostic criteria than the current standards as outlined in our workplan (e.g., cutoffs +SD to a different population mean)
5 No info on yield (prevalence), sens/spec or reliability
6 Not one of established screening criteria used (e.g. HgbA1c)
7 Not one of the included treatments for GDM; (e.g., thiazolidinediones)
8 Editorials, comments, and letters
9 Non-systematic reviews
10 Does not address one of the key questions
11 Systematic Review, but search strategy too old to be relevant for our interval update of the USPSTF 2003 GDM review
12 SER used as source document
13 Prevalence outside U.S
14 Prevalence only articles
15 Natural history only articles
16 Does not report sensitivity and specificity criterion to assess specified health outcomes in the Analytic Framework
17 Poor quality