# References

1 Kessler RC, McGonagle KA, Zhao S, et al. Lifetime and 12-month prevalence of DSM-IIIR psychiatric disorders in the United States. Results from the National Comorbidity Survey. Arch Gen Psychiatry. 1994;51:8-19. [pmid: 8279933].
2 Robins L, Regier D. Psychiatric Disorders in America. New York: Free Press. 1991.
3 Depression Guideline Panel. Depression in Primary Care: Volume 1. Detection and Diagnosis. Clinical Practice Guideline, Number 5. Rockville, Maryland: U.S Department of Health and Human Services; 1993. AHCPR No. 93-0550.
4 Katon W. The epidemiology of depression in medical care. Int J Psychiatry Med. 1987;17:93-112. [pmid: 3294691].
5 Judd LL. The clinical course of unipolar major depressive disorders. Arch Gen Psychiatry. 1997;54:989-991. [pmid: 9366654].
6 Greenberg PE, Stiglin LE, Finkelstein SN, Berndt ER. The economic burden of depression in 1990. J Clin Psychiatry. 1993;54:405-418. [pmid: 8270583].
7 Blair-West GW, Mellsop GW, Eyeson-Annan ML. Down-rating lifetime suicide risk in major depression. Acta Psychiatr Scand. 1997;95:259-263. [pmid: 9111861].
8 Harris EC, Barraclough B. Suicide as an outcome for mental disorders. A meta-analysis. Br J Psychiatry. 1997;170:205-228. [pmid: 9229027].
9 Murray L, Stanley C, Hooper R, King F, Fiori-Cowley A. The role of infant factors in postnatal depression and mother-infant interactions. Dev Med Child Neurol. 1996;38:109-119. [pmid: 8603778].
10 Musselman D, Evans D, Nemeroff C. The relationship of depression to cardiovascular disease. Arch Gen Psychiatry. 1998;55:580-592. [pmid: 9672048].
11 Consensus Development Panel. NIMH/NIH Consensus Development Conference statement. Mood disorders: pharmacologic prevention of recurrences. Am J Psychiatry. 1985;142:469-476. [pmid: 3976921].
12 Pennix BW, Guralnik JM, Ferrucci L, Simonsick EM, Deeg DJ, Wallace RB. Depressive symptoms and physical decline in community-dwelling older persons. JAMA. 1998;276:1720-1726.
13 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition. Washington, DC: American Psychiatric Association. 1994. [pmcid: 330086].
14 Wells KB, Stewart A, Hays RD, et al. The functioning and well-being of depressed patients. Results from the Medical Outcomes Study. JAMA. 1989;262:914-919. [pmid: 2754791].
15 Howland R. General health, health care utilization, and medical comorbidity in dysthymia. Int J Psychiatry Med. 1993;23:211-238. [pmid: 8270354].
16 Wells KB, Burnam MA, Rogers W, Hays R, Camp P. The course of depression in adult outpatients. Results from the Medical Outcomes Study. Arch Gen Psychiatry. 1992;49:788-794. [pmid: 1417431].
17 Williams JW Jr, Kerber CA, Mulrow CD, Medina A, Aguilar C. Depressive disorders in primary care: prevalence, functional disability, and identification. J Gen Intern Med. 1995;10:7-12. [pmid: 7699487].
18 Wagner R, Burns BJ, Yarnall K, Sigmon A, Walker R, Gaynes BN Minor depression in family practice: functional morbidity, comorbidity, service utilization, and outcomes Psychol Med 2000 30(6):1377 1390 11097078
19 Cooper-Patrick L, Crum RM, Ford DE. Characteristics of patients with major depression who received care in general medical and specialty mental health settings. Med Care. 1994;32:15-24. [pmid: 8277799].
20 Paykel E, Priest R. Recognition and management of depression in general practice: consensus statement. BMJ. 1992;305:1198-1202. [pmid: 1467723].
21 Simon GE, Von Korff M, Durham ML. Predictors of outpatient mental health utilization by primary care patients in a health maintenance organization. Am J Psychiatry. 1994;151:908-913. [pmid: 8185002].
22 Song F, Freemantle N, Sheldon TA, et al. Selective serotonin reuptake inhibitors: meta-analysis of efficacy and acceptability. BMJ. 1993;306:683-687. [pmid: 8471919].
23 Kessler RC, Nelson CB, McGongale KA, Liu J, Swartz M, Blazer DG. Comorbidity of DSM-IIIR major depressive disorder in the general population: Results from the US National Comorbidity Survey. Br J Psychiatry. 1996;168:17-30.
24 Regier DA, Narrow WE, Rae DS, Manderscheid RW, Locke BZ, Goodwin FK. The de facto US mental and addictive disorders service system. Epidemiologic catchment area prospective 1-year prevalence rates of disorders and services. Arch Gen Psychiatry. 1993;50:85-94. [pmid: 8427558].
25 Pincus HA, Tanielian TL, Marcus SC, et al. Prescribing trends in psychotropic medications: primary care, psychiatry, and other medical specialities. JAMA. 1998;279:526-531. [pmid: 9480363].
26 Simon GE, Von Korff M. Recognition, management, and outcomes of depression in primary care. Arch Fam Med. 1995;4:99-105. [pmid: 7842160].
27 Gerber PD, Barrett J, Barrett J, Manheimer E, Whiting R, Smith R. Recognition of depression by internists in primary care: a comparison of internist and 'gold standard' psychiatric assessments. J Gen Intern Med. 1989;4:7-13. [pmid: 2915277].
28 Klinkman MS. Competing demands in psychosocial care. A model for the identification and treatment of depressive disorders in primary care. Gen Hosp Psychiatry. 1997;19:98-111. [pmid: 9097064].
29 Borowsky SJ, Rubenstein LV, Meredith LS, Camp P, Jackson-Triche M, Wells KB. Who is at risk of nondetection of mental health problems in primary care?. J Gen Intern Med. 2000;15:381-388. [pmid: 10886472].
30 Linde K, Mulrow CD. St. John's wort for depression (Cochrane Review). The Cochrane Library. 1998.
31 US Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Alexandria, Va.: International Medical Publishing. 1996. [pmcid: 190016].
32 American College of Physicians. ACP-ASIM Clinical Practice Guidelines: Current and Future Projects. Available at: http://www.acponline.org/sci-policy/guidelines/projects.htm. Accessed November 15, 1999.
33 Feightner JW. Early detection of depression. In: Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventive Health Care. Ottawa: Health Canada. 1994:450-454.
34 Arthur A, Jagger C, Lindesay J, Graham C, Clarke M. Using an annual over-75 health check to screen for depression: validation of the short Geriatric Depression Scale (GDS15) within general practice. Int J Geriatr Psychiatry. 1999;14:431-439. [pmid: 10398352].
35 Banerjee S, Shamash K, MacDonald AJ, Mann AH. The use of the SelfCARE(D) as a screening tool for depression in the clients of local authority home care services -- a preliminary study. Int J Geriatr Psychiatry. 1998;13:695-699. [pmid: 9818305].
36 Bashir K, Blizard R, Jenkins R, Mann A. Validation of the 12-item general health questionnaire in British general practice. Primary Care Psychiatry. 1996;2:4-7.
37 Beekman AT, Deeg DJ, Van Limbeek J, Braam AW, De Vries MZ, Van Tilburg W. Criterion validity of the Center for Epidemiologic Studies Depression scale (CES-D): results from a community-based sample of older subjects in The Netherlands. Psychol Med. 1997;27:231-235. [pmid: 9122304].
38 Bird AS, Macdonald AJD, Mann AH, Philpot MP. Preliminary experience with the Selfcare (D): A self-rating depression questionnaire for use in elderly, non-institutionalized subjects. Int J Geriatr Psychiatry. 1987;2:31-38.
39 Broadhead WE, Leon AC, Weissman MM, et al. Development and validation of the SDDS-PC screen for multiple mental disorders in primary care. Arch Fam Med. 1995;4:211-219. [pmid: 7881602].
40 Burnam MA, Wells KB, Leake B, Landsverk J. Development of a brief screening instrument for detecting depressive disorders. Med Care. 1988;26:775-789. [pmid: 3398606].
41 D'Ath P, Katona P, Mullan E, Evans S, Katona C. Screening, detection and management of depression in elderly primary care attenders. I: The acceptability and performance of the 15 item Geriatric Depression Scale (GDS15) and the development of short versions. Fam Pract. 1994;11:260-266. [pmid: 7843514].
42 Fechner-Bates S, Coyne JC, Schwenk TL. The relationship of self-reported distress to depressive disorders and other psychopathology. J Consult Clin Psychol. 1994;62:550-559. [pmid: 8063981].
43 Finlay-Jones RA, Murphy E. Severity of psychiatric disorder and the 30-item general health questionnaire. Br J Psychiatry. 1979;134:609-616. [pmid: 476372].
44 Geisser ME, Roth RS, Robinson ME. Assessing depression among persons with chronic pain using the Center for Epidemiological Studies-Depression Scale and the Beck Depression Inventory: a comparative analysis. Clin J Pain. 1997;13:163-170. [pmid: 9186024].
45 Gerety MB, Williams JW Jr, Mulrow CD, et al. Performance of case-finding tools for depression in the nursing home: influence of clinical and functional characteristics and selection of optimal threshold scores. J Am Geriatr Soc. 1994;42:1103-1109. [pmid: 7930337].
46 Goldberg DP, Blackwell B. Psychiatric illness in general practice. A detailed study using a new method of case identification. BMJ. 1970;1:439-443. [pmid: 5420206].
47 Hendrie HC, Callahan CM, Levitt EE, et al. Prevalence rates of major depressive disorders: The effects of varying the diagnostic criteria in an older primary care population. Am J Geriatr Psychiatry. 1995;3:119-131.
48 Holcomb WL Jr, Stone LS, Lustman PJ, Gavard JA, Mostello DJ. Screening for depression in pregnancy: characteristics of the Beck Depression Inventory. Obstet Gynecol. 1996;88:1021-1025. [pmid: 8942846].
49 Hoyl MT, Alessi CA, Harker JO, et al. Development and testing of a five-item version of the Geriatric Depression Scale. J Am Geriatr Soc. 1999;47:873-878. [pmid: 10404935].
50 Irwin M, Artin KH, Oxman MN. Screening for depression in the older adult: criterion validity of the 10-item Center for Epidemiological Studies Depression Scale (CES-D). Arch Intern Med. 1999;159:1701-1704. [pmid: 10448771].
51 Klinkman MS, Coyne JC, Gallo S, Schwenk TL. Can case-finding instruments be used to improve physician detection of depression in primary care?. Arch Fam Med. 1997;6:567-573. [pmid: 9371051].
52 Leon AC, Olfson M, Weissman MM, et al. Brief screens for mental disorders in primary care. J Gen Intern Med. 1996;11:426-430. [pmid: 8842936].
53 Leung KK, Lue BH, Lee MB, Tang LY. Screening of depression in patients with chronic medical diseases in a primary care setting. Fam Pract. 1998;15:67-75. [pmid: 9527300].
54 Lewinsohn PM, Seeley JR, Roberts RE, Allen NB. Center for Epidemiologic Studies Depression Scale (CES-D) as a screening instrument for depression among community-residing older adults. Psychol Aging. 1997;12:277-287. [pmid: 9189988].
55 Lustman PJ, Clouse RE, Griffith LS, Carney RM, Freedland KE. Screening for depression in diabetes using the Beck Depression Inventory. Psychosom Med. 1997;59:24-31. [pmid: 9021863].
56 Lyness JM, Noel TK, Cox C, King DA, Conwell Y, Caine ED. Screening for depression in elderly primary care patients. A comparison of the Center for Epidemiologic Studies-Depression Scale and the Geriatric Depression Scale. Arch Intern Med. 1997;157:449-454. [pmid: 9046897].
57 Myers JK, Weissman MM. Use of a self-report symptom scale to detect depression in a community sample. Am J Psychiatry. 1980;137:1081-1084. [pmid: 7425160].
58 Nagel R, Lynch D, Tamburrino M. Validity of the medical outcomes study depression screener in family practice training centers and community settings. Fam Med. 1998;30:362-365. [pmid: 9597535].
59 Neal RM, Baldwin RC. Screening for anxiety and depression in elderly medical outpatients. Age Aging. 1994;23:461-464.
60 Okimoto JT, Barnes RF, Veith RC, Raskind MA, Inui TS, Carter WB. Screening for depression in geriatric medical patients. Am J Psychiatry. 1982;139:799-802. [pmid: 7081496].
61 Parkerson GR Jr, Broadhead WE. Screening for anxiety and depression in primary care with the Duke Anxiety-Depression Scale. Fam Med. 1997;29:177-181. [pmid: 9085098].
62 Salokangas RK, Poutanen O, Stengard E. Screening for depression in primary care. Development and validation of the Depression Scale, a screening instrument for depression. Acta Psychiatr Scand. 1995;92:10-16. [pmid: 7572242].
63 Schulberg HC, Saul M, McClelland M, Ganguli M, Christy W, Frank R. Assessing depression in primary medical and psychiatric practices. Arch Gen Psychiatry. 1985;42:1164-1170. [pmid: 4074109].
64 Spitzer RL, Kroenke K, Williams JBW. Validation and utility of a self-report version of PRIME-MD. JAMA. 1999;282:1737-1744. [pmid: 10568646].
65 Steer RA, Cavalieri TA, Leonard DM, Beck AT. Use of the Beck Depression Inventory for Primary Care to screen for major depression disorders. Gen Hosp Psychiatry. 1999;21:106-111. [pmid: 10228890].
66 Turk DC, Okifuji A. Detecting depression in chronic pain patients: adequacy of self-reports. Behav Res Ther. 1994;32:9-16. [pmid: 8135727].
67 Upadhyaya AK, Stanley I. Detection of depression in primary care: comparison of two self-administered scales. Int J Geriatr Psychiatry. 1997;12:35-37. [pmid: 9050421].
68 van Marwijk HW, Wallace P, de Bock GH, Hermans J, Kaptein AA, Mulder JD. Evaluation of the feasibility, reliability and diagnostic value of shortened versions of the geriatric depression scale. Br J Gen Pract. 1995;45:195-199. [pmid: 7612321].
69 Von Korff M, Shapiro S, Burke JD, et al. Anxiety and depression in a primary care clinic. Comparison of Diagnostic Interview Schedule, General Health Questionnaire, and practitioner assessments. Arch Gen Psychiatry. 1987;44:152-156. [pmid: 3813810].
70 Weyerer S, Killmann U, Ames D, Allen N. The even briefer assessment scale for depression (EBAS DEP): its suitability for the elderly in geriatric care in english- and german-speaking countries. Int J Geriatr Psychiatry. 1999;14:473-480. [pmid: 10398358].
71 Whooley MA, Avins AL, Miranda J, Browner WS. Case-Finding Instruments for Depression. J Gen Intern Med. 1997;12:439-445. [pmid: 9229283].
72 Wickberg B, Hwang CP. The Edinburgh Postnatal Depression Scale: validation on a Swedish community sample. Acta Psychiatr Scand. 1996;94:181-184. [pmid: 8891084].
73 Zich JM, Attkisson CC, Greenfield TK. Screening for depression in primary care clinics: the CES-D and the BDI. Int J Psychiatry Med. 1990;20:259-277. [pmid: 2265888].
74 Appleby L, Warner R, Whitton A, Faragher B. A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ. 1997;314:932-936. [pmid: 9099116].
75 Mynors-Wallis LM, Gath DH, Day A, Baker F. Randomized controlled trial of problem solving treatment, antidepressant medication, and combined treatment for major depression in primary care. BMJ. 2000;320:26-30. [pmid: 10617523]. [pmcid: 27250].
76 Malt UF, Robak OH, Madsbu HP, Bakke O, Loeb M. The Norwegian naturalistic treatment study of depression in general practice (NORDEP)-I: randomised double blind study. BMJ. 1999;318:1180-1184. [pmid: 10221945]. [pmcid: 34546].
77 Mynors-Wallis LM, Gath DH, Lloyd-Thomas AR, Tomlinson D. Randomised controlled trial comparing problem solving treatment with amitriptyline and placebo for major depression in primary care. BMJ. 1995;310:441-445. [pmid: 7873952].
78 Schulberg HC, Block MR, Madonia MJ, et al. Treating major depression in primary care practice. Eight-month clinical outcomes. Arch Gen Psychiatry. 1996;53:913-919. [pmid: 8857868].
79 Brown C, Schulberg HC, Madonia MJ, Shear MK, Houck PR. Treatment outcomes for primary care patients with major depression and lifetime anxiety disorders. Am J Psychiatry. 1996;153:1293-1300. [pmid: 8831437].
80 Coulehan JL, Schulberg HC, Block MR, Madonia MJ, Rodriguez E. Treating depressed primary care patients improves their physical, mental, and social functioning. Arch Intern Med. 1997;157:1113-1120. [pmid: 9164377].
81 Scott AI, Freeman CP. Edinburgh primary care depression study: treatment outcome, patient satisfaction, and cost after 16 weeks. BMJ. 1992;304:883-887. [pmid: 1392754].
82 Whooley MA, Stone B, Soghikian K. Randomized trial of case-finding for depression in elderly primary care patients. J Gen Intern Med. 2000;15:293-300. [pmid: 10840264].
83 Blackburn IM, Bishop S, Glen AI, Whalley LJ, Christie JE. The efficacy of cognitive therapy in depression: a treatment trial using cognitive therapy and pharmacotherapy, each alone and in combination. Br J Psychiatry. 1981;139:181-189. [pmid: 7317698].
84 Holden JM, Sagovsky R, Cox JL. Counselling in a general practice setting: controlled study of health visitor intervention in treatment of postnatal depression. BMJ. 1989;298:223-226. [pmid: 2493868].
85 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. 1996;53:924-932. [pmid: 8857869].
86 Lynch DJ, Tamburrino MB, Nagel R. Telephone counseling for patients with minor depression: preliminary findings in a family practice setting. J Fam Pract. 1997;44:293-298. [pmid: 9071250].
87 Miranda J, Munoz R. Intervention for minor depression in primary care patients. Psychosom Med. 1994;56:136-141. [pmid: 8008800].
88 Ross M, Scott M. An evaluation of the effectiveness of individual and group cognitive therapy in the treatment of depressed patients in an inner city health centre. J R Coll Gen Pract. 1985;35:239-242. [pmid: 4020747].
89 Scott C, Tacchi MJ, Jones R, Scott J. Acute and one-year outcome of a randomised controlled trial of brief cognitive therapy for major depressive disorder in primary care. Br J Psychiatry. 1997;171:131-134. [pmid: 9337947].
90 Teasdale JD, Fennell MJ, Hibbert GA, Amies PL. Cognitive therapy for major depressive disorder in primary care. Br J Psychiatry. 1984;144:400-406. [pmid: 6372925].
91 Callahan CM, Hendrie HC, Dittus RS, Brater DC, Hui SL, Tierney WM. Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. 1994;42:839-846. [pmid: 8046193].
92 Callahan CM, Dittus RS, Tierney WM. Primary care physicians' medical decision making for late-life depression. J Gen Intern Med. 1996;11:218-225. [pmid: 8744879].
93 Dowrick C. Does testing for depression influence diagnosis or management by general practitioners?. Fam Pract. 1995;12:461-465. [pmid: 8826066].
94 Johnstone A, Goldberg D. Psychiatric screening in general practice. A controlled trial. Lancet. 1976;1:605-608. [pmid: 55891].
95 Linn LS, Yager J. The effect of screening, sensitization, and feedback on notation of depression. J Med Educ. 1980;55:942-949. [pmid: 7441675].
96 Lewis G, Sharp D, Bartholomew J, Pelosi AJ. Computerized assessment of common mental disorders in primary care: effect on clinical outcome. Fam Pract. 1996;13:120-126. [pmid: 8732321].
97 Magruder-Habib K, Zung WW, Feussner JR. Improving physicians' recognition and treatment of depression in general medical care. Results from a randomized clinical trial. Med Care. 1990;28:239-250. [pmid: 2179650].
98 Moore JT, Silimperi DR, Bobula JA. Recognition of depression by family medicine residents: the impact of screening. J Fam Pract. 1978;7:509-513. [pmid: 690583].
99 Rand EH, Badger LW, Coggins DR. Toward a resolution of contradictions. Utility of feedback from the GHQ. Gen Hosp Psychiatry. 1988;10:189-196. [pmid: 3378697].
100 Reifler DR, Kessler HS, Bernhard EJ, Leon AC, Martin GJ. Impact of screening for mental health concerns on health service utilization and functional status in primary care patients. Arch Intern Med. 1996;156:2593-2599. [pmid: 8951303].
101 Wells KB, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. 2000;283:212-220. [pmid: 10634337].
102 Williams JW Jr, Mulrow CD, Kroenke K, et al. Case-finding for depression in primary care: a randomized trial. Am J Med. 1999;106:36-43. [pmid: 10320115].
103 Zung WW, King RE. Identification and treatment of masked depression in a general medical practice. J Clin Psychiatry. 1983;44:365-368. [pmid: 6643397].
104 Mulrow CD, Williams JW Jr, Gerety MB, Ramirez G, Montiel OM, Kerber C. Case-finding instruments for depression in primary care settings. Ann Intern Med. 1995;122:913-921. [pmid: 7755226].
105 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition: Primary Care Version (DSM-IV-PC). 1st ed. Washington, DC: American Psychiatric Press. 1995. [pmcid: 441483].
106 Furukawa T, Hirai T, Kitamura T, Takahashi K. Application of the Center for Epidemiological Studies Depression Scale among first-visit psychiatric patients: a new approach to improve its performance. J Affect Disord. 1997;46:1-13. [pmid: 9387082].
107 Conde MV, Williams JW Jr, Mulrow CD. Targeting depression interviewing: an exercise in diagnostic reasoning. J Gen Intern Med. 1998;13:262-265. [pmid: 9565390].
108 Gutterman EM, O'Brien JD, Young JG. Structured diagnostic interviews for children and adolescents: current status and future directions. J Am Acad Child Adolesc Psychiatry. 1987;26:621-630. [pmid: 3312159].
109 Kashani JH, Sherman DD, Parker DR, Reid JC. Utility of the Beck Depression Inventory with clinic-referred adolescents. J Am Acad Child Adolesc Psychiatry. 1990;29:278-282. [pmid: 2324068].
110 Ambrosini PJ, Metz C, Bianchi MD, Rabinovich H, Undie A. Concurrent validity and psychometric properties of the Beck Depression Inventory in outpatient adolescents. J Am Acad Child Adolesc Psychiatry. 1991;30:51-57. [pmid: 2005064].
111 Roberts RE, Lewinsohn PM, Seeley JR. Screening for adolescent depression: a comparison of depression scales. J Am Acad Child Adolesc Psychiatry. 1991;30:58-66. [pmid: 2005065].
112 Barrera M Jr, Garrison-Jones CV. Properties of the Beck Depression Inventory as a screening instrument for adolescent depression. J Abnorm Child Psychol. 1988;16:263-273. [pmid: 3403810].
113 Whitaker A, Johnson J, Shaffer D, et al. Uncommon troubles in young people: prevalence estimates of selected psychiatric disorders in a nonreferred adolescent population. Arch Gen Psychiatry. 1990;47:487-496. [pmid: 2331210].
114 Winter LB, Steer RA, Jones-Hicks L, Beck AT. Screening for major depression disorders in adolescent medical outpatients with the Beck Depression Inventory for Primary Care. J Adolesc Health. 1999;24:389-394. [pmid: 10401966].
115 Costello EJ, Angold A. Scales to assess child and adolescent depression: checklists, screens, and nets. J Am Acad Child Adolesc Psychiatry. 1988;27:726-737. [pmid: 3058677].
116 Garrison CZ, Addy CL, Jackson KL, McKeown RE, Waller JL. The CES-D as a screen for depression and other psychiatric disorders in adolescents. J Am Acad Child Adolesc Psychiatry. 1991;30:636-641. [pmid: 1890099].
117 Fendrich M, Weissman MM, Warner V. Screening for depressive disorder in children and adolescents: validating the Center for Epidemiologic Studies Depression Scale for Children. Am J Epidemiol. 1990;131:538-551. [pmid: 2301363].
118 Angold A, Costello EJ, Messer SC, Pickles A. Development of a short questionnaire for use in epidemiological studies of depression in children and adolescents. Int J Methods Psychiatric Res. 1995;5:237-249.
119 King CA, Katz SH, Ghaziuddin N, Brand E, Hill E, McGovern L. Diagnosis and assessment of depression and suicidality using the NIMH Diagnostic Interview Schedule for Children (DISC-2. 3). J Abnorm Child Psychol. 1997;25:173-181. [pmid: 9212370].
120 Jensen PS, Salzberg AD, Richters JE, Watanabe HK. Scales, diagnoses, and child psychopathology: I. CBCL and DISC relationships. J Am Acad Child Adolesc Psychiatry. 1993;32:397-406. [pmid: 8444770].
121 Stancin T, Palermo TM. A review of behavioral screening practices in pediatric settings: do they pass the test?. J Dev Behav Pediatr. 1997;18:183-194. [pmid: 9213238].
122 Marton P, Churchard M, Kutcher S, Korenblum M. Diagnostic utility of the Beck Depression Inventory with adolescent psychiatric outpatients and inpatients. Can J Psychiatry. 1991;36:428-431. [pmid: 1933746].
123 Canning EH, Kelleher K. Performance of screening tools for mental health problems in chronically ill children. Arch Pediatr Adolesc Med. 1994;148:272-278. [pmid: 8130859].
124 Mulrow CD, Williams JW Jr, Chiquette E, et al. Efficacy of newer pharmacotherapies for treating depression in primary care patients. Am J Med. 2000;108:54-64. [pmid: 11059441].
125 Lima MS, Moncrieff J. Drugs versus placebo for dysthymia (Cochrane Review). The Cochrane Library. 1999.
126 Gill D, Hatcher S. Antidepressant drugs in depressed patients who also have a physical illness (Cochrane Review). The Cochrane Library. 1999.
127 Evans M, Hammond M, Wilson K, Lye M, Copeland J. Placebo-controlled treatment trial of depression in elderly physically ill patients. Int J Geriatr Psychiatry. 1997;12:817-824. [pmid: 9283926].
128 Williams JW Jr, Mulrow CD, Chiquette E, Noel PH, Aguilar C, Cornell J. A systematic review of newer pharmacotherapies for depression in adults: evidence report summary. Ann Intern Med. 2000;132:743-756. [pmid: 10787370].
129 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. 1995;273:1026-1031. [pmid: 7897786].
130 Simon GE, Von Korff M, Rutter C, Wagner E. Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care. BMJ. 2000;320:550-554. [pmid: 10688563]. [pmcid: 27299].
131 Katzelnick DJ, Simon GE, Pearson SD, et al. Randomized trial of a depression management program in high utilizers of medical care. Arch Fam Med. 2000;9:345-351. [pmid: 10776363].
132 Llewellyn-Jones RH, Baikie KA, Smithers H, Cohen J, Snowdon J, Tennant CC. Multifaceted shared care intervention for late life depression in residential care: randomised controlled trial. BMJ. 1999;319:676-682. [pmid: 10480824]. [pmcid: 28220].
133 Peveler R, George C, Kinmonth AL, Campbell M, Thompson C. Effect of antidepressant drug counselling and information leaflets on adherence to drug treatment in primary care: randomised controlled trial. BMJ. 1999;319:612-615. [pmid: 10473477]. [pmcid: 28214].
134 Boyer P, Lecrubier Y. Atypical antipsychotic drugs in dysthymia: placebo controlled studies of amisulpride versus imipramine versus amineptine. Eur Psychiatry. 1996;11:135S-140S.
135 Mynors-Wallis L. Problem-solving treatment: evidence for effectiveness and feasibility in primary care. Int J Psychiatry Med. 1996;26:249-262. [pmid: 8976466].
136 Robins L, Helzer J, Croughan J, Ratcliff K. National Institute of Mental Health Diagnostic Interview Schedule. Arch Gen Psychiatry. 1981;38:381-391. [pmid: 6260053].
137 Kendrick T. Why can't GPs follow guidelines on depression? We must question the basis of the guidelines themselves (letter). BMJ. 2000;320:200-201. [pmid: 10642207].
138 Spitzer RL, Endicott J, Robins E. Research Diagnostic Criteria: Rationale and reliability. Arch Gen Psychiatry. 1978;35:773-782. [pmid: 655775].
139 Simon GE, Von Korff M, Heiligenstein JH, et al. Initial antidepressant choice in primary care. Effectiveness and cost of fluoxetine vs tricyclic antidepressants. JAMA. 1996;275:1897-1902. [pmid: 8648870].
140 Reynolds CF III, Frank E, Perel JM, et al. Nortriptyline and interpersonal psychotherapy as maintenance therapies for recurrent major depression: a randomized controlled trial in patients older than 59 years. JAMA. 1999;281:39-45. [pmid: 9892449].
141 Keller MB, McCullough JP, Klein DN, et al. A comparison of nefazodone, the cognitive behavioral-analysis system of psychotherapy, and their combination for the treatment of chronic depression. N Engl J Med. 2000;342:1462-1470. [pmid: 10816183].
142 Zigmond A, Snaith R. The Hospital Anxiety and Depression Scale. Acta Psychiatr Scand. 1983;67:361-370. [pmid: 6880820].
143 Jaycox LH, Reivich KJ, Gillham J, Seligman ME. Prevention of depressive symptoms in school children. Behav Res Ther. 1994;32:801-816. [pmid: 7993324].
144 Clarke GN, Hawkins W, Murphy M, Sheeber LB, Lewinsohn PM, Seeley JR. Targeted prevention of unipolar depressive disorder in an at-risk sample of high school adolescents: a randomized trial of a group cognitive intervention. J Am Acad Child Adolesc Psychiatry. 1995;34:312-321. [pmid: 7896672].
145 Lamb JM, Puskar KR, Sereika SM, Corcoran M. School-based intervention to promote coping in rural teens. MCN Am J Matern Child Nurs. 1998;23:187-194. [pmid: 9661327].
146 Reinecke MA, Ryan NE, DuBois DL. Cognitive-behavioral therapy of depression and depressive symptoms during adolescence: a review and meta-analysis. J Am Acad Child Adolesc Psychiatry. 1998;37:26-34. [pmid: 9444896].
147 Wood A, Harrington R, Moore A. Controlled trial of a brief cognitive-behavioural intervention in adolescent patients with depressive disorders. J Child Psychol Psychiatry. 1996;37:737-746. [pmid: 8894955].
148 Reynolds WM, Coats KI. A comparison of cognitive-behavioral therapy and relaxation training for the treatment of depression in adolescents. J Consult Clin Psychol. 1986;54:653-660. [pmid: 3534032].
149 Lewinsohn P, Clarke G, Hops H, Andrews J. Cognitive-behavioural treatment for adolescents. Behavior Therapy. 1990;21:385-401.
150 Lerner M, Clum G. Treatment of suicide ideators: a problem-solving approach. Behavior Therapy. 1990;21:403-411.
151 Kahn J, Kehle T, Jensen W, Clark E. Comparison of cognitive-behavioral, relaxation, and self-modeling interventions for depression among middle-school students. School Psychology Review. 1990;19:196-211.
152 Kazdin A, Bass D, Ayers W, Rodgers A. Empirical and clinical focus of child and adolescent psychotherapy needs. J Consult Clin Psychol. 1990;58:729-740. [pmid: 2292623].
153 Weisz J, Weiss B, Alicke M, Klotz M. Effectiveness of psychotherapy with children and adolescents: a meta-analysis for clinicians. Consul and Clin Psychol. 1987;55:542-549.
154 Berney T, Kolvin I, Bhate SR, et al. School phobia: a therapeutic trial with clomipramine and short-term outcome. Br J Psychiatry. 1981;138:110-118. [pmid: 7020816].
155 Kramer AD, Feguine RJ. Clinical effects of amitriptyline in adolescent depression. J Am Acad Child Psychiatry. 1981;20:636-644. [pmid: 7031113].
156 Petti TA, Law W. Imipramine treatment of depressed children: a double-blind pilot study. J Clin Psychopharmacol. 1982;2:107-110. [pmid: 7042769].
157 Preskorn SH, Weller EB, Weller RA. Depression in children: relationship between plasma imipramine levels and response. J Clin Psychiatry. 1982;43:450-453. [pmid: 7174621].
158 Kashani JH, Shekim WO, Reid JC. Amitriptyline in children with major depressive disorder: a double-blind cross-over pilot study. J Am Acad Child Psychiatry. 1984;23:348-351. [pmid: 6736501].
159 Geller B, Cooper TB, McCombs HG, Graham D, Wells J. Double-blind, placebo-controlled study of nortriptyline in depressed children using a "fixed plasma level" design. Psychopharmacol Bull. 1989;25:101-108. [pmid: 2672066].
160 Puig-Antich J, Perel JM, Lupatkin W, et al. Imipramine in prepubertal major depressive disorders. Arch Gen Psychiatry. 1987;44:81-89. [pmid: 3541830].
161 Bernstein GA, Garfinkel BD, Borchardt CM. Comparative studies of pharmacotherapy for school refusal. J Am Acad Child Adolesc Psychiatry. 1990;29:773-781. [pmid: 2228932].
162 Geller B, Cooper TB, Graham DL, Marsteller FA, Bryant DM. Double-blind placebo-controlled study of nortriptyline in depressed adolescents using a "fixed plasma level" design. Psychopharmacol Bull. 1990;26:85-90. [pmid: 2196631].
163 Hughes CW, Preskorn SH, Weller EB, Weller RA, Hassanein R, Tucker S. The effect of concomitant disorders in childhood depression on predicting treatment response. Psychopharmacol Bull. 1990;26:235-238. [pmid: 2236462].
164 Boulos C, Kutcher S, Marton P, Simeon J, Ferguson B, Roberts N. Response to desipramine treatment in adolescent major depression. Psychopharmacol Bull. 1991;27:59-65. [pmid: 1862207].
165 Geller B, Cooper TB, Graham DL, Fetner HH, Marsteller FA, Wells JM. Pharmacokinetically designed double-blind placebo-controlled study of nortriptyline in 6- to 12-year-olds with major depressive disorder. J Am Acad Child Adolesc Psychiatry. 1992;31:34-44. [pmid: 1537779].
166 Hazell P, O'Connell D, Heathcote D, Robertson J, Henry D. Efficacy of tricyclic drugs in treating child and adolescent depression: a meta-analysis. BMJ. 1995;310:897-901. [pmid: 7719178].
167 Kutcher S, Boulos C, Ward B, et al. Response to desipramine treatment in adolescent depression: a fixed-dose, placebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 1994;33:686-694. [pmid: 8056732].
168 Kye CH, Waterman GS, Ryan ND, et al. A randomized, controlled trial of amitriptyline in the acute treatment of adolescent major depression. J Am Acad Child Adolesc Psychiatry. 1996;35:1139-1144. [pmid: 8824057].
169 Sallee FR, Vrindavanam NS, Deas-Nesmith D, Carson SW, Sethuraman G. Pulse intravenous clomipramine for depressed adolescents: double-blind, controlled trial. Am J Psychiatry. 1997;154:668-673. [pmid: 9137123].
170 Birmaher B, Waterman GS, Ryan ND, et al. Randomized, controlled trial of amitriptyline versus placebo for adolescents with "treatment-resistant" major depression. J Am Acad Child Adolesc Psychiatry. 1998;37:527-535. [pmid: 9585655].
171 Klein RG, Mannuzza S, Koplewicz HS, et al. Adolescent depression: controlled desipramine treatment and atypical features. Depress Anxiety. 1998;7:15-31. [pmid: 9592629].
172 Geller B, Reising D, Leonard HL, Riddle MA, Walsh BT. Critical review of tricyclic antidepressant use in children and adolescents. J Am Acad Child Adolesc Psychiatry. 1999;38:513-516. [pmid: 10230182].
173 Colle LM, Belair JF, DiFeo M, Weiss J, LaRoche C. Extended open-label fluoxetine treatment of adolescents with major depression. J Child Adolesc Psychopharmacol. 1994;4:225-232.
174 Ghaziuddin N, Naylor MW, King CA. Fluoxetine in tricyclic refractory depression in adolescents. Depression. 1995;2:287-291.
175 Nguyen N, Biu B, Wettllesey S, DiGiacome D, Bui T. A pilot study: pattern analysis of fluoxetine in childhood depression. Psychopharmacol Bull. 1995;31.
176 Armitage R, Yonkers K, Cole D, Rush AJ. A multicenter, double-blind comparison of the effects of nefazodone and fluoxetine on sleep architecture and quality of sleep in depressed outpatients. J Clin Psychopharmacol. 1997;17:161-168. [pmid: 9169959].
177 Riggs PD, Coffman LM, Crowley TJ. Fluoxetine in drug-dependent delinquents with major depression: an open trial. J Child Adolesc Psychopharmacol. 1997;7:87-95. [pmid: 9334894].
178 Tierney E, Paramjit TJ, Llinas JF, Rosenberg L, Riddle MA. Sertraline for major depression in children and adolescents: preliminary clinical experience. J Child Adolesc Psychopharmol. 1995;5:13-27.
179 McConville BJ, Minnery KL, Sorter JT, West SA, Friedman LM, Christian K. An open study of the effects of sertraline on adolescent major depression. J Child Adolesc Psychopharmacol. 1996;6:41-51. [pmid: 9231298].
180 Ambrosini PJ, Wagner KD, Biederman J, et al. Multicenter open-label sertraline study in adolescent outpatients with major depression. J Am Acad Child Adolesc Psychiatry. 1999;38:566-572. [pmid: 10230188].
181 Rey-Sanchez F, Gutierrez-Casares JR. Paroxetine in children with major depressive disorder: an open trial. J Am Acad Child Adolesc Psychiatry. 1997;36:1443-1447. [pmid: 9334558].
182 Masi G, Marcheschi M, Pfanner P. Paroxetine in depressed adolescents with intellectual disability: an open label study. J Intellect Disabil Res. 1997;41:268-272. [pmid: 9219077].
183 Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry. 1997;58:146-152. [pmid: 9164424].
184 Simeon JG, Dinicola VF, Ferguson HB, Copping W. Adolescent depression: a placebo-controlled fluoxetine treatment study and follow-up. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14:791-795. [pmid: 2293257].
185 Emslie GJ, Rush AJ, Weinberg WA, et al. A double-blind, randomized, placebo-controlled trial of fluoxetine in children and adolescents with depression. Arch Gen Psychiatry. 1997;54:1031-1037. [pmid: 9366660].
186 Hughes CW, Emslie GJ, Crimson ML, et al. The Texas Children's Medication Algorithm Project: report of the Texas Consensus Conference Panel on Medication Treatment of Childhood Major Depressive Disorder. J Am Acad Child Adolesc Psychiatry. 1999;38:1442-1454. [pmid: 10560232].
187 Texas Department of Mental Health and Mental Retardation. The Texas Medication Algorithm Project. Available at: http://www.mhmr.state.tx.us/centraloffice/medicaldirector/tmapover.html. Accessed December 9, 1999.
188 American Academy of Child and Adolescent Psychiatrists. Practice parameters for the assessment and treatment of children and adolescents with depressive disorders. J Am Acad Child Adolesc Psychiatry. 1998;37:63S-83S. [pmid: 9785729].
189 First MB, Spitzer RL, Gibbon M, Williams JB. Structured Clinical Interview for DSM-IV Axis I Disorders-Patient Edition (SCID-I/P, Version 2. 0). New York, NY: New York State Psychiatric Institute. 1995. [pmcid: 441483].
190 Robins LN, Wing JK, Wittchen HU, et al. The Composite International Diagnostic Interview: An epidemiologic instrument suitable for use in conjunction with different diagnostic systems and in different cultures. Arch Gen Psychiatry. 1988;45:1069-1077. [pmid: 2848472].
191 Friedman RJ, Butler LF. Development and Evaluation of a Test Battery to Assess Childhood Depression. Ottawa, Canada: Health and Welfare Canada. 1979. [pmcid: 413150].
192 US Preventive Services Task Force. Guide to Clinical Preventive Services: An Assessment of the Effectiveness of 169 Interventions: Report of the U. S. Preventive Services Task Force. Baltimore, Md.: Williams & Wilkins. 1989. [pmcid: 361432].