# Discussion

## Major Findings

Depressive disorders are common in primary care settings and cause substantial morbidity and mortality. Multiple studies have documented that depressive disorders are often unrecognized or undertreated by "usual care" or nonsystematic approaches to diagnosis and therapy.^26,27^ The overlap between symptoms of depression and symptoms of physical illnesses may lead to unnecessary tests and treatments in an attempt to diagnose or treat complaints that are actually caused by the depression itself. Failure to recognize and treat depression can lead to increased or prolonged disability, morbidity, and mortality, at least for those patients with more severe illnesses. Patients with less severe illnesses appear less likely to be detected but also may benefit less from treatment.

In our systematic review, we have addressed several key questions and subquestions concerning screening accuracy in various populations, pharmacotherapy and psychotherapy in adults and children, and screening outcomes in adults. The quality of evidence on these questions is summarized in Table 16, which shows our ratings (of good, fair, or poor, as defined in Appendix C) for 3 important measures relating to a body of evidence for a given key question or linkage in the analytic framework (Figure 1, Chapter 1) -- aggregate internal validity, aggregate external validity, and coherence (ie, consistency).

Table 16: Summary of the Quality of Evidence for Key Questions

Key Question | | Aggregate Internal Validity | Aggregate External Validity | Coherence
1A | Screening Accuracy in Adults | Good | Good | Good
1B | Screening Accuracy in Elderly | Good | Fair - Good | Good
1C | Screening Accuracy in Children/Adolescents | Fair - Good | Fair - Good | Fair - Good
2A | Pharmacotherapy in Adults | Good | Good | Good
2B | Psychotherapy in Adults | Fair | Good | Good
2C | Pharmacotherapy in Children | Fair | Good | Poor
2D | Psychotherapy in Children | Good | Fair | Good
3 | Screening Outcomes in Adults | Good | Good | Fair-Poor

In our systematic review, we have shown that brief, accurate, and feasible screening tests are available for detecting depressive disorders in adults and the elderly. This reflects good evidence across the board for adults and good or fair-to-good evidence for the elderly. Recently tested shorter instruments appear to perform about as well as the longer versions evaluated in the previous 2 editions of the Guide to Clinical Preventive Services.^31,192^ Among the elderly, specific scales appear to improve detection compared with general scales.

In addition, effective pharmacologic and psychotherapeutic treatments are available for adult primary care patients with major depression (good evidence in all 3 measures). Treatment for adults with dysthymia also appears effective although the amount of data from primary care populations is smaller than for major depression. The available data for treatment of adults with dysthymia and minor depression are less well developed but suggestive of benefit as well. Educational interventions designed to improve the quality of care have shown success in improving treatment initiation, adherence, and outcomes.^ 129 ^

The accuracy of screening tests for depression in adolescents and children has been less well studied in primary care settings but available data suggest similar levels of performance (fair-to-good evidence on all 3 measures). Treatment for adolescents with cognitive-behavioral therapy has been shown to improve depression,^ 146 ^ with evidence judged to be good for internal validity and coherence and fair for external validity. The data for selective serotonin reuptake inhibitors (SSRIs) are mixed but suggestive of benefit, but tricyclic agents appear to be ineffective. The quality of the pharmacotherapy evidence for the pediatric age group is quite mixed, however (fair internal validity, good external validity, but poor coherence).

The overarching question for adult patients -- whether screening and subsequent treatment is superior to treatment based on usual means of diagnosis -- is controversial; evidence on aggregate internal and external validity is good, but the level of coherence in findings across these studies is only fair to poor. Data from several trials suggest that patients who are screened are more likely to be recognized as depressed and sometimes are more likely to be treated. The effect of screening on clinical outcomes, however, has been mixed when compared with the usual care provided in studies. Further support beyond identification appears to improve treatment adherence and outcomes. The recent study by Wells et al^ 101 ^ suggests that a simple 2-question screener, when coupled with a quality improvement process, can improve outcomes over 6 to 12 months in patients with a spectrum of depressive disorders.

## Benefits and Harms

The potential benefits of screening and treatment of depressive disorders include reduced morbidity and mortality, improved quality-of-life functioning, and employment. It may also lower expenditures on unnecessary health care. The potential harms of screening include false-positive screening results, the adverse effects of treatment, the adverse effects and costs of treatment for patients who are incorrectly identified as being depressed, and the potential adverse effects of labeling.

The trade-offs between benefits and harms are an important component of the decision to screen or not to screen for depression. We currently have insufficient information about the harms of screening (false positives and labeling) to create a balance sheet to inform the decision to screen.

## Future Research Needs

Despite a wealth of new studies concerning screening accuracy and the effectiveness of treatment for depression, key elements of the evidence base for depression screening remain insufficiently developed. The limitations are greater for children and adolescents than for adults, as reflected in Table 16. Nonetheless, additional research is needed across the age spectrum and in special populations, including the underserved and minority groups. For the adult and geriatric populations, especially those in primary care settings, further research on the identification and treatment of dysthymia and subsyndromal or "minor" depression will be a major step forward.

For all ages, outcomes to be considered should include persistent depressive symptoms and associated disability as well as appropriate outcome measures including functional status and quality of life. Such disability measures are a key element in documenting improvement for depressive illness and in reducing its staggering disease burden. In addition, investigators should examine health care utilization and ensure that their studies are sufficiently powered for detecting modest but clinically important differences.

Considerable additional research is needed for children and adolescents in both screening and treatment, particularly in primary care settings. The question of whether SSRIs are effective in adolescents and children should be addressed in additional sufficiently powered trials that are analyzed by intention to treat. Determining whether simple screening instruments can be accurate and are feasible for application in primary care settings or schools remains an important investigative step.

For both children and adults, more research is required about the harms of screening; these include issues relating to labeling, inappropriate treatment, failure to make the correct diagnosis, and unnecessary costs. We also need better information about the optimal means of addressing a positive screening test in real-world settings, including the ability of primary care providers to conduct further diagnostic assessment, initiate treatment, and optimally use psychiatric referral.