# Appendix D Evidence Tables and Specialized Glossary

## Glossary of Evidence Table Abbreviations Screening for Depression

AGECAT: Computerized diagnostic screening test

AMI: Amitriptyline

ARR: Absolute risk reduction

BDI: Beck Depression Inventory

CAGE: CAGE questionnaire

CAMDEX: Cambridge Examination for Mental Disorders of the Elderly

CBT: Cognitive behavior therapy

CES-D: Centers for Epidemiologic Studies Depression scale

CGI: Clinical Global Impressions

Cntrl: Control

COG: Cognitive therapy

CT: Cognitive treatment

DI: Diagnostic interview

DIS: Diagnostic interview schedule

DK: Don't know

DSM-IIIR: Diagnostic and Statistical Manual, 3rd Edition (Revised)

DUSOI: Duke University Severity of Illness Scale

dx: Diagnosis

EPDS: Edinburgh Postnatal Depression Scale

FP: Family practice

GAS: Global Assessment Score

GDS: Geriatric Depression Scale

GDS-S: Short form Geriatric Depression Scale

GHQ: General Health Questionnaire

GMSS: Geriatric Mental Status Schedule

GP: General Practice Patients

HAM-D: Hamilton Depression Rating Scale

HS: High school

HSCL-20: Hopkins Symptomatic Checklist-20

HV: Health Visitor Counseling

ICD 10: International Classification of Disease - 10th Revision

IDS: Inventory of Depressive Symptomatology

IPT: Interpersonal psychotherapy

ITT: Intention-to-treat

MADS: Montgomery-Asberg Depression Scale

MD: Medical Doctor (when under gold standard used)

MD-UC: Depression program for major depression

MD_UC: Usual care for major depression

mD-CT: Depression program for minor depression

mD-UC: Usual care for minor depression

MMSE: Mini-Mental State Exam

MOS: Medical Outcomes Study

NA: Not available

NNT: Numbers needed to treat

NOR: Nortriptyline

NOS: Not otherwise specified

NR: Not reported

NS: Not significant

OSI: Other Structured Interview

OTH: Other

PC: Private clinic

PD: Physician diagnosis

PHQ: Patient health questionnaire

Pl: Placebo

PROQSY: Self-administered computerized assessment

PS: Problem solving

PSE: Present State Exam

PS-GP: Problem solving by general practitioner

PS-N: Problem solving by nurse

QDIS: Quick Diagnostic Interview Schedule

RDC: Research Diagnostic Criteria

RRR: Relative risk reduction

SADS-L: Schedule for Affective Disorders and Schizophrenia, Lifetime Version

SCI: Structured clinical interview

SCID: Structure clinical interview for DSM-III-R (or -IV)

SD: Standard Deviation

SDS: Zung Self-Rating Depression Scale

SDDS: Symptom Drive Diagnostic System

SF-36: Short Form 36

SI: Structured Interview

SIP: Sickness Impact Profile

SSD: Subsyndromal Symptom Depression

SW: Social worker

TC: Telephone counseling

UC: Usual Care

VA: Veterans Administration / Department of Veterans Affairs

Evidence Table 1. Screening Accuracy for Depression Studies

Author, Year | Screening Setting | Age Range (years) | Other Inclusion Criteria | Conditions of Interest | Exclusions | Definition of Groups | Number of Subjects | Mean Age (years) | % Female | Ethnicity | Education | Test(s) Defined with Cut-Offs: (1): Test 1 (2): Test 2 (3): Test 3 (4): Test 4 | Primary Screening Test Evaluated | Gold Standard Used | Sensitivity | Specificity | LR+/LR− | Adequate Inclusion Criteria? | Appropriate Spectrum of Patients? | Gold Standard Applied to All Subjects? | Masked Assessors? | Aggregate Internal Validity | External Validity | Overall Quality
Williams et al, 1995^ 17 ^ | Primary Care: 3 different clinics | >30 | | Major Depession, Sub-syndromal depression | Current substance abuse, major psychiatric illness, known depression or anti-depressants, chronic pain, dementia | All | 221 | 60 (SD=12.7) | 32% | 38% White 9% Black 53% Hispanic | 9.5 mean years of education | (1): SDS for MDD: >.043 (2): SDS for SSD>.043 | SDS | DI: HAM-D, DIS: OSI: SCID, OTH: SF-36 | Test 1: 100% Test 2: 66% | Test 1: 72% Test 2: 79% | Test 1: 3.6/0 Test 2: 3.1/0.4 | Yes | Yes | Yes | NR | Good | Good | Good
Arthur et al, 1999^ 34 ^ | Primary care | >75 | | Depression | | All | 201 | 79 | 57% | NR | NR | (1):GDS 15: > 3 | GDS 15 | 968 | 100% | 72% | 3.6 / NA | Yes | Yes | Yes | Yes | Good | Good | Good
Banerjee et al, 1998^ 35 ^ | Community | >65 | Home care patients from Lewishon East in UK | Depression | Current psychiatric care | All | 214 | NR | NR | NR | NR | (1): Self-care (D): > 8 | Self-care (D) | GMS/ AGECAT | 90% | 53% | 1.9/0.19 | Yes | Yes | Yes | DK | Good | Good | Good
Bashir et al, 1996^ 36 ^ | Primary care | 18-74 | Attending an appointment at a study practice | Depression | | Grp 1: All Grp 2: Men Grp 3: Women | 129 | 34 | 62% | NR | NR | (1): GHQ: >3 (all) (2): GHQ: >3 (men) (3): GHQ: >3 (women) | GHQ | PROQSY (Computerized self-administered diagnostic review) | Test 1: 76% Test 2: 75% Test 3: 77% | Test 1: 74% Test 2: 68% Test 3: 78% | Test 1: 2.9/0.32 Test 2: 2.3/0.37 Test 3: 3.5/0.29 | Yes | Yes | Yes | No | Good | Good | Good
Beekman et al, 1997^ 37 ^ | Community | 55-85 | | Major Depression | | All | 487 | NR | 58% | NR | 55% HS grads | (1): CES-D: > 16 (2): CES-D: > 18 (3): CES-D: > 20 | CES-D | DIS | Test 1: 100% Test 2: 93.5% Test 3: 93.5% | Test 1: 53.3% Test 2: 65.6% Test 3: 73.5% | Test 1: 2.12/0 Test 2: 2.7/0.10 Test 3: 3.5/0.09 | Yes | Yes | Yes | DK | Good | Good | Good
Bird et al, 1987^ 38 ^ | Primary care | >65 | NR | Significantly depressed state | NR | Grp 1: Depressed Grp 2: Non-depressed | 75 | Grp 1: 72.4 (SD=4.7) Grp 2: 73.3 (SD=4.7) | Grp 1: 68% Grp 2: 65% | NR | NR | (1): Self-care (D):> 5 (2): Self-care (D):> 6 (3): Self-care (D):> 7 (4): Zung: >38 | Self-care (D) | MD | Test 1: 77% Test 2: 77% Test 3: 61% Test 4: ~ 87% | Test 1: 91% Test 2: 98% Test 3: 98% Test 4: ~ 76% | Test 1: 8.5/0.25 Test 2: 38.5/0.23 Test 3: 30.5/0.40 Test 4: 3.6/0.17 | Yes | Yes | Yes | DK | Fair | Fair | Good
Broadhead et al, 1995^ 39 ^ | Primary care | 18-70 | Able to read and write in English and scheduled to have a physician visit | Major Depression | | All | 388 | 39.4 (SD=12.4) | 73% | 98% White 0.3% Black 1.7% Other | NR | (1): SDDS-PC: NR | SDDS-PC | SCID-P | 90.40% | 77.20% | 4.0/0.12 | Yes | No | Yes, All patients who consented had gold standard exam, but only 41% of those screened had gold standard. | Yes | Fair | Good | Fair
Burnam et al, 1988^ 40 ^ | Primary care | NR | | Major Depression, Depression | | Primary care sample | 1,450 | 43 | 60% | 51% White 39% Hispanic | NR | (1): MOS screener: 0.060 | MOS screener | DIS | 86% | 95% | 17.2 / 0.15 | Yes | Yes | Yes | Yes | Good | Good | Good
D'Ath et al, 1994^ 41 ^ | Primary care | 65-90 | | Depression | Substance Abuse: DK, Suicidality: DK, Pregnancy: NA | Grp 1: Validation | 198 | 74.1 | 68% | NR | NR | (1):GDS 15: >5/>6 (2):GDS 10: >3/>4 (3):GDS 4: >2/>1 (4):GDS 1: | GDS | GMS | Test 1: 91%/78% Test 2: 93%/89% Test 3: 61%/93% Test 4: 59% | Test 1: 72%/82% Test 2: 63%/77% Test 3: 88%/63% Test 4: 75% | Test 1: 3.25/0.125 | Yes | Yes | Yes | Yes | Good | Good | Good
Fechner-Bates et al, 1994^ 42 ^ | Primary Care | 17-80 | | Major Depression | NR | Grp 1: All | 1,928 screened, 425 in study | 39.6 | 76.70% | 93% White | 62.4% HS grads | (1): CES-D > 16: for major depression (2): CES-D > 16: depression broadly defined (3): CES-D > 16: for dysthymia | CES-D | SCID within 14 days of CES-D | Test 1: 79.5% Test 2: 72% Test 3: 100% (9/9) | Test 1: 71.1% Test 2: 75.6% Test 3: NR | Test 1: 2.7/0.30 | Yes | No | Yes, Gold standard administered only to group selected to have confirmatory testing | NR | Fair | Good | Fair
Finlay-Jones et al, 1979^ 43 ^ | Primary care | Grp 1: 18-40 Grp 2: 18-65 | Women only | Major Depression | | Grp 1: General practice patients Grp 2: Medically ill patients | 197 | Grp 1: 28 (SD=5) Grp 2: 42 (SD=14) | Grp 1: 100% Grp 2: 100% | NR | NR | (1): GHQ: > 5 | GHQ | PSE | Grp 1: 75% (GP patients) Grp 2: 76% (medically ill patients) | Grp 1: 73% (GP patients) Grp 2: 71% (medically ill patients) | Grp 1: 2.8/0.34 (GP patients) Grp 2: 2.6/0.34 (medically ill patients) | Yes | Yes | Yes | No, team assessment of outcome, with one member aware of screening status | Fair | Good | Fair
Geisser et al, 1997^ 44 ^ | Pain clinic | NR | Duration of pain >3 months | Major Depression | | All | 132 | 40.7 (SD=11.2) | 71% | 92% White 5% Black 2% Hispanic | 82% HS grads | (1): CES-D: > 27 (2): BDI > 16 | CES-D, BDI | Interview by trained clinical psychologist using DSM-IV criteria | Test 1: 81.8% Test 2: 68.2% | Test 1: 72.7% Test 2: 78.4% | Test 1: 3.0/0.25 Test 2: 3.1/0.41 | Yes | Yes | Yes | DK | Good | Fair | Fair
Gerety et al, 1994^ 45 ^ | Nursing home | >60 | | Major Depression | English-speaking, >50% on MMSE (pro-rated) | All | 123 | 78.9 (SD=9.6) | 56% | 74% White NR Black 15% Hispanic | NR | (1): GDS: >11 (2): GDS-S >6 (3): Brief Carroll Dep. Rating Scale: >5 (4):CES-D: >16 | GDS CES-D Other | SCID | Test 1: 89% Test 2: 88% Test 3: 85% Test 4: 74% | Test 1: 68% Test 2: 62% Test 3: 77% Test 4: 70% | Test 1: 2.8/0.16 Test 2: 2.3/0.19 Test 3: 3.7/0.19 Test 4: 2.5 | Yes | Yes | Yes | NR | Good | Good | Good
Goldberg et al, 1970^ 46 ^ | Primary care | NR | | Major Depression, Depression, any depressive symptoms | | All | 200 | NR | 64% | NR | NR | (1): GHQ: > 12 | GHQ | MD | 95.80% | 87.80% | 7.9/0.05 | Yes | No | Yes | Yes | Fair | Good | Fair
Hendrie et al, 1995^ 47 ^ | Primary care | >60 yr | | Major Depression, Depression Minor depression | Prisoners, non-English speaking, hearing-impaired | All | 125 | 68 | 68.80% | NR White 63.4% Black NR Other | NR | (1): CES-D > 16 (2): CAMDEX (inclusive method) (3): CAMDEX (substitution) | CES-D | DSM-IIIR, SI: CAMDEX inclusive and substitutive methods | Test 1: 80% Test 2: 65% Test 3: 72% | Test 1: 91% Test 2: 87% Test 3: 86% | Test 1: 8.9 / 0.22 | Yes | Yes | No, only 45% of patients with CES-D >16 completed gold standard, but 81 subjects with CES-D <16 also completed the gold standard | Yes | Fair | Good | Fair
Holcomb et al, 1996^ 48 ^ | OB clinic | NR | Women already attending OB-GYN clinics | Current, remittent, no depression | | All women | 105 | 24.2 (SD=6.3) | 100% | 33% White 63% Black 4% Other | 66% HS grads | (1): BDI: > 16 | BDI | DIS | 83% (.56,.98) | 89% (.81,.95) | Test 1: 7.75/0.19 | Yes | Yes | Yes | Yes | Good | Good | Good
Hoyl et al, 1999^ 49 ^ | Geriatric clinic at VA hospital | 65-87 | Attending geriatric assessment clinic | Major Depression, Depressive NOS | | All | 74 | 74.6 | 1% | NR | 75.7% HS grads | (1): GDS 15: > 5 (2): GDS 5: > 2 (3): Single item: > 1 | GDS 15 and GDS 5 and single item | Prime MD mood module, MD | Test 1: 94% Test 2: 97% Test 3: 85% | Test 1: 82% Test 2: 85% Test 3: 65% | Test 1: 5.2/0.07 Test 2: 6.5/0.04 Test 3: 2.4/0.23 | Yes | Yes | Yes, The gold standard was the PRIME-MD based assessment (unblinded) | No | Fair | Good | Fair
Irwin et al, 1999^ 50 ^ | Community | NR | | Major Depression | Physical disorder leading to secondary depression | Grp 1: Patients from mental health research setting Grp 2: Community dwelling older adults from primary care practices | Grp 1: 83 Grp 2: 68 | Grp 1: 44.9 (SD=10.3) int. 40.0 (SD=12.8) control Grp 2: 72.0 (SD=7.0) | Grp 1: 50% int./ 42% control Grp 2: 48% | Grp 1: NR Grp 2: NR | Grp 1: NR Grp 2: NR | (1):CES-D: > 4 | CES-D | DSM-IV, SCID | Test 1: 99% Test 2: 100% | Test 1: 84% Test 2: 92% | Test 1: 6.2 / 0.01 Test 2: N/A | Yes | No | Yes | Yes | Fair | Fair | Fair
Klinkman et al, 1997^ 51 ^ | Primary care | NR | | Major Depression | | All | 425 | 39.6 | 77% | 93% | 62.4% HS grads | (1): CES-D > 16 (2): CES-D > 22 (3): MD ID (4): MD ID and CES-D > 16 | CES-D | OSI: SCID | Test 1: 81% Test 2: 61% Test 3: 35% Test 4: 31% | Test 1: 72% Test 2: 85% Test 3: 93% Test 4: 95% | Test 1: 2.9/.26 Test 2: 4.0/.46 Test 3: 4.9/.70 Test 4: 5.7/.73 | DK | No | Yes | DK | Fair | Good | Fair
Leon et al, 1996^ 52 ^ | Primary care | 18-70 | English speaking/writing | Major Depression | | All | 501 | 49.4 (SD=12.8) | 66% | 35% White 46% Black 9% Hispanic 9% Asian | NR | SDDS-PC: NA | SDDS-PC | Specific diagnosis manuals | 71% | 87% | 5.5/0.33 | Yes | Yes | Yes | Yes | Good | Good | Good
Leung et al, 1998^ 53 ^ | Primary care | NR | Taiwan Primary care patients with chronic medical problems and no known previous history of depression | Any depressive symptom | | All | 268 | 59 | 60% | 100% Asian | 31% HS grads | (1): Zung SDS: > 50 (2): Zung SDS: > 55 (3): Zung SDS: > 60 | Zung SDS | MD: Following DSM-IV criteria | Test 1: 100% Test 2: 66.7% Test 3: 44.4% | Test 1: 70.7% Test 2: 90.2% Test 3: 90.2% | 6.8/0.37 | Yes | Yes | Yes | Yes | Good | Good | Good
Lewinsohn et al, 1997^ 54 ^ | Community | >50 | Licensed drivers | Major Depression, Depression | | All | 1,005 | 63.9 (SD=7.9) | 58% | Blank | 94% HS grads | (1): CES-D: > 12 (2): brief CES-D: > 4 | CES-D, brief CES-D | DI: RDC, DSM-IIIR OTH: SADS-L | Test 1: 76% Test 2: 80% | Test 1: 77% Test 2: 80% | Test 1: 3.3/.31 Test 2: 4/.25 | Yes | No | Yes, analyses based on 1,005/1,554 who completed the diagnostic interview | DK | Fair | Good | Fair
Lustman et al, 1997^ 55 ^ | Special diabetes clinic with patients recruited from community | Blank | Patients with poorly controlled diabetes | Major Depression | | Grp 1: All Grp 2: Depressed Grp 3: Non-depressed | 172 | Grp 1: 48 (SD=13.6) (all) Grp 2: 43.2 (SD=13.0) (depressed) Grp 3: 50.7 (SD=13.1) (non-depressed) | Grp 1: 48% Grp 2: 56% Grp 3: 43% | Grp 1: 84% White/ 15% Black/ 1% Other Grp 2: 89% White/ 11% Black Grp 3: 82% White/ 16% Black/ 2% Other | Grp 1: 13.7±2.6 years Grp 2: 12.9±2.0 years Grp 3: 14.1±2.7 years | (1): BDI: > 13 | BDI | DIS | 85% | 88% | Test 1: 7.1/0.17 | Yes | Yes, sample drawn from a population of trial enrolees | Yes | Yes | Good | Fair | Fair
Lyness et al, 1997^ 56 ^ | Primary care | >60 | | Major Depression | | All | 130 | 71.0 (SD=6.8) | 58.50% | 97.7% White 2.3% Black | 13.7 mean years | (1): CES-D: > 21 (2): GDS: > 10 (3): GDS-S: > 5 | CES-D, GDS, GDS-S | DI: SCID | Test 1: 92/40 (major/minor) Test 2: 100/70 Test 3: 92/80 | Test 1: 87/82 (major/minor) Test 2: 84/80 Test 3: 81/78 | Test 1: 7.1 / 0.09 | Yes | No | No | DK | Fair | Good | Fair
Myers and Weissman, 1980^ 57 ^ | Community clinic | >18 | | Major Depression OTH: Minor depression | | All | 515 | NR | 57% | 89.6% White 10.4% Black | NR | (1): CES-D: > 16 (2): CES-D: > 17 (3): CES-D: > 21 (4): CES-D: > 16 (minor depression) | CES-D for MDD CES-D for minor depression | DI: SADS-RDC | Test 1: 63.6% Test 2: 63.6% Test 3: 54.5% Test 4: 23% | Test 1: 93.9% Test 2: 94.4% Test 3: 95.9% Test 4: 92% | 10.4/0.39 | Yes | Yes | Yes | DK | Good | Good | Good
Nagel et al, 1998^ 58 ^ | Primary care | >18 | | Major Depression; Dysthymia | | Grp 1: Training center Grp 2: Community | Grp 1: 566 Grp 2: 457 | Grp 1: 47.2 Grp 2: 46.1 | Grp 1: 66% Grp 2: 70% | Grp 1: 78.6% White 19.2% Black Grp 2: 93.4% White 4.6% Black | Grp 1: 89% HS graduates Grp 2: 87% HS graduates | (1): MOS (2): MOS | MOS | DIS | Test 1: 88% Test 2: 100% | Test 1: 72% Test 2: 77% | Test 1: 3.1/0.17 Test 2: 4.3/0 | Yes | Yes | Yes | Yes | Good | Good | Good
Neal and Baldwin, 1994^ 59 ^ | Geriatric outpatient clinic | >65 | Consecutive new patients | Depression | Severe cognitive impairment, unable to give consent | NR | 45 | 77 | 62% | NR | NR | (1): GDS >11 (2): GDS >4 (3): MD detection (4): short GDS >5 | GDS | SI: GMSS | Test 1: 83% Test 2: 67% Test 3: 40% Test 4: 71% | Test 1: 80% Test 2: 80% Test 3: Blank Test 4: 80% | Test 1: 4.15/.21 Test 2: 3.35/.41 Test 3: Blank Test 4: 3.55/.36 | Yes | Yes | Yes | DK | Good | Good | Good
Okimoto et al, 1982^ 60 ^ | VA Primary care | >60 | VA patients | NR | NR | NR | 55 | Grp 1: 69.4 (SD=8.1) Grp 2: same | Grp 1: 2% Grp 2: same | Grp 1: NR | Grp 1: NR | (1): Zung: 60 (2): Popoff: not given | SDS | Physician diagnosis based on DSM-IIIR | Test 1: 76% Test 2: 88% | Test 1: 82% Test 2: 61% | Test 1: 4.2/.29 Test 2: 2.3/.20 | DK | Yes | No | Yes | Fair | Good | Fair
Parkerson and Broadhead, 1997^ 61 ^ | Primary care | 18-64 | Clinic attendees | Major Depression & Dysthymia | NR | Duke AD | 481 | 36.9 (SD=10.9) | 72% | 73% White NR Black NR Other | 93% HS grads | (1): Duke-AD >30 | Duke AD | DIS (DSM-IIIR based) | Test 1: 81% | Test 1: 64% | Test 1: 2.25/.30 | Yes | Yes | Yes | NR | Good | Good | Good
Salokangas et al, 1995^ 62 ^ | Primary care | 18-64 | | Severe depression | | All subjects | 436 | NR | NR | NR | NR | (1): DEPS: > 9 | DEPS | PSE (Present state exam) | 74% | 85% | 4.9 / 0.31 | Yes | Yes | Yes | NR | Good | Good | Good
Schulberg et al, 1985^ 63 ^ | Primary care | NR | New patients at 3 primary care practices and 3 community MH sites | Multiple categories | | Primary care patients | 294 | NR | NR | NR | NR | (1): CES-D > 16 (2): CES-D > 27 (3): MD dx | CES-D | DIS | Test 1: 96.3% Test 2: 89% Test 3: 26% | Test 1: 38.6% Test 2: 70% Test 3: 98% | Test 1: 1.6/.10 Test 2:2.97/.16 Test 3: 13/.75 | Yes | No | Yes, only those who agreed to participate in the diagnostic interview are included in the final sample | Yes | Fair | Good | Fair
Spitzer et al, 1999^ 64 ^ | Primary care | >18 | | Major Depression OTH: Any mood disorder | | All | 585 | 46 (SD=17.2) | 66% | 79% White 13% Black 4% Hispanic | 25% College graduates | (1): PHQ: NR (2): PHQ: NR | PHQ | Mental health professional telephone interview | Test 1: 73% Test 2: 61% | Test 1: 98% Test 2: 94% | Test 1: 36/0.28 Test 2: 10.2/0.41 | Yes | Yes | Yes | Yes | Good | Good | Good
Steer et al, 1999^ 65 ^ | Primary care | NR | NR | Major Depression | | All patients | 120 | 58.4 (SD=15.5) | 50% | 86% White 9% Black 2.5% Hispanic 2.5% Asian | NR | (1): BDI-PC: > 4 | BDI-PC | Mood module of prime-MD | 97% (82-99) | 99% (94-99) | Test 1: 97 / 0.03 | Yes | Yes | Yes, mood module of PRIME-MD used as criteria standard | Yes | Fair | Good | Fair
Turk and Okifuji, 1994^ 66 ^ | Pain clinic | NR | | Major Depression; Dysthymia | | Grp 1: Depressed Grp 2: Non-depressed | Grp 1: 50 Grp 2: 50 | Grp 1: 40.2 Grp 2: 43.7 | Grp 1: 70% Grp 2: 62% | Grp 1: 88% White Grp 2: 90% White | Grp 1: 88% HS graduates Grp 2: 88% HS graduates | CES-D: > 16 | CES-D | Psychologist using DSM-IIIR | 86% | 50% | 1.72/0.28 | Yes | No | Yes | Yes | Fair | Fair | Fair
Upadhyaya and Stanley, 1997^ 67 ^ | Primary care | 65-90 | | Depression | NR | Patients attending health center | 72 | 71 (SD=4.6) | 49% | NR | NR | (1): HAD-D: > 9 (2): Self-care: > 6 | Other | GMS-AGECAT | Test 1: 70% Test 2: 95% | Test 1: 87% Test 2: 86% | Test 1: 5.38/.34 Test 2: 6.8/.06 | Yes | Yes | Yes | Yes | Good | Good | Good
van Marwijk et al, 1995^ 68 ^ | Primary care | 65-94 | Consecutive patients invited to participate | Major Depression; Dysthymia | MD assessment of fitness to participate | FP patients | 586 | 73.5 | 60% | NR | NR | (1):GDS 30: <11/> 11 (2):GDS 15: <3/> 3 (3):GDS 10: <3/> 3 (4):GDS 4: <2/> 2 | GDS | DIS | Test 1: 55% Test 2: 67% Test 3: 52% Test 4: 67% | Test 1: 86% Test 2: 73% Test 3: 83% Test 4: 66% | Test 1: 3.9/0.52 Test 2: 2.48/1.22 Test 3: 3.06/0.7 Test 4: 1.97/0.5 | Yes | Yes | Yes | NR | Good | Good | Good
Von Korff et al, 1987^ 69 ^ | Primary care | >18 | Visit between 12/81-3/21/82 | Major Depression OTH: Depression and anxiety | Living far from clinic; participation in another study | All | 809 | NR | 68% | 16.6% White 83.4% Non-White | 23.7% HS grads | (1): GHQ: > 5 (2): MD assessment of "mental disorder" | GHQ | DIS | Test 1: 78.5% Test 2: 74.8% | Test 1: 66% Test 2: 72% | Test 1: 2.3/.33 Test 2: 2.7/.35 | Yes | Yes | Yes | DK | Good | Good | Good
Weyerer et al, 1999^ 70 ^ | Old age home and a psychogeriatric clinic | NR | | OTH: Depression | | All | 71 | NR | NR | NR | NR | (1): EBAS DEP: >2 (2): EBAS DEP: >3 (3): EBAS DEP: <4 | EBAS | Physician or psychiatric nurse diagnosis | Test 1: 100% Test 2: 100% Test 3: 93.3% | Test 1: 47% Test 2: 67.7% Test 3: 85.3% | Test 1: 2.1/0 Test 2: 3.0/0 Test 3: 6.2/0.08 | No | No | Yes | Yes | Fair | Fair | Fair
Whooley et al, 1997^ 71 ^ | VA urgent care clinic | 21-89 | Consecutive patients attending urgent care clinic | Major Depression | Bipolar Disorder, too delusional/intoxicated, schizophrenia | All | 590 to 536 | 53 (SD=14.0) | 3% | 55% White 29% Black 8% Hispanic 6% Asian 2% Other | 86% HS grads | (1): New 2-item (2): CES-D:>16 (3): Short CES-D: 10 (4): BDI: 10 (5): Short BDI: 5 (6): MOS: 0.060 (7): SDDS-PC: 2 | CES-D BDI MOS Other | DI: QDIS DSM-IIIR | Test 1: 96% Test 2: 93% Test 3: 90% Test 4: 89% Test 5: 92% Test 6: 93% Test 7: 96% | Test 1: 57% Test 2: 69% Test 3: 72% Test 4: 64% Test 5: 61% Test 6: 72% Test 7: 51% | Test 1: 2.2/0.07 Test 2: 3/0.10 Test 3: 3.2/0.14 Test 4: 2.5/0.17 Test 5: 2.4/0.13 Test 6: 3.3/0.10 Test 7: 2/0.08 | Yes | Yes | Yes | NR | Good | Good | Good
Wickberg and Hwang, 1996^ 72 ^ | Post-partum women | >18 | Swedish-speaking women | Major Depression | Already in treatment | All | 128 | NR | 100% | NR | NR | (1): EPDS: > 11.5 (2): EPDS: > 12.5 | EPDS | Clinical psychologist using DSM-IIIR | Test 1: 96% Test 2: 85% | Test 1: 49% Test 2: 63% | Test 1: 2.34/2.30 Test 2: 0.08/0.24 | Yes | Yes | Yes | Yes | Good | Good | Good
Zich et al, 1990^ 73 ^ | Primary Care | >18 | Random sample of pateints from general internal medicine clinic | Major Depression | DK | Grp 1: CES-D (34) Grp 2: BDI (31) Grp 3: All screening participants (475) | 475 | All: 57 | All: 63% | All: 50% White 20% Black 15% Hispanic 12% Asian 3% Other | Grp 1: NR | (1): CES-D > 16 (2): CES-D > 27 (3): BDI > 10 (4): BDI > 16 | CES-D | DIS | Test 1: 100% Test 2: 100% Test 3: 100% Test 4: 100% | Test 1: 53% Test 2: 81% Test 3: 75% Test 4: 89% | Test 1: 2.13/-infinity Test 2: 5.3/infinity Test 3: 4.0/infinity Test 4: 9.1/infinity | Yes | No | No | DK | Fair | Fair | Fair

Evidence Table 2. Pharmacologic Treatment in Depression Studies

Author, Year | Treatment Setting | Recruitment Setting | Conditions of Interest | How Diagnosis Made | Exclusions | Definition of Intervention | Study Duration | No. of potential subjects screened, randomized, analyzed | Definition of Population (inclusion): | Definition of Study Groups | Mean Age (years) | % Female | Ethnicity | Baseline Severity of Depression | Baseline QOL/functional status measure(s) | Adherence Measured: Yes/No If yes, how/results? | Outcome Data Defined: (1) Main 1 (2) Sec. 2 | Outcome Data Main 1: | Outcome Data Sec 2: | Summary Measures: RRR Main Outcome (95% CI or P value) | Summary Measures: ARR Main Outcome (95% CI or P value) | Summary Measures: NNT (over time) | Adequate Inclusion Criteria? | Similar attrition between groups? | Adequate Randomization & Concealment? | Intention to Treat Analysis? | Internal Validity? | External Validity? | Overall Quality?
Appleby et al, 1997^ 74 ^ | Primary Care | OB wards of 2 hospitals in UK | Major depression or minor depression (post-partum) | SI: Revised clinical interview schedule, MD: RDC, OTH: Edinburgh postnatal depression scale | Substance abuse, suicidal, serious medical illness, breastfeeding, dysthymia, tx-resistant depression, psychosis | Pharmacotherapy (fluoxetine) with 1 or 6 sessions CBT vs placebo with 1 or 6 sessions CBT | 12 weeks | Eligible: 2,978 Screened: 2,395 Randomized: 87 Analyzed: 87 | Female, childbearing, duration of symptoms: 2 weeks, women 6-8 weeks Postpartum | Grp1: Fluoxetine+1session CBT Grp 2: Fluoxetine+ 6 session CBT Grp 3: Pl+1 session CBT Grp 4: Pl+ 6 session CBT | Grp 1: 25.7 Grp 2: 26.6 Grp 3: 23.1 Grp 4: 26.0 | 100% | NR | Scale: HAM-D Grp 1: 14.4 Grp 2: 14.0 Grp 3: 14.0 Grp 4: 13.8 | NR | No | (1): % change in Hamilton Scores at 12 weeks (intention-to-treat) | Grp 1 and Grp 2 (Fluoxetine): 66.9% decrease in HAM-D Grp 3 and Grp 4 (Placebo): 54.0% decrease in HAM-D | NR | NA | NA | NA | Yes | Yes | Yes | Yes | Fair | Fair | Fair
Mynors-Wallis et al, 2000^ 75 ^ | Primary Care or patient's home | Primary Care | Major depression | PD DI: RDC OTH: HAM-D > 13 | Current substance abuse, suicidal, serious medical illness, current treatment for depression | Psychotherapy (6 tx sesions of problem-solving tx) or drug tx (6 sessions with Fluoxetine or Paroxetine) vs combination of psychotherapy and medication (12 sessions) | 52 weeks | Screened: 241 Randomized: 151 Analyzed: 151 | Both female and male, 18-65, duration of symptoms: >4 weeks, off medications >4 weeks | Grp 1: B: Problem-solving by GP (PS-GP) Grp 2: B: Problem-solving by Nurse (PS-N) Grp 3: D:Fluoxetine or Paroxetine (Drug) Grp 4: OTH: Combination of drug and PS-N (Combo) | Grp 1: 36 Grp 2: 33 Grp 3: 34 Grp 4: 35 | Grp 1: 85% Grp 2: 68% Grp 3: 86% Grp 4: 69% | NR | Scale: HAM-D Grp 1: 20.5 Grp 2: 20.5 Grp 3: 20.2 Grp 4: 19.8 | Scale: Social adjustment scale Grp 1: 29.6 Grp 2: 28.6 Grp 3: 29.3 Grp 4: 29.0 | No | (1) % recovered at 12 weeks (HAM-D <7) (2) % recovered at 52 weeks (HAM-D <7) | Grp 3 (Drug): 67% recovered at 12 weeks Group 1 (PS-GP) 51% recovered Grp 2 (PS-N): 54% recovered Grp 4 (Combo): 60% recovered No significant difference between groups | Grp 1 (PS-GP): 62% recovered Grp 2 (PS-N): 56% recovered Grp 3 (Drug): 56%% recovered at 52 weeks Grp 4 (Combo): 66% recovered No significant difference between groups | NA: difference among treatments insignificant | NA | NA | Yes | No: 36% PS-GP, 22% PS-N, 17% Drug, 17% Combo | Yes | Yes | Good | Good | Good
Malt et al, 1999^ 76 ^ | Primary Care | Primary Care | 2 weeks symptons of "severe enough to require treatment" >3 CGI >20 MADS | DI: MADS OTH: CGI severity OTH: DSM-III R checklist | Bipolar, >40 MADS, current depression >1 yearr current alcohol abuse, severe suicidality, non-responding to adequate drug tx | Drug treatment: sertraline (S) vs mianserin (M) vs placebo for 24 weeks | 24 weeks | Screened: NR Randomized: 372 Analyzed: 372 S=122, M=121 P=129 | Consecutive pts. 18-79 years in Norway | Grp 1: Placebo (Pl)(129) Grp 2: Sertraline (S) (122) Grp 3: Mianserin (M) (121) | Grp 1: 47.8 Grp 2: 48.6 Grp 3: 48.2 | Grp 1: 71.0% Grp 2: 78.0% Grp 3: 70.0% | NR | Scale: MADS S = 26.8 M = 26.8 P = 26.5 | Scale: CGIS S = 4.1 M = 4.0 P = 4.0 | Yes, pill count, drug level | (1): Treatment Response (2): Change MADS (3): Complete response for 1st time depressed (4): Complete response pts. with reoccurrence | Clinical remission: (1) 50% reduction in MADS, (2) CGI global of 1, 2, or 3, and (3) CGI improved 1 or 2 Grp 1 (Pl): 47% remission, OR= 1.0 Grp 2 (S): 61% remission, 0.56 (.33,.96) Grp 3 (M): 54% remission, 0.75 (.44, 1.27) | Grp 1: −12.5 Grp 2: −14.9 Grp 3: −15.5 | Sertraline 44% (4%, 67%), Mianserin 25% (+27%, 56%) | 14% | 7 (for sertraline) | Yes | No 29% placebo, 16% S, 14% M | Yes | Yes | Good | Good | Good
Mynors-Wallis et al, 1995^ 77 ^ | Primary Care or patient's home | Primary Care | Major depression | DI: HAM-D OTH: RDC | Bipolar disorder, substance abuse, suicidal, serious medical illness, current tx for depression | Psychotherapy (6 tx sesions of problem-solving tx) or drug tx (AMI) vs placebo | 12 weeks | Screened: 107 Randomized: 91 Analyzed: 82 | Both female and male, 18-65, duration of symptoms: >2 weeks | Grp 1: B: Problem-solving (PS) Grp 2: D: Amitriptyline (AMI) Grp 3: OTH: Placebo (Pl) | Grp 1: 37.3 Grp 2: 37.2 Grp 3: 37.0 | Grp 1: 83.3% Grp 2: 77.4% Grp 3: 70.0% | NR | Scale: HAM-D Grp 1: 19.4 Grp 2: 19.1 Grp 3: 18.4 | Scale: Social adjustment scale Grp 1: 22.3 Grp 2: 23.4 Grp 3: 21.3 | Yes, counting capsules | (1) Recovery at 12 weeks vs placebo (2): Change in depression severity at 12 weeks vs placebo (HAM-D) (3): Change in depression severity at 12 weeks vs drug (HAM-D) (4): Change in soc adjust scale vs placebo | Recovery at 12 weeks: Grp 2 (AMI): 52% Grp 3 (Pl): 27% | Grp 2 vs placebo: 3.75 (95%CI −0.59-8.09) | Recovery at 12 weeks (HAM-D) AMI vs placebo: 0.93 | 25% | 4.00 | Yes | Yes | Yes | No, analyzed only those completing at least 4 sessions | Good | Good | Good
Schulberg et al, 1996^ 78 ^; Brown et al, 1996^ 79 ^; Coulehan et al, 1997^ 80 ^ | Primary Care | Primary Care | Major depression | DI: CES-D, SI: DIS depression section, OTH: HAM-D | Bipolar disorder, current substance abuse, suicidal, pregnancy, serious medical illness, current tx for depression | Drug tx (NOR, weekly/monthly visits) or psychotherapy (16 weeks of IPT) vs UC | 32 weeks | Screened: 7,652 Randomized: 276 Analyzed: 276 | Both female and male, 18-64, duration of symptoms: >2 weeks | Grp 1: D: NOTHR Grp 2: B: IPT Grp 3: OTH: UC | Grp 1: 38.6 Grp 2: 37.1 Grp 3: 38.6 | Grp 1: 80.2% Grp 2: 82.8% Grp 3: 87.0% | Grp 1: 59.3% white Grp 2: 53.8% white Grp 3: 53.3% white | Scale: CES-D Grp 1: 37.3 Grp 2: 36.7 Grp 3: 48.8 | Scale: GAS Grp 1: 50.6 Grp 2: 50.7 Grp 3: 48.8 | Yes, NOR blood level | (1): ITT repeated measures anova (HAM-D) over 8 months (2): % recovered at 8 months, ITT (3): % recovered at 8 months, tx completers | Grp 1 (NOR) vs Grp 3 (UC): NOR > UC Grp 1 (NOR) vs Grp 2 (IPT): NOR not different from IPT | Grp 1 (NOR): 48% Grp 3 (UC): 18% | NOR vs UC (intention to treat): 1.67 NOR vs UC (tx completers): 2.35 | NOR vs UC (intention to treat): 30% NOR vs UC (tx completers): 47% | NOR vs UC (intention to treat): 3.3 NOR vs UC (tx completers): 2.13 | Yes | Yes | Yes | Yes | Good | Good (but high intensity) | Good
Scott et al, 1992^ 81 ^ | Primary Care | Primary Care | Major Depression | Physician diagnosis confirmed by SCI (DSM-III-R) | Current substance abuse, suicidal, OTH: Psychotic illness | Drug tx (Amitriptyline), CT by psychologist (weekly up to 16 weeks), or counseling by SW (weekly up to 16 weeks) vs UC | 16 weeks | Screened: 143 Randomized: 121 Analyzed: 113 | Both female and male, 18-65, duration of symptoms: 2 weeks | Grp 1: AMI Grp 2: COG Grp 3: SW counseling Grp 4: UC | Grp 1: 30.6 Grp 2: 28.8 Grp 3: 36.2 Grp 4: 31.6 | Grp 1: 61.3% Grp 2: 83.3% Grp 3: 83.3% Grp 4: 63.7% | NR | Scale: HAM-D Grp 1: 18.2 Grp 2: 18.3 Grp 3: 15.7 Grp 4: 19.7 | NR | No | (1): Change in HAM-D(depressive severity) at 16 weeks vs UC (2): Percent recovered at 16 weeks (HAM-D) | Grp 1 (AMI) vs Grp 4 (UC): −0.4 | Grp 1 (AMI): 58% Grp 4 (UC): 48% | AMI vs UC: % recovered at 16 weeks: 20.8% | 10% | 10.00 | Yes | Yes | Yes | No, analyzed only those beginning treatment | Fair | Fair | Fair

Evidence Table 3. Psychotherapeutic Treatment for Depression Studies

Author, Year | Treatment Setting | Recruitment Setting | Conditions of Interest | How Diagnosis Made | Exclusions | Definition of Intervention: | Study Duration | No. of potential subjects screened, randomized, analyzed | Definition of Population (inclusion) | Definition of Study Groups | Mean Age (years) | % Female | Ethnicity | Baseline Severity of Depression | Baseline QOL/functional Status Measure(s) | Adherence Measured: Yes/No If yes, how/results? | Outcome Data Defined: (1) Main 1 (2) Sec. 2 | Outcome Data Main 1: | Outcome Data Sec 2: | Summary Measures: RRR Main Outcome (95% CI or P value) | Summary Measures: ARR Main Outcome (95% CI or P value) | Summary Measures: NNT (over time) | Adequate Inclusion Criteria? | Similar Attrition between groups? | Adequate Randomization & Concealment? | Intention to Treat Analysis? | Internal Validity? | External Validity? | Overall Quality?
Appleby et al, 1997^ 74 ^ | Primary Care | OTH: OB wards of 2 hospitals in UK | Major depression or minor depression (Post-partum) | SI: Revised clinical interview schedule, MD: RDC, OTH>: Edinburgh postnatal depression scale | Substance abuse, suicidal, serious medical illness, breastfeeding, dysthymia, tx-resistant depression, psychosis | Pharmacotherapy with 1 or 6 sessions CBT; placebo with 1 or 6 sessions CBT | 12 weeks | Screened: 2,978 Randomized: 87 Analyzed: 87 | Female, Childbearing, Duration of symptoms: 2 weeks, Women 6-8 weeks postpartum | Grp 1: Fluoxetine, T: 1 session CBT Grp 2: Fluoxetine, T: 6 session CBT Grp 3: Placebo, T: 1 session CBT Grp 4: Placebo, T: 6 session CBT | Grp 1: 25.7 Grp 2: 26.6 Grp 3: 23.1 Grp 4: 26.0 | 100% | NR | Scale: HAM-D Grp 1: 14.4 Grp 2: 14.0 Grp 3: 14.0 Grp 4: 13.8 | NR | No | (1): % change in Hamilton Scores at 12 weeks (intention-to-treat), immediately post-treatment | Grp 2 and Grp 4 (6 sessions): 64.0% decrease in HAM-D Grp 1 and Grp 3 (1 session): 57.7% decrease in HAM-D | NR | NA | NA | NA | Yes | Yes | Yes | Yes | Fair | Fair | Fair
Mynors-Wallis et al, 2000^ 75 ^ | Primary Care or patient's home | Primary Care | Major depression | PD DI: RDC OTH: HAM-D > 13 | Current substance abuse, suicidal, serious medical illness, current treatment for depression | Psychotherapy (6 tx sesions of problem-solving tx) or drug tx (6 sessions with Fluoxetine or Paroxetine) vs. combination of psychotherapy and medication (12 sessions) | 52 weeks | Screened: 241 Randomized: 151 Analyzed: 151 | Both female and male, 18-65, duration of symptoms: >4 weeks, off medications >4 weeks | Grp 1: B: Problem-solving by GP (PS-GP) Grp 2: B: Problem-solving by Nurse (PS-N) Grp 3: D:Fluoxetine or Paroxetine (Drug) Grp 4: OTH: Combination of drug and PS-N (Combo) | Grp 1: 36 Grp 2: 33 Grp 3: 34 Grp 4: 35 | Grp 1: 85% Grp 2: 68% Grp 3: 86% Grp 4: 69% | NR | Scale: HAM-D Grp 1: 20.5 Grp 2: 20.5 Grp 3: 20.2 Grp 4: 19.8 | Scale: Social adjustment scale Grp 1: 29.6 Grp 2: 28.6 Grp 3: 29.3 Grp 4: 29.0 | No | (1) % recovered at 12 weeks (HAM-D <7) (2) % recovered at 52 weeks (HAM-D <7) | Grp 1 (PS-GP): 51% recovered at 12 weeks Grp 2 (PS-N): 54% recovered Grp 3 (Drug): 67% recovered Grp 4 (Combo): 60% No significant difference between groups | Grp 1 (PS-GP): 62% recovered at 52 weeks Grp 2 (PS-N): 56% recovered Grp 3 (Drug): 56%% recovered Grp 4 (Combo): 66% recovered No significant difference between groups | NA: difference among treatments insignificant | NA | NA | Yes | No: 36% PS-GP, 22% PS-N, 17% Drug, 17% Combo | Yes | Yes | Good | Good | Good
Mynors-Wallis et al, 1995^ 77 ^ | Primary Care OR patient's home | Primary Care | Major Depression | HAM-D, MD, RDC | Bipolar disorder, substance abuse, suicidal, serious medical illness, current tx for depression | Psychotherapy (6 tx sessions of problem-solving tx) or pharmacothx vs. UC | 12 weeks | Screened: 107 Randomized: 91 Analyzed: 82 | Both female and male, 18-65 years, duration of symptoms: > 2 weeks | Grp 1: B: PS Grp 2: D: AMI Grp 3: OTH: Pl | Grp 1: 37.3 Grp 2: 37.2 Grp 3: 37.0 | Grp 1: 83.3% Grp 2: 77.4% Grp 3: 70.0% | NR | Scale: HAM-D Cut-off: > 13 Grp 1: 19.4 Grp 2: 19.1 Grp 3: 18.4 | Scale: Social adjustment scale Grp 1: 22.3 Grp 2: 23.4 Grp 3: 21.3 | Yes, counting capsules | (1) Recovery at 12 weeks (immediately post-tx) (2): Change in depr severity at 12 weeks vs placebo (HAM-D) | Recovery at 12 weeks Grp 1 (PS): 60.0% Grp 3 (Pl): 27.0% | Grp 1 (PS) vs Grp 3 (Pl): 4.69 (95% CI 0.41-8.96) | Recovery at 12 weeks (HAM-D) (1): PS vs. placebo: 1.22 | 33% | 3 | Yes | Yes | Yes | No; analyzed only those completing at least 4 sessions | Good | Good | Good
Schulberg et al, 1996^ 78 ^; Brown et al, 1996^ 79 ^; Coulehan et al, 1997^ 80 ^ | Primary Care | Primary Care | Major depression | DI: CES-D, SI: DIS depression section, OTH: HAM-D | Bipolar disorder, substance abuse, suicidal, pregnancy, serious medical illness, prior tx for depression, current tx for depression | Drug tx (NOR, weekly-monthly visits) or psychotherapy (12-16 sessions of IPT) vs. UC | 8 months | Screened: 7,652 Randomized: 276 Analyzed: 276 | Both female and male, 18-64 years, duration of symptoms: > 2 weeks, no correct tx for mood disorder | Grp 1: NOR Grp 2: IPT Grp 3: UC | Grp 1: 38.6 Grp 2: 37.1 Grp 3: 38.6 | Grp 1: 80.2% Grp 2: 82.8% Grp 3: 87.0% | Grp 1: 59.3% White Grp 2: 53.8% White Grp 3: 53.3% White | Scale: CES-D Grp 1: 37.3 Grp 2: 36.7 Grp 3: 38.0 | Scale: Global assessment score Grp 1: 50.6 Grp 2: 50.7 Grp 3: 48.8 | Yes, nortriptyline blood level | (1): Intent to treat, repeated measures anova of HAM-D over 8 mos (2): % recovered at 8 months for intent to treat (4 mos post-tx) (3): % recovered at 8 months tx completers | Grp 2 (IPT) vs Grp 3 (pl): IPT> UC; Grp 2 (IPT) vs Grp 1 (NOR): NOR not different from IPT | Grp 1 (IPT): 46% Grp 3 (Pl): 18% | IPT vs. UC (intention to treat): 1.56 IPT vs. UC (tx completers): 2.6 | IPT vs. UC (intention to treat): 28% IPT vs. UC (tx completers): 52% | IPT vs. UC (intention to treat): 3.57 IPT vs. UC (tx completers): 1.92 | Yes | Yes | Yes | Yes | Good | Good | Good
Scott et al, 1992^ 81 ^ | Primary Care | Primary Care | Major depression | SI, MD | Substance abuse, suicidal, OTH: Psychotic illness | Pharmacology, CT by psychologists, or supportive counselling by "qualified" SW | 16 weeks | Screened: 143 Randomized: 121 Analyzed: 113 | Both female and male, 18-65 years, duration of symptoms: 2 weeks | Grp 1: AMI Grp 2: CT Grp 3: SW Grp 4: UC | Grp 1: 30.6 Grp 2: 28.8 Grp 3: 36.2 Grp 4: 31.6 | Grp 1: 61.3% Grp 2: 83.3% Grp 3: 83.3% Grp 4: 63.7% | NR | Scale: HAM-D Grp 1: 18.2 Grp 2: 18.3 Grp 3: 15.7 Grp 4: 19.7 | NR | No | (1): Change in HAM-D (depressive severity) at 16 weeks vs. UC (immediately post-tx) (2): % recovered at 16weeks (HAM-D) (immediately post-tx) | Grp 2 (CT) vs. Grp 4 (UC): −1.7 Grp 3 (SW) vs. Grp 4 (UC): −3.5 (p=0.05 vs. UC) | Grp 2 (CT): 41% Grp 3 (SW): 72% (p=0.05 vs. UC) Grp 4 (UC): 48% | % recovered at 16 weeks: SW vs UC: 50% | 24% | UC= 4.2 | Yes | Yes | DK | No; analyzed only those beginning treatment | Fair | Fair | Fair
Blackburn et al, 1981^ 83 ^ | Primary Care | Primary Care | Major Depression | DI: RDC OTH: Present state exam, BDI: >14 | Bipolar disorder, Psychotic illness | Pharmacology or cognitive psychotherapy | 20 weeks | Screened: 140 Randomized: 88 Analyzed: 64 | Both female and male, 18-65 years, duration of symptoms: 2 weeks | Grp 1: CT Grp 2: Anti-depressant drug of choice (TCA) Grp 3: CT and anti-depressant combined | Grp 1: NR | Grp 1: NR | Grp 1: NR | Grp 1: NR | Grp 1: NR | No | % responding (>=50% decrease in HAM-D or BDI score) | Grp 1 (CT): 72.7% Grp 2 (TCA): 55.0% Grp 3 (CT+TCA): 81.8% No significant difference between groups | NR | NA | NA | NA | Yes | Yes | DK | No | Fair | Fair | Fair
Holden et al, 1989^ 84 ^ | Primary Care | Primary Care | Major depression or minor depression (Post-partum) | DI: Edinburgh post-natal depression scale at 6 weeks post-partum, SI: Goldberg's standardized psychiatric interview at 12 weeks to include RDC (Spitzer) | DK | Supportive counseling by health visitors | 13 weeks | Screened: 734 Randomized: 55 Analyzed: 50 | Female, Childbearing, duration of symptoms: 2 weeks, women 12 weeks postpartum | Grp 1: Health visitor counselling (HV) Grp 2: UC | Grp 1: 27.6 Grp 2: 24.6 | 100% | NR | Scale: Edinburgh post-natal depression scale Grp 1: 16.0 Grp 2: 15.5 | NR | N/A | (1) Recovery from depression at 13 weeks (~ 1 mon. post-tx) | Grp 1 (HV): 69.0% Grp 2 (UC): 38.0% | NR | HV vs. no intervention: % recovered at 13 weeks: 0.83 | 31.70% | 3.15 | Yes | Yes | Yes | No | Fair (not ITT) | Fair | Fair
Katon et al, 1996^ 85 ^ | Primary Care | Primary Care | Major or minor depression | PD, DI: HSCL-20: > .075, IDS used to characterize minor depression vs. major depression | Substance abuse, suicidal, pregnancy, Serious medical illness, Psychosis, dementia, plan to withdraw from HMO | Structured Depression Program with cognitive-behavioral treatments and counseling remedication adherence | 7 months | Screened: 217 Randomized: 153 Analyzed: 153 | 18-80 years, Both male & female, off meds, Duration of symptoms > 2 weeks | Grp 1: Depression program for major depression (MD-UC) Grp 2: Usual care for major depression (MD_UC) Grp 3: Depression program for minor depression (mD-CT) Grp 4: UC for minor depression (mD-UC) | Grp 1: 43.1 Grp 2: 44.8 Grp 3: 49.2 Grp 4: 47.2 | Grp 1: 77.4% Grp 2: 73.5% Grp 3: 71.7% Grp 4: 73.8% | Grp 1: 77.4% white Grp 2: 91.2% white Grp 3: 91.3% white Grp 4: 85.7% white | Scale: SCL-20 Cut-off: 0.75 Grp 1: 2.46 Grp 2: 1.77 Grp 3: 2.35 Grp 4: 1.62 | Scale: NR | Automated pharmacy data, phone interview, # sessions attended, 74% with 6 sessions and 9% with 5 sessions | (1) % > 50% improvement in SCL-20 at 4 mos(1.5-2 mos post-tx); (2) Medication Adherence at 7 mos (4.5-5 mos post-tx); (3) | Grp 1 (MD-CT): 70.4% Grp 2 (MD-UC): 42.3% Grp 3 (mD-CT): 66.7% (p = 0.22) Grp 4 (mD-UC): 52.8% (p = 0.22) | Grp 1 (MD-CT): 79.0% Grp 2 (MD-UC): 54.0% Grp 3: (mD-CT): 65.0% Grp 4 (mD-UC): 41.0% | Outcome 1: Grp1(MD-CT) vs Grp2 (MC-UC), RRR=66.4%; Outcome 2: Grp 1 vs Grp 2 (p = 0.07), RRR:46.3% | Outcome 1: ARR: 25% Outcome 2: ARR: 32.5% | Outcome 1: NNT: 3.56 Outcome 2: NNT: 4 Outcome 3: NNT: 3.07 | Yes | Yes | Yes | Yes | Good | Good | Good
Lynch et al, 1997^ 86 ^ | Primary Care | Primary Care | Minor depression | MOS-D, DIS | Already receiving counseling | Telephone counseling (TC) using problem-solving therapy | 6 sessions | Screened: 239 Randomized: 29 Analyzed: 24 | Female and male, > 18 years | Grp 1: TC Grp 2: Placebo (Pl) | Grp 1: 46.8 Grp 2: 49.9 | Grp 1: 87.5% Grp 2: 85.7% | NR | Scale: HAM-D Grp 1: 14.4 Grp 2: 12.4 | Scale: NR | No | (1): HAM-D mean score (2): BDI mean | Grp 1 (TC): 10.9 Grp 2 (PI): 13.3 Nonsignificant difference between groups | Grp 1: 12.9 Grp 2: 22.4 Significant difference between groups p=0.00 | NA | NA | NA | Yes | No: TC lost 4/15, UC 1/14 | Yes | No | Fair | Fair | Fair
Miranda et al, 1994^ 87 ^ | Primary Care | Primary Care | Minor depression (BDI > 18 without diagnosis of major depression or dysthymia) | DIS | Substance abuse, major depression, dysthymia, psychotic disorder, not English or Spanish speaking | Cognitive behavioral therapy (CBT) | 12 months | Screened: 708 Randomized: 150 Analyzed: 150 | Both male and female, 18-69 years | Grp 1: CBT Grp 2: Usual care (UC) | Grp 1: 52.5 (NS difference in groups) | Grp 1: 62.0% (NS difference between groups) | Grp 1: 35.1% White 23.7% Black 24.3% Hispanic 10.1% Other | NR | NR | NR | (1) Mean depressive severity over 1 yr. (including 10 mos post-tx) (2) No. of missed medical appointments over 1yr. | Grp 1 (CBT) had greater reduction in depressive severity than Grp 2 (UC) | Grp 1 (CBT) (0.57) had fewer missed medical appointments than Grp 2 (UC) (1.22) (p=0.05) | NA | NA | NA | Yes | Yes | DK | Yes | Fair | Fair | Fair
Ross et al, 1985^ 88 ^ | Primary Care | Primary Care | Major depression | DI: RDC, PD, OTH: BDI: >14 | DK | Cognitive therapy | 12 weeks | Screened: Blank Randomized: 51 Analyzed: 51 | Male and female, Duration of symptoms: 2 weeks | Grp 1: B: Individual cognitive (I-CT) Grp 2: B: Group cognitive therapy (G-CT) Grp 3: Usual Care (UC) | Grp 1 vs Grp 2: "similar" | Grp 1 vs Grp 3: "similar" | Grp 1 vs Grp 3: "similar" | Scale: NR | Scale: NR | No | (1): Change in MADS score (immediately post-tx) | Grp 1 (I-CT): Significant vs. UC:p < 0.05 Grp 2 (G-CT): Significant vs. UC: p < 0.05 | NR | NA | NA | NA | Yes | DK | Yes | Yes | Good | Fair | Fair
Scott et al, 1997^ 89 ^ | Primary Care | Primary Care | Major depression | DI: BDI, MD, OTH: Interview by psychiatrist | Bipolar disorder, OTH: Dysthymia, psychosis, previous exposure to cognitive therapy, organic brain damage, illiterate | Cognitive therapy (CT) | 12 months | Screened: NR Randomized: 48 Analyzed: 48 | Both male and female, 18-65 years, duration of symptoms: > 2 weeks And < 2 years | Grp 1: CT Grp 2: UC | Grp 1: 41 (NS between groups) | Grp 1: 67% (NS between groups) | NR | Scale: HAM-D Cut-off: > 20 Grp 1: 21.4 Grp 2: 22.5 | NR | N/A | (1): Recovery at 7 weeks (immediately post-tx) (2): Mean depressive severity at 7 weeks (BDI), immediately post-tx | Grp 1 (CT): 62.5% Grp 2 (UC): 33.3% (p<0.05, Grp1 vs. 2) | Grp 1 (CT): 17.7 Grp 2 (UC): 22.7 (p<0.05, Grp 1 vs. 2) | CT vs. UC: % recovery at 7 weeks: 0.87 | 29% | 3.40 | Yes | No | Yes | Yes (for 7 weeks recovery only) | Fair | Fair (unclear # screened) | Fair
Teasdale et al, 1984^ 90 ^ | Primary Care | Primary Care | Major depression | DI: Research criteria | OTH: psychotic | Cognitive therapy (CT) | 6 months (3 months of tx, follow-up assessment 3 months later) | Screened: NR Randomized: 44 Analyzed: 33 | Both female and male, 18-60 years, duration of symptoms: 2 weeks | Grp 1: B: CT Grp 2: UC | Grp 1: 38.0 Grp 2: 37.0 | Grp 1: 94% Grp 2: 94% | NR | Scale: BDI Grp 1 (CT): 30 Grp 2 (UC): 29 | NR | N/A | (1): BDI <14 immediately post-tx (2): BDI < 14 at 3 mos post-tx | Grp 1 (CT): 14/17 (82%) Grp 2 (UC): 4/17 (24%) | Grp 1 (CT): 10/17 (59%) Grp 2 (UC): 9/17 (53%) | NA | NA | NA | Yes | Yes | DK | No | Fair | Fair | Fair

Table 4. Screening Outcomes for Depression Studies

Author, Year | Screening Setting | Definition of Population | Exclusions | Screening Instrument | Other Rating | Confirmatory Exam | Study Groups & Intervention Defined | Number of Subjects (intervention/control) | Study Duration | Mean Age (years) | % Female | Ethnicity | Education | Outcome Defined: (1) Main 1 (2) Sec. 2 (3) Sec. 3 (4) Sec. 4 | Outcome Main 1: | Outcome Sec 2: | Outcome Sec 3: | Outcome Sec 4: | Adequate Inclusion Criteria? | Drop-outs similar in Intervention & Control Groups? | Adequate Randomization & Concealment? | Intention to Treat Analysis? | Internal Validity? | External Validity? | Overall Quality? | Comments
Callahan et al, 1994^ 91 ^ | Primary Care (academic) | Age >60 with elevated CES-D and HAM-D scores | Prisoners, Nursing home residents, Non-English speakers, Hearing impaired | CES-D | HAM-D | SIP | Int.: 3 addtl appointments, addtl education, feedback of HAM-D, list of hazardous meds | 100 intervention 75 control | 9 months | 65 | 76% | 48% White 51% Black | 9 years mean | 1) New chart documentation of depression 2) Started antidepressant 3) Change in HAM-D 0-9 months | Int.: 32% Ctrl: 12% | Int.: 26% Ctrl: 8% | Int.: −7 Ctrl: −7 | NR | Yes | Yes | No | Yes | Fair | Fair | Fair
Callahan et al, 1996^ 92 ^ | Primary Care (academic) | First patient of providers randomized to intervention or control | NR | CES-D | CAGE Short, portable mental status questionnaire | HAM-D, SIP | Int.: Physicians received HAM-D scores plus explicit treatment recommendations | 3767 screened 515 eligible with CES-D >=16 254 enrolled 222 analyzed | 1 year | 65.9 | 76% | 46% | 10% greater than HS | 1) Chart documentation of depression or depressive symptoms 2) Likelihood of depression rated >50% 3) Intention to treat (any form) 4) Initiation of treatment | Int.: 86.7% Ctrl: 40.4% P=.001 | Int.: 49.6% Ctrl: 54.8% P=0.44 | Int.: 63.8% Ctrl: 18.2% P=.001 | Int.: 46.5% Ctrl: 29.0% P=.001 | Yes | Yes | No | Yes | Fair | Fair | Fair
Dowrick, 1995^ 93 ^ | Primary Care (community) | Patients who were not diagnosed as depressed on a visit | Beck >35 Clearly suicidal | Beck | Hamilton Scale RDC criteria for probable depression | ICD 10 based structured interview | Int.: Feedback of Beck results at 0 and 6 months Ctrl: No feedback | 116 patients rated as not depressed and with Beck >14 52 to intervention 64 to control | 12 months | NR | NR | NR | NR | 1) % diagnosed as depressed 2) Odds ratio for detection 3) % with def. plan to treat depression | Int.: 35% Ctrl: 21 % | 2.10 (0.84, 5.28) | Int.: 27% Ctrl: 21% P=NS | NR | Yes | Yes | Yes | Yes | Good | Fair | Good
Johnstone and Goldberg, 1976^ 94 ^ | Primary Care | Primary care attenders | NR | GHQ | Physician recognition | NR | Feedback of GHQ results | 1,093 screened 60 intervention 59 control | 1 year | NR | NR | NR | NR | 1. Mean GHQ scores at 12 months overall 2. Mean GHQ scores at 12 months (severe cases) 3. Duration of first episode (full sample) 4. Total duration of depression (full sample) | No difference | Int.: 11.0 Ctrl: 22.7 | Int.: 2.8 months Ctrl: 5.3 months P<.01 | Int.: 4.2 months Ctrl: 6.3 months P<0.01 | DK | Yes | No | DK | Fair | Fair | Fair
Linn and Yager, 1980^ 95 ^ | Primary Care | New patients attending an academic Medicine clinic | Non-English speaking | Zung SDS | Physician rating | None | Complicated 6 group design, results here for Grp. one (screening) vs Grps. 5 and 6 (no screening) | 150 total | No follow-up | 56 | 71% | 60% White 40% Non-White | NR | 1) Recognition and notation 2) Treatment | Int.: 29% Ctrl: 8% | Int.: 13% Ctrl: 8% | NR | NR | Yes | Yes | Yes | Yes | Good | Good | Good
Lewis et al, 1996^ 96 ^ | Primary care (low income population in London) | Consecutive attenders 18-70 | Unable to complete screening in English | GHQ | NR | PROQSY | Patients scoring <2 assigned to: Grp 1: GHQ feedback Grp 2: PROQSY feedback Grp 3: Control - no feedback | 1,937 screened 851 screened positive 146 refused 227 assigned to each group | 6 months | Grp 1: 39.5 Grp 2: 38.7 Grp 3: 37.4 | Grp 1: 70% Grp 2: 61% Grp 3: 68% | NR | NR | 1) Mean GHQ at 6 weeks 2) Mean GHQ at 3 months 3) Mean GHQ at 6 months | 1) 27.2 2) 25.7 3) 26.6 P=0.04 | 1) 27.0 2) 25.5 3) 26.4 P=0.07 | 1) 26.8 2) 25.4 3) 28.9 | NR | Yes | Yes | Yes | Yes | Good | Fair | Fair | General mental health screening, not specific to depression
Magruder-Habib et al, 1990^ 97 ^ | Primary Care (VA) | All patients during study period | Age >90; Women; Hospital employee; Depression noted within 6 months in chart | Zung SDS | NR | DIS | Feedback of SDS scores | 880 screened 100 depressed Grp 1: 48 feedback grp. Grp 2: 52 control grp. | 1 year | Grp 1: 57.9 Grp 2: 61.9 | Grp 1: 0% Grp 2: 0% | Grp 1: 68.8% White Grp 2: 67.3% White | NR | 1) % recognized as depressed initially 2) % recognized at 1 year 3) % treated initially 4) % treated at 1 year | Int.: 25% Ctrl: 7.7% | Int: 42% Ctrl: 21% | Int.: 28% Ctrl: 3.8% | Int.: 56% Ctrl: 42% | Yes | Yes | Yes | Yes | Good | Fair | Good
Moore et al, 1978^ 98 ^ | Primary Care (academic) | All patients seen during 8 weeks study, ages 20-60 years | NR | Zung SDS | Chart audit to determine if depression noted | NR | Int.: Feedback on screening results for scores >50, o/w same as controls Ctrl: Notification that screening performed | 213 contacted 212 completed SDS | None | NR | NR | NR | NR | 1) Chart documentation of diagnosis for subjects with SDS >50 | Int.: 56% Ctrl: 22% | NR | NR | NR | Yes | Yes | Yes | Yes | Good | Good | Good
Rand et al, 1988^ 99 ^ | Primary Care (academic) | Consecutive patients attending family practice training clinics | <18 years old "Too sick" Non-English speaking "Mentally disabled" | GHQ 28 | Chart review of physician notation of symptoms, diagnoses, treatment | NR | Feedback of GHQ results to intervention physicians vs usual care | 434 eligible pts. 356 did GHQ 260 enrolled | 3 months | NR | 50% | 50% | NR | 1) % of residents increasing rate of making diagnosis of depression (pre and post) 2) % of patients with any psychiatric diagnosis 3) % patients with depression who received treatment | Int.: 75% Ctrl: 25% | Int.: pre 7%, post 16% Ctrl: pre 13%, post 12% | "Significant" increase in the use of antidepressants for experimental group | NR | Yes | Yes | No | NA | Fair | Fair | Fair
Reifler et al, 1996^ 100 ^ | Primary Care (academic) | Random sample of scheduled patients | Missed appointment; unable to read English | SDDS-PC | SF-36 Zung SDS | SDDS diagnostic module (for those screening positive) | Int.: Received screening results and asked to complete diagnostic module Ctrl: No feedback | 605 contacted 501 eligible 358 enrolled 186 intervention 172 control | 3 months | 40.8 | 76% | 56% White; 32% Black | NR | 1) Health care visits for those screening positive (mean ± SD) 2) Change in SF-36 3) Change in Zung SDS 4) Satisfaction | Int.: 3.7 ±3.9 Ctrl.: 5.3 ±6.7 P=0.06 | No difference | No difference | No difference | Yes | Yes | Yes | No | Good | Good | Good | 18% prevalence of MDD or subsyndromal depression
Wells et al, 2000^ 101 ^ | Multiple primary care clinics | Consecutive clinic patients with current depressive symptoms | <18 years old; acute medical emergency; no insurance; non-English or Spanish speaker | 2 question screener | CES-D | CIDI | Randomization by clinic; intervention clinics received feedback on screening and educational intervention | 46 clinics 27,332 patients screened 1,356 randomized 913 intervention 443 controls | 12 months | 43.7 | 71% | 57% White 30% Hispanic 7% African Amercican 6% Other | 81% High school or greater | 1) Appropriate care at 12 months 2) Depressed on CES-D at 12 months 3) Still (+) on screener at 12 months 4) Employment among those initially employed | Int: 59% Ctrl: 50% P=0.006 | Int: 54% Ctrl: 61% P=0.04 | Int: 42% Ctrl: 51% P=0.005 | Int: 90% Ctrl: 85% P=0.05 | Yes | Yes | Yes | N/A | Good | Good | Good
Williams et al, 1999^ 102 ^ | Primary Care | Adult primary care attenders | NR | 1) Single question 2) CES-D 20 | SF-36 CAGE DUSOI rand visit rating scale MD recognition from chart review | DIS | Grp 1: Single question vs Grp 2: CES-D vs Grp 3: Usual care | Grp 1: 330 Grp 2: 323 Grp 3: 316 | 3 months | Grp 1: 58 Grp 2: 59 Grp 3: 56 | Grp 1: 68% Grp 2: 74% Grp 3: 71% | 30% White 60 % Hispanic 10% African American | Grp 1: 11 years Grp 2: 10 years Grp 3: 11 years | 1) Sensitivity/specificity of screening tests 2) Recognition of depression 3) Treatment or referral rates 4) Depression at 3 months | 1) Single question sens = 85% spec = 66% 2) CES-D sens = 88% spec = 75% | Int.: 39% Ctrl: 29% P=NS | Int.: 44% Ctrl: 43% P=NS | Int.: 37% Ctrl: 46% (P=0.19) | Yes | Yes | Yes | Yes | Good | Good | Good
Zung and King, 1983^ 103 ^ | Primary Care (private practice) | Consecutive clinic patients | <20 years old Mentally retarded Pregnant Prev dx of dep | Zung SDS | CGI severity of illness CGI improvement | DSM-IIIR | Feedback of SDS scores and treatment with alprazolam vs usual care | 499 patients screened 60 scored >55 49 + on DSM-III Grp 1: 23 to feedback Grp 2: 26 to control | 4 weeks | Grp 1: 53.4 Grp 2: 65.9 | NR | NR | NR | 1) Improvement (decrease) on SDS >12 | Int.: 66% Ctrl: 35% | NR | NR | NR | Yes | Yes | Yes | DK | Good | Good | Good