# Appendix B Glossary of Acronyms, Abbreviations and Initialisms for Screening for Depression

AACAP: American Academy of Child and Adolescent Psychiatrists

AAP: American Academy of Pediatrics

ARR: Absolute risk reduction

ACP: American College of Physicians

AHCPR: Agency for Health Care Policy and Research

AHRQ: Agency for Healthcare Research and Quality

BDI: Beck Depression Inventory

BDI-PC: Beck Depression Inventory for Primary Care

CAGE: (Cut down, Annoyed, Guilty, Eye-opener) Screening Questionnaire

CAS: Child Assessment Schedule

CBT: Cognitive-behavioral therapy (sometimes, cognitive therapy)

CBCL: Child Behavior Checklist

CDI: Children's Depression Inventory

CDRS-R: Children's Depression Rating Schedule - Revised

CDS: Child Depression Scale

CES-D: Center for Epidemiology Study Depression scale

CED-DC (or D-C): Center for Epidemiology Study Depression scale for Children

CGI: Clinical Global Impressions

CI: Confidence interval

CSRS: Children's Self-report Rating Scale

DACL: Depressive Adjective Checklist

DEPS: The Depression Scale

DICA: Diagnostic Interview for Children and Adolescents

DIS: Diagnostic Interview Schedule

DISC: Diagnostic Interview Schedule for Children

DSM: Diagnostic and Statistical Manual of Mental Disorders

: (III, third edition; IIIR, third edition revised; IV, fourth edition)

DSRS: Depression Self-Rating Scale

Duke AD: Duke Anxiety-Depression Scale

EPC: Evidence-based Practice Center

GAS: Global Assessment Score

GDS: Geriatric Depression Scale

GHQ: General Health Questionnaire

HAM-D: Hamilton Depression Rating Scale

HIV: Human immunodeficiency virus

HSCL: Hopkins Symptomatic Checklist (as in HCSL-20)

ICD: International Classification of Diseases

IDS: Inventory of Depressive Symptomatology

IPT: Interpersonal therapy (interpersonal psychotherapy)

K-SADS: Schedule for Affective Disorders and Schizophrenia for School-age Children

MADRS:: Montgomery-Asberg Depression Rating Scale

MAOI: Monoamine oxidase inhibitors

MDD: Major depression disorder(s)

MHI: Mental Health Index (as in MHI-5)

MOS: Medical Outcomes Study

NNT: Number needed to treat

OR: Odds ratio

PRIME-MD: Primary Care Evaluation of Mental Disorders

PSC: Pediatric Symptom Checklist

RADS: Reynolds Adolescent Depression Scale

RCT: Randomized controlled trial

RDC: Research Diagnostic Criteria

ROC: Receiver operating characteristics (curve)

RR: Risk ratio

SCI: Structured clinical interview

SCID: Structured Clinical Interview for DSM-III-R (or -IV)

SCL-90: Symptom Checklist 90

SDDS-PC: Symptom Drive Diagnostic System - Primary Care

SER: Systematic evidence review

SDS: Zung self-depression screener

SF: Short Form (for MOS SF-36)

SIP: Sickness Impact Profile

SSLR: Stratum-specific likelihood ratio

SSRI: Selective serotonin reuptake inhibitor

TCA: Tricyclic antidepressants

TMAP: Texas Medication Algorithm Project

USPSTF: U.S. Preventive Services Task Force

WHO: World Health Organization