# References

1 Global Initiative for Chronic Obstructive Lung Disease. Global Strategy for the Diagnosis, Management, and Prevention of Chronic Obstructive Pulmonary Disease. Global Initiative for Chronic Obstructive Lung Disease; 2007. Accessed at www.goldcopd.com/Guidelineitem.asp?l1=2&l2=1&intId=989 on 29 January 2008.
2 Wilt TJ, Niewoehner D, Kim CB, Kane RL, Linabery A, Tacklind J, et al. Use of Spirometry for Case Finding, Diagnosis, and Management of Chronic obStructive Pulmonary Disease (COPD). (Prepared by the Minnesota Evidence-based Practice Center under contract no. 290-02-0009.) Rockville, MD: Agency for Healthcare Research and Quality; 2005. AHRQ publication no. 05-E017-2
3 Ferguson GT, Enright PL, Buist AS, Higgins MW. Office spirometry for lung health assessment in adults: a consensus statement from the National Lung Health Education Program. Respir Care. 2000;45:513-30. [PMID: 10813228]. [pmid: 10813228].
4 Wilt TJ, Niewoehner D, Kane RL, MacDonald R, Joseph AM. Spirometry as a motivational tool to improve smoking cessation rates: a systematic review of the literature. Nicotine Tob Res. 2007;9:21-32. [PMID: 17365733]. [pmid: 17365733].
5 Wilt TJ, Niewoehner D, MacDonald R, Kane RL. Management of stable chronic obstructive pulmonary disease: a systematic review for a clinical practice guideline. Ann Intern Med. 2007;147:639-53. [PMID: 17975187]. [pmid: 17975187].
6 Mannino DM, Gagnon RC, Petty TL, Lydick E. Obstructive lung disease and low lung function in adults in the United States: data from the National Health and Nutrition Examination Survey, 1988-1994. Arch Intern Med. Jun. 2000;160(11):1683-9. [PMID: 10847262]. [pmid: 10847262].
7 Mannino DM, Ford ES, Redd SC. Obstructive and restrictive lung disease and markers of inflammation: data from the Third National Health and Nutrition Examination. American Journal of Medicine. Jun. 2003;114(9):758-62. [PMID: 12829203]. [pmid: 12829203].
8 Fields CL, Byrd RP Jr, Ossorio MA, Roy TM, Michaels MJ, Vogel RL. Cardiac arrhythmias during performance of the flow-volume loop. Chest. 1993;103:1006-9. [PMID: 8131430]. [pmid: 8131430].
9 Hardie JA, Buist AS, Vollmer WM, Ellingsen I, Bakke PS, Mørkve O. Risk of over-diagnosis of COPD in asymptomatic elderly never-smokers. Eur Respir J. 2002;20:1117-22. [PMID: 12449163]. [pmid: 12449163].
10 Vedal S, Crapo RO. False positive rates of multiple pulmonary function tests in healthy subjects. Bull Eur Physiopathol Respir. 1983;19:263-6. [PMID: 6882951]. [pmid: 6882951].
11 Segnan N, Ponti A, Battista RN, Senore C, Rosso S, Shapiro SH, et al. A randomized trial of smoking cessation interventions in general practice in Italy. Cancer Causes Control. 1991;2:239-46. [PMID: 1873454]. [pmid: 1873454].
12 Bize R, Burnand B, Mueller Y, Cornuz J. Biomedical risk assessment as an aid for smoking cessation. Cochrane Database Syst Rev. 2005:CD004705. [PMID: 16235375]
13 Walker WB, Franzini LR. Low-risk aversive group treatments, physiological feedback, and booster sessions for smoking cessation. Behav Ther. 1985;16:263-74.
14 Buffels J, Degryse J, Decramer M, Heyrman J. Spirometry and smoking cessation advice in general practice: a randomised clinical trial. Respir Med. 2006;100:2012-7. [PMID: 16580189]. [pmid: 16580189].
15 Anthonisen NR, Connett JE, Enright PL, Manfreda J. Lung Health Study Research Group. Hospitalizations and mortality in the Lung Health Study. Am J Respir Crit Care Med. Aug 1. 2002;166(3):333-9. [PMID: 12153966]. [pmid: 12153966].
16 Sin DD, Wu L, Anderson JA, Anthonisen NR, Buist AS, Burge PS, et al. Inhaled corticosteroids and mortality in chronic obstructive pulmonary disease. Thorax. 2005;60:992-7. [PMID: 16227327]. [pmid: 16227327]. [pmcid: 1747271].
17 Calverley PM, Anderson JA, Celli B, Ferguson GT, Jenkins C, Jones PW, et al. Salmeterol and fluticasone propionate and survival in chronic obstructive pulmonary disease. N Engl J Med. 2007;356:775-89. [PMID: 17314337]. [pmid: 17314337].
18 Górecka D, Gorzelak K, Sliwiński P, Tobiasz M, Zieliński J. Effect of long-term oxygen therapy on survival in patients with chronic obstructive pulmonary disease with moderate hypoxaemia. Thorax. 1997;52:674-9. [PMID: 9337824]. [pmid: 9337824]. [pmcid: 1758616].
19 Chaouat A, Weitzenblum E, Kessler R, Charpentier C, Enrhart M, Schott R, et al. A randomized trial of nocturnal oxygen therapy in chronic obstructive pulmonary disease patients. Eur Respir J. 1999;14:1002-8. [PMID: 10596681]. [pmid: 10596681].
20 Lacasse Y, Brosseau L, Milne S, Martin S, Wong E, Guyatt GH, et al. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2002:CD003793. [PMID: 12137716]
21 Sin DD, McAlister FA, Man SF, Anthonisen NR. Contemporary management of chronic obstructive pulmonary disease: scientific review. JAMA. 2003;290:2301-12. [PMID: 14600189]. [pmid: 14600189].
22 Lacasse Y, Goldstein R, Lasserson TJ, Martin S. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2006:CD003793. [PMID: 17054186]
23 Salpeter SR. Cardiovascular safety of beta(2)-adrenoceptor agonist use in patients with obstructive airway disease: a systematic review. Drugs Aging. 2004;21:405-14. [PMID: 15084142]. [pmid: 15084142].
24 Salpeter SR, Ormiston TM, Salpeter EE. Cardiovascular effects of beta-agonists in patients with asthma and COPD: a meta-analysis. Chest. 2004;125:2309-21. [PMID: 15189956]. [pmid: 15189956].
25 Sestini P, Renzoni E, Robinson S, Poole P, Ram FS. Short-acting beta 2 agonists for stable chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2002:CD001495. [PMID: 12519559]
26 Ferguson GT, Funck-Brentano C, Fischer T, Darken P, Reisner C. Cardiovascular safety of salmeterol in COPD. Chest. 2003;123:1817-24. [PMID: 12796155]. [pmid: 12796155].
27 Salpeter SR, Buckley NS, Salpeter EE. Meta-analysis: anticholinergics, but not beta-agonists, reduce severe exacerbations and respiratory mortality in COPD. J Gen Intern Med. 2006;21:1011-9. [PMID: 16970553]. [pmid: 16970553]. [pmcid: 1831628].
28 Kesten S, Jara M, Wentworth C, Lanes S. Pooled clinical trial analysis of tiotropium safety. Chest. 2006;130:1695-703. [PMID: 17166984]. [pmid: 17166984].
29 Barr RG, Bourbeau J, Camargo CA, Ram FS. Tiotropium for stable chronic obstructive pulmonary disease: A meta-analysis. Thorax. 2006;61:854-62. [PMID: 16844726]. [pmid: 16844726]. [pmcid: 2104759].
30 Barr RG, Bourbeau J, Camargo CA, Ram FS. Inhaled tiotropium for stable chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2005:CD002876. [PMID: 15846642]
31 Alsaeedi A, Sin DD, McAlister FA. The effects of inhaled corticosteroids in chronic obstructive pulmonary disease: a systematic review of randomized placebo-controlled trials. Am J Med. 2002;113:59-65. [PMID: 12106623]. [pmid: 12106623].
32 Gartlehner G, Hansen RA, Carson SS, Lohr KN. Efficacy and safety of inhaled corticosteroids in patients with COPD: a systematic review and meta-analysis of health outcomes. Ann Fam Med. 2006;4:253-62. [PMID: 16735528]. [pmid: 16735528]. [pmcid: 1479432].
33 Halpern MT, Schmier JK, Van Kerkhove MD, Watkins M, Kalberg CJ. Impact of long-term inhaled corticosteroid therapy on bone mineral density: results of a meta-analysis. Ann Allergy Asthma Immunol. 2004;92:201–7; quiz 207–8, 267. [PMID: 14989387]
34 Poole PJ, Chacko E, Wood-Baker RW, Cates CJ. Influenza vaccine for patients with chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2006:CD002733. [PMID: 16437444]
35 Granger R, Walters J, Poole PJ, Lasserson TJ, Mangtani P, Cates CJ, et al. Injectable vaccines for preventing pneumococcal infection in patients with chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2006:CD001390. [PMID: 17054135]
36 Alfageme I, Vazquez R, Reyes N, Muñoz J, Fernández A, Hernandez M, et al. Clinical efficacy of anti-pneumococcal vaccination in patients with COPD. Thorax. 2006;61:189-95. [PMID: 16227328]. [pmid: 16227328]. [pmcid: 2080738].