# Acknowledgments

The authors thank Timothy Wilt, MD, MPH, and coinvestigators at the Minnesota Evidence-based Practice Center, for generously sharing data that were not yet published when this review was written. They also thank Caryn McManus and Gloria Washington at the AHRQ, for technical assistance with the literature searches and compilation of data.