# Discussion

No direct evidence indicates that screening patients for COPD using spirometry improves long-term health outcomes (Table 2). An evaluation of the potential benefits of such screening depends on piecing together a coherent chain of evidence. One impetus for screening has been data from population surveys showing that a substantial number of smokers with severe airflow obstruction do not recognize or report respiratory symptoms to a physician. However, these prevalence data also show that more than 90% of patients with undetected airflow obstruction have FEV_1_ of 50% of predicted or greater. This information is important because the efficacy of COPD pharmacologic treatments has been established only in symptomatic patients with FEV_1_ less than 50% of predicted.

Table 2 Summary of Evidence*

Key Question | Studies Identified | Summary of Evidence
Does screening for COPD with spirometry reduce morbidity and mortality? | No RCTs directly address this question | No evidence is available to answer this question.
What is the prevalence of COPD in the general population? | Population-based surveys from 7 countries including NHANES | Prevalence is 4.5% to 21.1%, depending on COPD definition; 7.2% in U.S. population using GOLD definition.
Do risk factors reliably discriminate between high-risk and average risk populations? | NHANES I and III (6,7) | Severe airflow obstruction is higher in older adults and in current and past smokers.
What are the adverse effects of screening for COPD with spirometry? | 3 small studies of spirometry performed in pulmonary function laboratories | Spirometry seems to be physically safe; some false-positive test results occur in asymptomatic patients.
Do individuals with COPD detected by screening spirometry have improved smoking cessation rates compared with usual smokers? | 8 RCTs and 2 systematic reviews with up to 36 months of follow-up; only 2 RCTs evaluated the independent motivational effect of spirometry | Spirometry does not seem to increase smoking cessation rates, but further studies may be needed.
Does pharmacologic treatment, oxygen therapy, or pulmonary rehabilitation for COPD reduce morbidity and mortality? | 43 RCTs and 10 meta-analyses identified in 2007 systematic review by Wilt et al. (5) | Pharmacologic treatments reduce exacerbations in patients with symptomatic severe COPD and have a small effect on all-cause mortality.
| | Oxygen therapy reduces mortality in patients with resting hypoxia.
| | Pulmonary rehabilitation improves some health status measures.
| | None of these therapies has been tested in patients with airflow obstruction who do not recognize or report symptoms.
What are the adverse effects of COPD treatments? | 12 fair- to good-quality systematic reviews | Common minor adverse effects include dry mouth, urinary retention, tachycardia, oropharyngeal candidiasis, and easy bruising.
| | Major adverse effects seem rare.
Do influenza and pneumococcal immunizations reduce COPD-associated morbidity and mortality? | 2 Cochrane systematic reviews, including 11 and 4 RCTs, respectively | Influenza vaccination reduced COPD exacerbations occurring >4 weeks after vaccination.
What are the adverse effects of influenza and pneumococcal immunizations in patients with COPD? | | Pneumococcal vaccination had no statistically significant effect on health outcomes.
| | Local reactions occurred at injection site.

* COPD = chronic obstructive pulmonary disease; GOLD = Global Initiative for Chronic Obstructive Lung Disease; NHANES = National Health and Nutrition Examination Survey; RCT = randomized, controlled trial.

Pharmacologic treatments for COPD have been demonstrated to reduce the absolute risk for 1 or more COPD exacerbations by 4% to 6% in pooled analyses. Although a recent RCT suggested that these treatments also reduce mortality to a smaller degree, that trial was conducted in a sample of symptomatic patients, most of whom had already experienced exacerbations and would have been received a diagnosis clinically rather than with screening. No studies to date permit an estimate of the incremental mortality benefit from treating a sample of patients who would not have received a diagnosis clinically.

The hypothesis that knowing one's spirometry results might provide extra motivation for a smoker to quit has not been tested adequately. Previous trials have not assessed the independent effect of spirometry as part of a comprehensive smoking cessation program that includes proven pharmacologic therapies. However, data suggest that even if spirometry provides an incremental benefit over other cessation strategies, the benefit is likely to be small.

Individuals with mild to moderate airflow obstruction may benefit from receiving an annual influenza vaccine, although how much of the overall reduction in COPD exacerbations applies to this subgroup is uncertain. The incremental benefit is likely to be small because most patients with COPD are older than 50 years of age and would already be targeted to receive the vaccine.

These potential benefits must be weighed against potential harms. Although studies conducted in pulmonary function laboratories have demonstrated little risk of spirometry causing physical harm, widespread screening of adult smokers (most of whom do not have airflow obstruction) is likely to produce some false-positive results. Pharmacotherapy is commonly associated with minor adverse effects and, rarely, with major events.

In conclusion, screening for COPD using spirometry is likely to identify a predominance of patients with mild to moderate airflow obstruction who would not experience additional health benefits if labeled as having COPD. A few individuals with severe airflow obstruction (FEV_1_ <50% of predicted) might benefit from pharmacologic treatments that reduce exacerbations. Hundreds of patients would need to have screening spirometry to identify one person with COPD whose incremental health benefit over clinical diagnosis would likely be limited to the avoidance of a first exacerbation.

From the Center for Primary Care, Prevention, and Clinical Partnerships, Agency for Healthcare Research and Quality, Rockville, Maryland; Washington DC Veterans Affairs Medical Center, Washington, D.C.; University of Maryland School of Medicine, Baltimore, Maryland; and Brooks Air Force Base, Brooks City-Base, Texas.