# Methods

In addition to summarizing evidence previously synthesized in the 2005 AHRQ report (2) and in 2 subsequent updated reviews (4, 5), we performed, at the request of the USPSTF, supplemental literature searches for evidence that COPD screening programs reduce morbidity and mortality, evidence of harms from spirometry and COPD treatments, and new evidence on spirometry's use as an independent motivational tool for smoking cessation.

## Data Sources

Supplemental searches were limited to English-language articles identified in PubMed and the Cochrane Library. We searched for studies from 1966 through December 2006 that addressed key questions 1 and 3. We searched for studies published in 2005 and 2006 that addressed key question 4. We searched for systematic reviews published from 1997 through January 2007 that addressed key questions 6, 7, and 8. The Appendix provides detailed search terms. We identified additional potentially relevant studies by reviewing the reference lists of retrieved articles and consulting with experts.

## Study Selection

Two authors independently reviewed all titles, abstracts, and full articles by using explicit inclusion and exclusion criteria for each key question (Appendix). Abstracts that were selected by fewer than 2 reviewers were discussed and selected on the basis of consensus. We considered studies of spirometry regardless of whether the testing was performed in a pulmonary function laboratory or in an office setting.

For questions on benefits of screening and treatment, we included randomized, controlled trials (RCTs); systematic reviews; and meta-analyses. For questions on harms, we also included nonrandomized studies that were generalizable to primary care populations.

## Data Extraction and Quality Assessment

Two authors independently reviewed the text of studies selected for full article review to determine whether the studies met eligibility criteria for inclusion. Two authors rated the quality of studies that met inclusion criteria by using established USPSTF methods (Appendix Table 1). Disagreements in quality rating were resolved by consensus.

## Data Synthesis and Statistical Analysis

With 1 exception, data were synthesized qualitatively in narrative and tabular format because of the heterogeneity of patient characteristics, study methods, and/or outcome assessments. Selected health outcomes of COPD treatments were synthesized quantitatively in the 2007 review by Wilt and colleagues (5) but were not further meta-analyzed for this review.

Projected outcomes of population-based screening for COPD using spirometry were estimated by using data on the prevalence of airflow obstruction in the general U.S. population (2) and pooled effectiveness of inhaled therapies at reducing the absolute risk for COPD exacerbations (5).

## Role of the Funding Source

The work of the USPSTF is supported by the AHRQ. This review did not receive separate funding.