# Introduction

Chronic obstructive pulmonary disease is defined as airflow limitation that is not fully reversible, is gradually progressive, and is associated with an abnormal inflammatory lung response to noxious particles or gases (1). It currently affects more than 5% of the adult population and is the fourth leading cause of death in the United States. Direct medical and total economic costs of COPD in 1993 were estimated to be $15 billion and $24 billion, respectively (2).

The Global Initiative for Chronic Obstructive Lung Disease (GOLD) specifies 4 stages of COPD based on impairment in FEV_1_, measured with spirometry: mild (stage I), moderate (stage II), severe (stage III), and very severe (stage IV) (1). Patients with stage I disease have an FEV_1_ of at least 80% of predicted, whereas those with stage IV disease have an FEV_1_ less than 30% of predicted or FEV_1_ less than 50% of predicted and chronic respiratory failure.

Fewer than half of the estimated 24 million Americans with airflow obstruction have actually received a diagnosis of COPD, and diagnosis often occurs in advanced stages of the disease (2). Because 4 in 5 patients with COPD are current or former smokers, some groups have advocated mass screening of asymptomatic smokers by using office spirometry (3). Early detection could theoretically improve health outcomes by increasing smoking cessation rates; prioritizing administration of influenza and pneumococcal vaccines; and permitting earlier initiation of pharmacologic treatments, oxygen therapy, or pulmonary rehabilitation.

In 2005, the Agency for Healthcare Research and Quality (AHRQ) published a systematic review (2) from the Minnesota Evidence-based Practice Center of the utility of spirometry for case finding, diagnosis, and management of COPD. The report created an opportunity for the U.S. Preventive Services Task Force (USPSTF) to make a timely recommendation on screening for COPD using spirometry. In consultation with the USPSTF, we developed an analytic framework (Figure 1) to guide this summary of the evidence on the benefits and harms associated with screening for COPD using spirometry. The key questions were as follows:

1 Does screening for COPD with spirometry reduce morbidity and mortality?
2 What is the prevalence of COPD in the general population? Do risk factors reliably discriminate between high-risk and average-risk populations?
3 What are the adverse effects of screening for COPD with spirometry?
4 Do individuals with COPD detected by screening spirometry have improved smoking cessation rates compared with usual smokers?
5 Does pharmacologic treatment, oxygen therapy, or pulmonary rehabilitation for COPD reduce morbidity and mortality?
6 What are the adverse effects of COPD treatments?
7 Do influenza and pneumococcal immunizations reduce COPD-associated morbidity and mortality?
8 What are the adverse effects of influenza and pneumococcal immunizations in patients with COPD?

Figure 1. Analytic Framework for COPD Screening using Spirometry

M/M = morbidity and mortality.

KQ1: Does screening for COPD with spirometry reduce morbidity and mortality?

KQ2: What is the prevalence of COPD in the general population? Do risk factors (smoking, other exposures) reliably discriminate between high risk and average risk populations?

KQ3: What are the adverse effects of screening for COPD with spirometry?

KQ4: Do individuals with COPD detected by screening spirometry have improved smoking cessation rates compared to usual smokers?

KQ5: Do pharmacologic treatments, oxygen therapy, or pulmonary rehabilitation for COPD reduce morbidity and mortality?

KQ6: What are the adverse effects of COPD treatments?

KQ7: Do influenza and pneumococcal immunizations reduce COPD-associated morbidity and mortality?

KQ8: What are the adverse effects of influenza and pneumococcal immunizations in patients with COPD?