# Appendix: Details of Supplemental Literature Searches

## Key Question 1

We searched PubMed to identify English-language RCTs or meta-analyses published from 1966 through December 2006, using combinations of Medical Subject Heading (MeSH) terms pulmonary disease/chronic obstructive, spirometry, smoking, and mass screening. Articles were eligible for inclusion if they had a randomized or quasi-randomized study design, compared a screened sample with an unscreened sample, and included morbidity and/or mortality outcomes. The literature search returned 1 abstract, which was excluded because it was a study of lung cancer screening with computed tomography rather than COPD screening with spirometry.

## Key Question 3

We searched OVID MEDLINE to identify English-language studies published from 1966 through December 2006, using combinations of the MeSH terms spirometry, diagnostic errors, and adverse effects. We considered studies of spirometry regardless of whether the testing was performed in a pulmonary function laboratory or in an office setting. We excluded articles that were narrative reviews, letters, or editorials; included only a sample that did not have COPD (for example, children with cystic fibrosis); or did not address harms or test characteristics of spirometry. We also excluded isolated case reports documenting spirometry-induced pneumomediastinum, bronchial obstruction, or incarcerated inguinal hernia.

Although we had determined a priori to exclude articles that compared the diagnostic accuracy of spirometry performed in primary care settings with that performed in referral settings (with referral settings serving as the “gold standard”), no articles of this type were retrieved by the search.

Two reviewers independently reviewed the title lists, abstracts, and full articles. Disagreements were resolved by consensus.

The initial literature search retrieved 59 articles, which were entered into an EndNote database (Thomson ResearchSoft, Philadelphia, Pennsylvania). We excluded 27 articles at the title stage; after a review of the remaining abstracts, we excluded 23 additional articles. The remaining 9 articles were obtained for full-text review; 7 more articles were excluded at this stage. One article was identified from reviewing the reference list from an excluded article, leaving a total of 3 articles included in this review. Appendix Figure 1 shows the flow of the literature search.

## Key Question 4

We searched PubMed for systematic reviews and RCTs of spirometry as a motivational tool for smoking cessation published in 2005 and 2006, using a search strategy identical to that of the 2005 AHRQ report (2). We excluded studies that had follow-up shorter than 6 months or had fewer than 25 participants per treatment group or if the control group received spirometric results. Two reviewers independently reviewed the title lists, abstracts, and full articles. Disagreements were resolved by consensus. The initial literature search returned 42 articles, which were entered into an Endnote database. We excluded 36 articles at the title or abstract stage; the remaining 6 articles were obtained for full-text review. We excluded 3 more articles at this stage. One of the remaining 3 articles was the 2005 AHRQ report (5); the other 2 articles are included in this review. Appendix Figure 2 shows the flow of the literature search.

## Key Question 6

We searched PubMed to identify English-language systematic reviews of adverse effects of COPD medications published from January 1997 through January 2007, using the MeSH term pulmonary disease, chronic obstructive/drug therapy, and combinations of MeSH terms and text words representing adverse effects noted in the RCTs of therapy included in Wilt and colleagues' 2007 systematic review (5). Two reviewers reviewed the titles. Studies were excluded if they were not systematic reviews; discussed medications other than β-agonists, anticholinergics, or inhaled corticosteroids; were older versions of the same publication (such as Cochrane reviews); or had no relevant outcomes.

The initial literature search returned 50 articles, which were entered into an EndNote database. We excluded 38 articles at the title stage. Two reviewers independently reviewed the full text of the remaining 12 articles, all of which met inclusion criteria for this review. Appendix Figure 3 shows the flow of the literature search.

## Key Question 7

We searched the Cochrane Database of Systematic Reviews for completed reviews of the benefits of influenza and pneumococcal vaccinations in patients with COPD. One review on each vaccination was identified and included in the review.

## Key Question 8

We searched PubMed to identify English-language systematic reviews published from January 1997 through January 2007, using combinations of the MeSH terms and text words pneumococcal vaccine, influenza vaccine, adverse effects, harms, and safety. The initial literature search returned 3 articles. Two of these articles had already been retrieved for key question 7, and the third article was a previous version of one of these articles.

Appendix Figure 1. Key Question 3 Literature Search Flow Diagram

Reasons for exclusion (number of studies excluded):
Not COPD (n = 12): | Study of test performance of spirometry in other respiratory diseases (e.g. asthma)
Not Spirometry n = (13): | Study not on spirometry
Case Report (n = 11): | Case report or uncontrolled case series
No Outcomes (n = 20): | No information about false positives or adverse effects
Special Population (n = 1): | Study not generalizable to outpatient primary care populations

Appendix Figure 2. Key Question 4 Literature Search Flow Diagram

Reasons for exclusion (number of studies excluded):
Study Design (n = 39): | Narrative review or study design not meeting inclusion criteria
No Outcomes: | No information on smoking cessation outcomes
Not Spirometry: | Spirometry not a component of smoking cessation intervention

Appendix Figure 3. Key Question 6 Literature Search Flow Diagram

Reasons for exclusion (number of studies excluded):
Wrong Drug (n = 21): | Study of a medication not meeting inclusion criteria
Not Chronic (n = 6): | Therapy for acute exacerbations rather than chronic disease
Study Design (n = 11): | Not a systematic review

Appendix Table 1. U.S. Preventive Services Task Force Hierarchy of Research Design and Quality Rating Criteria*

Hierarchy of research design
I: Properly conducted RCT
II-1: Well-designed controlled trial without randomization
II-2: Well-designed cohort or case-control analytic study
II-3: Multiple time-series with or without the intervention; dramatic results from uncontrolled experiments
III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees
Design-specific criteria and quality category definitions
Systematic reviews
Criteria
Comprehensiveness of sources considered/search strategy used
Standard appraisal of included studies
Validity of conclusions
Recency and relevance are especially important for systematic reviews
Definition of ratings based on above criteria
Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies
Case-control studies
Criteria
Accurate ascertainment of cases
Nonbiased selection of cases/controls with exclusion criteria applied equally to both
Response rate
Diagnostic testing procedures applied equally to each group
Measurement of exposure accurate and applied equally to each group
Appropriate attention to potential confounding variables
Definition of ratings based on above criteria
Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate ≥80%; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables
Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rates <80% or attention to some but not all important confounding variables
Poor: Major section or diagnostic work-up biases, response rates <50%, or inattention to confounding variables
Randomized, controlled trials and cohort studies
Criteria
Initial assembly of comparable groups
For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
For cohort studies: Consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
Important differential loss to follow-up or overall high loss to follow-up
Measurements: equal, reliable, and valid (includes masking of outcome assessment)
Clear definition of the interventions
All important outcomes considered
Definition of ratings based on above criteria
Good: Evaluates relevant available screening tests; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients
Fair: Evaluates relevant available screening tests; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 participants) and a “medium” spectrum of patients
Poor: Has fatal flaw, such as uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum of patients
Diagnostic accuracy studies
Criteria
Screening test relevant, available for primary care, adequately described
Study uses a credible reference standard, performed regardless of test results
Reference standard interpreted independently of screening test
Handles indeterminate result in a reasonable manner
Spectrum of patients included in study
Sample size
Administration of reliable screening test
Definition of ratings based on above criteria
Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50–100 participants) and a “medium” spectrum of patients
Poor: Has fatal flaw, such as uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum of patients

* From Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21–35. [PMID: 11306229]

Appendix Table 2. ystematic Literature Reviews on Adverse Effects of Pharmacologic Therapies for Chronic Obstructive Pulmonary Disease*

Study | COPD Drug Class | Selected Studies | Literature Search Method: Search Strategy, Inclusion Criteria
Part 1
Sestini et al., 2002 (25) | β_2_-Agonist: short-acting | 13 RCTs | Cochrane Airways Group, reference list from review articles and RCTs; no language restriction
| | Crossover | RCTs on inhaled short-acting β_2_-agonist treatment compared with placebo, with 1-wk minimum treatment duration in patients with stable COPD
| | High quality
Ferguson et al., 2003 (26) | β_2_-Agonist: salmeterol | 7 RCTs | Trials selected by availability of individual patient data, sponsorship by GSK, randomized, double-blind, parallel-group, multiple-dose studies, and salmeterol, 50 μg bid in arm via MDI, to patients with COPD diagnosis
| | Pooled analysis
Salpeter et al., 2004 (24) | β_2_-Agonist | 33 RCTs: 13 single-dose trials, 20 longer duration (3–365 d) | EMBASE, MEDLINE, CINAHL, scanned references of identified articles and reviews; published 1966–June 2003; no language restriction
| | Meta-analysis | RCTs on β_2_-agonist use in asthma or COPD that allowed open-label “rescue” β_2_-agonist use in both treatment groups, providing extractable data on heart rate or potassium concentrations or reporting ≥1 adverse CV event
| | Quality: 15 longer-duration trials were parallel-group trials; all single-dose and 5 longer-duration trials were crossover trials
Salpeter, 2004 (23) | β_2_-Agonist | 8 case-control studies by systematic review | EMBASE, MEDLINE, CINAHL, scanned references of identified articles and reviews; published 1966–June 2003; no language restriction
| | 33 RCTs by meta-analysis (see detail in previous row: Salpeter et al., 2004 [24]) | RCTs and case-control studies on CV safety of β_2_-agonist use in asthma or COPD
Salpeter et al., 2006 (27) | β_2_-Agonist: albuterol, metaproterenol, formoterol, salmeterol | 22 RCTs | EMBASE, MEDLINE, Cochrane, scanned relevant articles from FDA Web site and references of identified reviews; published 1966–December 2005; no language restriction
| Anticholinergic: ipratropium, tiotropium | Pooled analysis | RCTs on β_2_-agonist or anticholinergic use in COPD compared with placebo, 3-mo minimum duration, reporting ≥1 COPD exacerbation leading to study withdrawal, hospitalization, or respiratory death
| | Quality: No study received the lowest quality score on the 4 measurements (randomization and allocation concealment, double-blinding, withdrawals, and intention-to-treat analysis)
Barr et al., 2005 (30) | Anticholinergic: tiotropium | 12 RCTs; 6584 patients (3 trials reported combined results of separate pairs of trials) | Cochrane Airways Group, Cochrane Central Register of Controlled Trials, LILACS, hand searches of 20 respiratory journals and conference abstracts, requests for unpublished studies from tiotropium manufacturer and identified RCT authors, and search of bibliographies for included trials and reviews; no language restriction
| | Quality: Concealment of allocation not described in 9 trials; adequately described in 3 trials | RCTs comparing tiotropium with placebo, ipratropium, or long-acting β_2_-agonist in patients with stable COPD, for at least 1-mo duration
| | By the Jadad criteria, trials scored between 3 and 5 on a 5-point scale
Barr et al., 2006 (29) | Anticholinergic: tiotropium | 9 RCTs; 8002 patients | Cochrane Airways Group, hand searches of 20 respiratory journals and conference abstracts, requests for unpublished trials from tiotropium manufacturer and RCT authors, and search of reference lists for included trials and reviews; no language restriction.
| | Meta-analysis | RCTs comparing tiotropium with placebo, ipratropium, or long-acting β_2_-agonist in patients with stable COPD, for at least 3-mo duration
| | Quality: Concealment of allocation was described in 1 study
| | By the Jadad criteria, trials scored between 3 and 5 on a 5-point scale
Kesten et al., 2006 (28) | Anticholinergic: tiotropium | 19 RCTs; 7819 patients (mean age, 64 y) | No published trials met inclusion criteria: Completed trials of 18-g/d tiotropium, placebo-controlled, parallel-group
| | Pooled analysis | RCTs on tiotropium use in obstructive lung disease in the HandiHaler (Boehringer-Ingelheim, Germany) project database as of May 2004
Alsaeedi et al., 2002 (31) | Corticosteroid | 9 RCTs; 3976 patients | EMBASE, MEDLINE, CINAHL, SIGLE, Cochrane Central Register of Controlled Trials, reference lists of identified trials, and request for unpublished trials from content experts; restricted to human subjects, no language restrictions
| | Quality: By the Jadad criteria, 6 trials scored between 3 and 5 on a 5-point scale | RCTs of inhaled corticosteroids for at least 6 mo in stable COPD
Halpern et al., 2004 (33) | Corticosteroid | 14 studies; prospective cohort and randomized trials | EMBASE, MEDLINE, reference lists from product literature, and unpublished studies from pharmaceutical companies that produce the drug; language restricted to English, French, Spanish, Italian, German, Russian or Polish
| | Meta-analysis, random effects | Studies using 1 or more inhaled corticosteroid, providing inclusion/exclusion criteria for participants, presented adult data separately from pediatric patients or adults only, 12-mo minimum duration, defined treatment protocol, presented primary results, included 1 or more desired outcomes measures
| | Quality: Unpublished study not rated
| | Others rated according to the Oxford Centre for Evidence-based Medicine Levels of Evidence (May 2001): 4 studies rated 1b (individual RCT [with narrow CI]) and 9 studies rated 2b (individual cohort study [including low-quality RCT]; e.g., <80% follow-up)
Sin et al., 2005 (16) | Corticosteroid | 7 RCTs; 5085 patients | The Inhaled Steroid Effects Evaluation in COPD study: randomized trials on effects of inhaled corticosteroid vs. placebo for at least 12 mo in patients with stable COPD.
| | Pooled analysis, based on intention-to-treat analysis
Gartlehner et al., 2006 (32) | Corticosteroid | 13 RCTs, 11 observational studies | EMBASE, MEDLINE, Cochrane Library, International Pharmaceutical Abstracts, reference lists of identified studies and request for unpublished studies from content experts; restricted to human studies, English language, and 1970–2005
| | Meta-analysis; fixed effects | RCTs, 6-mo minimum duration and outpatient sample, for efficacy of corticosteroids in obstructive airway disease; observational studies, 12-mo minimum duration with >100 patients, were added for safety assessment
| | Quality: Most studies given a rating of “fair”, according to the USPSTF criteria

Study | Outcomes of Interest | Results | Sponsor
Part 2
Sestini et al., 2002 (25) | Symptoms, QOL, lung function, patient preference, adverse effects, study withdrawals, mortality, exercise capacity, sick-days | No adverse events reliably noted; may be because of insufficient data, small sample size, or short duration of studies. | None noted
| | No data reported on hospital admissions or mortality.
| | FEV_1_ and FVC are significantly higher with use compared with placebo.
| | Postbronchodilator morning and evening PEFR are significantly increased with use compared with placebo.
| | Patients preferred β_2_-agonists 10 times more than placebo.
| | Sparse trials and nonuniform methods of measurement gave variable results for symptoms, QOL, and exercise capacity.
Ferguson et al., 2003 (26) | Incidence of CV adverse events† | No significant difference of incidence for CV adverse events (RR, 1.03 [95% CI, 0.8–1.3]; P = 0.796), or time to first CV adverse event (P = 0.944) between salmeterol, 50 μg bid, and placebo among patients with COPD. Significant interaction with age: increasing incidence of CV adverse events with age (P = 0.027). | GSK Research & Development
Salpeter et al., 2004 (24) | Short-term effects on heart rate and potassium | Short-term use (single dose) increased heart rate by 9.12 beats/min (CI, 5.32–12.92 beats/min) and reduced potassium concentration by 0.36 mmol/L (CI, 0.18–0.54 mmol/L) compared with placebo. | None noted
| Long-term CV adverse events‡ | Long-term use significantly increased CV adverse event risk (RR, 2.54 [CI, 1.59–4.09]; P < 0.001) compared with placebo and significantly increased sinus tachycardia (RR, 3.06 [CI, 1.7–5.5]). All other CV events showed no statistical difference (RR, 1.66 [CI, 0.76–3.6]).
Salpeter, 2004 (23) | CV adverse events† | Case-control: Use associated with increased CV adverse effects, degree of risk may be dose-dependent. Two studies demonstrated increased risk for MI: One found it higher among new users and those with concomitant cardiac conditions, the other found significantly higher risk for hospitalization with unstable angina or MI with inhaled β_2_-agonist use over 3 mo. A third study found no significant association with short-acting β_2_-agonist use and risk for MI. Three studies found increased risk for heart failure or cardiomyopathy. Finally, 2 studies showed higher risks for cardiac arrest and acute cardiac death with nebulized and oral treatment vs. MDI. | None noted
| | RCT: β_2_-Agonist use increases CV adverse effects >2-fold when compared with placebo (see details in previous row: Salpeter et al., 2004 [24])
Salpeter et al., 2006 (27) | Safety and efficacy; RR for exacerbations leading to study withdrawal, hospitalization, or respiratory death | Anticholinergics, compared with placebo, decreased study withdrawals (RR, 0.60 [CI, 0.48–0.75]), hospitalizations (RR, 0.67 [CI, 0.53–0.86]), and respiratory deaths (RR, 0.27 [CI, 0.09–0.81]); NNT = 25. | None noted
| | β_2_-Agonists, compared with placebo, decreased withdrawal (RR, 0.81 [CI, 0.68–0.95]), had no significant effect on hospitalization (RR, 1.08 [CI, 0.61–1.95]), but significantly increased respiratory deaths (RR, 2.47 [CI, 1.12–5.45]); NNH = 131. (Note: 57% of participants had concomitant inhaled corticosteroid use.)
| | β_2_-Agonist, compared with anticholinergics, increased withdrawals (RR, 2.02 [CI, 1.39–2.93]) and hospitalizations (RR, 1.95 [CI, 1.06–3.59]). There was a nonsignificant upward trend toward respiratory deaths associated with β_2_-agonist compared with anticholinergics (RR, 6.91 [CI, 0.85–55.97]; P = 0.07).
Barr et al., 2005 (30) | Exacerbations, hospitalization, all-cause mortality, symptom scales, pulmonary function, anticholinergic adverse events§ | Tiotropium reduced exacerbations (OR, 0.74; P = 0.85; NNT = 14) and hospitalizations (OR, 0.64; P = 0.83; NNT = 30) compared with placebo or ipratropium. | NIH grant
| | No significant difference in all-cause mortality when tiotropium was compared with placebo, ipratropium, or salmeterol.
| | Significant increase in dry mouth when compared with placebo (OR, 5.4 [CI, 3.3–8.8]), ipratropium (OR, 2.1 [CI, 1.05–4.2]), or salmeterol (OR, 5.1 [CI, 2.2–12]).
| | Tiotropium improved QOL and symptom scores and may slow decline of FEV_1_.
Barr et al., 2006 (29) | Exacerbations, hospitalizations, all-cause mortality, symptom scales, pulmonary function, anticholinergic adverse events§ | Tiotropium significantly decreases COPD exacerbation (OR, 0.73 [CI, 0.66–0.81]; NNT = 13) and hospitalizations (OR, 0.68 [CI, 0.54–0.84]; NNT = 38), compared with placebo and ipratropium. No significance differences in CV (OR, 1.17 [CI, 0.54–2.51], pulmonary (OR, 0.50 [CI, 0.19–1.29]), and all-cause mortality (OR, 0.38 [CI, 0.09–1.66]) for the same comparison. No significant differences in exacerbation (OR, 0.86 [CI, 0.67–1.11]) and hospitalization (OR, 0.54 [CI, 0.29–1.01]) when tiotropium is compared with salmeterol. Tiotropium improved QOL and symptom scores and may slow decline of FEV_1_. | NIH grants
| | Dry mouth is significantly increased with use compared with placebo (OR, 4.6 [CI, 3.0–7.1]), ipratropium (OR, 2.1 [CI, 1.05–4.2]), and salmeterol (OR, 4.7 [CI, 2.4–9.2]); summary estimate OR, 3.9 (CI, 2.8–5.5). Urinary tract infections are significantly increased with use compared to placebo (OR, 1.6 [CI, 0.97–2.6]) and ipratropium (OR, 1.8 [CI, 0.97–2.6]); summary estimate OR, 1.6 (CI, 1.03–2.6). Urinary retention and constipation were consistently found, but were not statistically significant. The significant heterogeneity of arrhythmia and AF events could not provide a reliable summary estimate.
Kesten et al., 2006 (28) | Incidence rates and RR for all adverse events | There are significantly increased risks for dry mouth (RR, 3.60 [CI, 2.56–5.05]) and urinary retention (RR, 10.93 [CI, 1.26–94.88]) with tiotropium use compared with placebo, while risks are significantly decreased for dyspnea (RR, 0.64 [CI, 0.50–0.81]), COPD exacerbation (RR, 0.72 [CI, 0.64–0.82]), and pneumonia (RR, 0.64 [CI, 0.42–0.98]). No significant difference in incidence of CV mortality (RR, 0.57 [CI, 0.26–1.26]), cardiac arrest (RR, 0.90 [CI, 0.26–3.15]), or MI (RR, 0.74 [CI, 0.26–2.07]). Increased risk for any tachycardia (RR, 1.68 [CI, 0.69–4.1]). Risk for dysrhythmias, other than VT, VF, and AF, were increased (RR, 2.71 [CI, 1.10–6.65]) with tiotropium use compared with placebo, although no excess of dysrhythmias was classified as serious. No significance differences in respiratory mortality (RR, 0.71 [CI, 0.29–1.74]), CV mortality (RR, 0.57 [CI, 0.26–1.26]), and all-cause mortality (RR, 0.76 [CI, 0.50–1.16]) when tiotropium use was compared with placebo. | Boehringer-Ingelheim Pharmaceutical
Alsaeedi et al., 2002 (31) | Long-term effects of inhaled corticosteroid on COPD; RRs for rate of decline in FEV_1_, exacerbation, and all-cause mortality | Pulmonary function tests results varied among the trials. Inhaled corticosteroid use reduced exacerbations (RR, 0.70 [CI, 0.58–0.84]) compared with placebo. There was no significant difference in all-cause mortality (RR, 0.84 [CI, 0.60–1.18]) associated with use compared with placebo. | None noted
| | Adverse events include significantly increased risk for oropharyngeal candidiasis (RR, 2.1 [CI, 1.5–3.1]) and skin bruising (RR, 2.1 [CI, 1.6–2.8]) for inhaled corticosteroid use compared with placebo. There were variable effects on BMD. Trials were short, leading to inadequate follow-up time and evidence on BMD, fractures, cataracts, and adrenal insufficiency.
Halpern et al., 2004 (33) | BMD | Long-term use of inhaled corticosteroid is not significantly associated with changes in BMD of the lumbar spine (mean, -0.23% [CI, -1.84% to 1.38%]), femoral neck (mean, -0.17% [CI, -1.88% to 1.54%]), or trochanter major (mean, 1.46% [CI, -3.26% to 6.19%]). Neither are there significant differences in lumbar BMD among asthmatics (mean, 0.13% [CI, -2.60% to 2.86%]) and patients with COPD (mean, -0.42% [CI, -2.41% to 1.58%]). No significant differences where found for lumbar BMD among patients treated with fluticasone propionate (mean, -0.20% [CI, -2.74% to 2.33%]), beclomethasone dipropionate (mean, -0.73% [CI, -3.01% to 1.54%]), and budesonide (mean, -0.39% [CI, -3.46% to 2.69%]). | None noted
Sin et al., 2005 (16) | Effect on all-cause mortality | Inhaled corticosteroid use reduces risk for mortality significantly when compared with placebo (adjusted HR, 0.73 [CI, 0.55–0.96]). Patients with GOLD stages III and IV disease showed a significantly reduced mortality with inhaled corticosteroids (HR, 0.66 [CI, 0.45–0.96]). Subgroup analysis found women (adjusted HR, 0.46 [CI, 0.24–0.91]), former smokers (adjusted HR, 0.60 [CI, 0.39–0.93]), and those who had baseline postbronchodilator FEV_1_ <60% (adjusted HR, 0.67 [CI, 0.48–0.94]) with increase beneficial effect, although not statistically significant. | None noted
Gartlehner et al., 2006 (32) | Overall mortality, exacerbations, QOL, functional capacity, and symptoms | No significant difference in all-cause mortality (RR, 0.81 [CI, 0.60–1.08]) associated with inhaled corticosteroid use compared with placebo. Risk for exacerbation was significantly reduced (RR, 0.67 [CI, 0.59–0.77]). NNT for 17.7 months in patients with moderate or severe COPD is 12. Heterogeneous results are seen for QOL, functional capacity, and symptoms. | None noted
| | Adverse events: The short duration and small sample sizes of RCTs limited validity of adverse events analysis. Observational studies showed mixed results for inhaled corticosteroids' effects on BMD, however, 2 case studies showed an increased risk for fractures. A COPD subgroup analysis of a case-control study found increased risk for cataracts with longer duration of use (adjusted OR, 1.03 [CI, 0.94–1.13]). The risk for open-angle glaucoma increased in a case-control study and a cross-sectional study, with associated dose-related increase.

* AF = atrial fibrillation; bid = twice daily; BMD = bone mineral density; CCLS = Copenhagen City Lung Study; COPD = chronic obstructive pulmonary disease; CV = cardiovascular; EUROSCOP = European Respiratory Society Study on Chronic Obstructive Pulmonary Disease; FDA = U.S. Food and Drug Administration; GOLD = Global Initiative for Chronic Obstructive Lung Disease; GSK = GlaxoSmithKline; HR = hazard ratio; ISOLDE = Inhaled Steroids in Obstructive Lung Disease in Europe; LHS-2 = Lung Health Study 2; MDI = metered dose inhaler; MI = myocardial infarction; NIH = National Institutes of Health; NNH = number needed to harm; NNT = number needed to treat; OR = odds ratio; PEFR = peak expiratory flow rate; QOL = quality of life; RCT = randomized, controlled trial; RR = relative risk; TRISTAN = Trial of Inhaled Steroids and Long Acting β2 Agonists; USPSTF = U.S. Preventive Services Task Force; VF = ventricular fibrillation; VT = ventricular tachycardia.

† CV adverse events may include hypertension, angina pectoris, palpitations, tachyarrhythmias, tachycardia, syncope, cardiac failure, MI, coronary artery disorders, and thrombosis.

‡ CV adverse events may include sinus tachycardia and VT, syncope, AF, congestive heart failure, MI, cardiac arrest, or sudden death.

§ Palpitations, dry mouth, blurred vision, urinary obstruction, and constipation.

Appendix Table 3. Adverse Effects of Pharmacologic Treatments for Chronic Obstructive Pulmonary Disease

COPD Drug Class | Adverse Effect: Detail
Part 1
β_2_-Agonists
Short-acting inhaled (albuterol or salbutamol, isoproterenol, terbutaline) | None: No adverse events reliably noted—may be because of insufficient data, small size, or short duration of RCTs (25).
| A case-control study found no significant association with short-acting β_2_-agonist use and risk for MI (24).
Long-acting inhaled (salmeterol, formoterol) | Increased heart rate: Short-term use (single dose) increased heart rate by 9 beats/min (95% CI, 5.32–12.92 beats/min) compared with placebo (24).
| Reduced potassium: Short-term use reduced potassium concentration by 0.36 mmol/L (CI, 0.18–0.54 mmol/L) compared with placebo (24).
| CV events†: Long-term use increased CV adverse event risk (RR, 2.54 [CI, 1.59–4.09]) compared with placebo and increased sinus tachycardia (RR, 3.06 [CI, 1.7–5.5]). All other CV events showed no statistical difference (RR, 1.66 [CI, 0.76–3.6]) (24).
| No significant difference in incidence for CV adverse events (RR, 1.03 [CI, 0.8–1.3]; P = 0.796), or time to first CV adverse event (P = 0.944) between salmeterol and placebo in patients with COPD. Incidence of CV adverse events increased with age (P = 0.027) (26).
| In case-control studies, inhaled β_2_-agonist use is associated with increased CV adverse effects. Two studies demonstrated increased risk for MI: One found it higher among new users and those with concomitant cardiac conditions, the other found significantly higher risk for hospitalization with unstable angina or MI with inhaled β_2_-agonist use over 3 months. Three additional case-control studies found increased risk for heart failure or cardiomyopathy (23).
Anticholinergics
Inhaled (tiotropium, ipratropium) | Dry mouth: Significant increase in dry mouth when tiotropium was compared with placebo (OR, 5.4 [CI, 3.3–8.8]), ipratropium (OR, 2.1 [CI, 1.05–4.2]), or salmeterol (OR, 5.1 [CI, 2.2–12]) (30).
| Dry mouth is increased with tiotropium use compared with placebo (OR, 4.6 [CI, 3.0–7.1]), ipratropium (OR, 2.1 [CI, 1.05–4.2]), and salmeterol (OR, 4.7 [CI, 2.4–9.2]); summary estimate OR, 3.9 (CI, 2.8–5.5) (29).
| There are significantly increased risks for dry mouth (RR, 3.60 [CI, 2.56–5.05]) with tiotropium use compared with placebo (28).
| Urinary retention and constipation: Increased risk for urinary retention (RR, 10.93 [CI, 1.26–94.88]) with tiotropium compared with placebo (28).
| Urinary retention (OR, 2.6 [CI, 0.6–12]) and constipation (OR, 1.7 [CI, 0.8–3.7]) consistently found, but not statistically significant (29).
| Urinary tract infections are significantly increased with tiotropium use compared with placebo (OR, 1.6 [CI, 0.97–2.6]) and ipratropium (OR, 1.8 [CI, 0.97–2.6]); summary estimate OR, 1.6 (CI, 1.03–2.6) (29).
| CV events: No reliable summary estimate of arrhythmias because of significant heterogeneity of data (29).
| No significant difference in incidence of cardiac arrest (RR, 0.90 [CI, 0.26–3.15]) or MI (RR, 0.74 [CI, 0.26–2.07]). Increased risk for any tachycardia (RR, 1.68 [CI, 0.69–4.1]). Risk for dysrhythmias, other than VT, VF, and AF, were increased (RR, 2.71 [CI, 1.10–6.65]) with tiotropium use compared with placebo, although no excess of dysrhythmias was classified as serious (28).
Corticosteroids
Inhaled (flunisolide, triamcinolone acetate, budesonide, fluticasone propionate, beclomethasone dipropionate) | Oropharyngeal candidiasis: Significantly increased risk for oropharyngeal candidiasis (RR, 2.1 [CI, 1.5–3.1]), compared with placebo (31).
| Skin bruising: Significantly increased risk for skin bruising (RR, 2.1 [CI, 1.6–2.8]), compared with placebo (31).
| BMD: Long-term use of inhaled corticosteroids is not significantly associated with changes in BMD of the lumbar spine (mean, -0.23% [CI, -1.84% to 1.38%]), femoral neck (mean, -0.17% [CI, -1.88% to 1.54%]), or trochanter major (mean, 1.46% [CI, -3.26% to 6.19%]). No significant differences where found for lumbar BMD among patients treated with fluticasone propionate, beclomethasone dipropionate, and budesonide (33).
| Observational studies showed mixed results for inhaled corticosteroids' effects on BMD (32).
| Fractures: Case-control studies showed an increased risk for fractures (32).
| Open-angle glaucoma: Risk for open-angle glaucoma increased in 1 case-control study and 1 cross-sectional study, with associated dose-related increase (32).
| Cataracts: A COPD subgroup analysis of a case-control study found an increased risk for cataracts with longer duration of use (adjusted OR, 1.03 [CI, 0.94–1.13]) (32).

COPD Drug Class | Mortality Effect
Part 2
β_2_-Agonists
Short-acting inhaled (albuterol or salbutamol, isoproterenol, terbutaline) | No data.
Long-acting inhaled (salmeterol, formoterol) | β_2_-Agonists, compared with placebo, had significantly increased respiratory deaths (RR, 2.47 [CI, 1.12–5.45]); NNH = 131 (27).
| β_2_-Agonists, compared with anticholinergics, had a nonsignificant upward trend toward respiratory deaths (RR, 6.91 [CI, 0.85–55.97]; P = 0.07) (27).
| Two case-control studies showed higher risks for cardiac arrest and acute cardiac death with nebulized and oral treatment vs. metered-dose inhaler (23).
Anticholinergics
Inhaled (tiotropium, ipratropium) | Anticholinergics, compared with placebo, decreased respiratory deaths (RR, 0.27 [CI, 0.09–0.81]); NNT = 25 (27).
| No significant difference in all-cause mortality when tiotropium was compared with placebo, ipratropium, or salmeterol (30).
| No significance differences in CV, pulmonary, and all-cause mortality when tiotropium was compared with placebo and ipratropium (28, 29).
Corticosteroids
Inhaled (flunisolide, triamcinolone acetate, budesonide, fluticasone propionate, beclomethasone dipropionate) | No significant difference in all-cause mortality associated with use compared with placebo (31, 32).
| Significantly reduced risk for death compared with placebo (adjusted HR, 0.73 [CI, 0.55–0.96]), especially in patients in GOLD stages III and IV disease (HR, 0.66 [CI, 0.45–0.96]) (16).

* AF = atrial fibrillation; BMD = bone mineral density; COPD = chronic obstructive pulmonary disease; CV = cardiovascular; GOLD = Global Initiative for Chronic Obstructive Lung Disease; HR = hazard ratio; MI = myocardial infarction; NNH = number needed to harm; NNT = number needed to treat; OR = odds ratio; RCT = randomized, controlled trial; RR = relative risk; VF = ventricular fibrillation; VT = ventricular tachycardia.

† Hypertension, angina pectoris, palpitations, AF, tachyarrhythmia, sinus tachycardia and VT, syncope, cardiac failure, MI, coronary artery disorders, thrombosis, cardiac arrest, or sudden death.