# References

(1) Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, Atkins D. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3):21-35. [pmid: 11306229].
(2) WHO ASSIST Working Group. The Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): development, reliability and feasibility. Addiction. 2002;97:1183-1194. [pmid: 12199834].
(3) Newcombe DL, Humeniuk RE, Ali R. Validation of the World Health Organization Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): report of results from the Australian site. Drug Alcohol Review. 2005;24:217-226. [pmid: 16096125].
(4) Brown RL, Rounds LA. Conjoint screening questionnaires for alcohol and other drug abuse: criterion validity in a primary care practice. Wis Med J. 1995;94:135-140. [pmid: 7778330].
(5) Hinkin CH, Castellon SA, Dickson-Fuhrman E, Daum G, Jaffe J, Jarvik L. Screening for drug and alcohol abuse among older adults using a modified version of the CAGE. Am J Addict. 2001;10:319-326. [pmid: 11783746].
(6) Leonardson GR, Ness FK, Daniels MC, Kemper E, Koplin BA, Leonardson GA. Validity and reliability of the AUDIT and CAGE-AID in Northern Plains American Indians. Psychological Reports. 2005;97:161-166. [pmid: 16279320].
(7) Knight JR, Shrier LA, Bravender TD, Farrell M, Bilt JV, Shaffer HJ. A new brief screen for adolescent substance abuse. Arch Pediatr Adolesc Med. 1999;153:591-596. [pmid: 10357299].
(8) Knight JR, Sherritt L, Shrier LA, Harris SK, Chang G. Validity of the CRAFFT substance abuse screening test among adolescent clinic patients. Arch Pediatr Adolesc Med. 2002;156:607-614. [pmid: 12038895].
(9) Cummins LH, Chan KK, Burns KM, Blume AW, Larimer M, Marlatt GA. Validity of the CRAFFT in American-Indian and Alaska-Native adolescents: screening for drug and alcohol risk. J Stud Alcohol. 2003;64:727-732. [pmid: 14572196].
(10) Levy S, Sherritt L, Harris SK, Gates EC, Holder DW, Kulig JW, Knight JR. Test-retest reliability of adolescents' self-report of substance use. Alcohol Clin Exp Res. 2004;28:1236-1241. [pmid: 15318123].
(11) Skinner HA. The Drug Abuse Screening Test. Addictive Behaviors. 1982;7:363-371. [pmid: 7183189].
(12) Staley D, El-Guebaly N. Psychometric properties of the Drug Abuse Screening Test in a psychiatric patient population. Addictive Behaviors. 1990;15:257-264. [pmid: 2378285].
(13) El-Bassel N, Schilling RF, Schinke S, Orlandi M, Sun W. Assessing the utility of the Drug Abuse Screening Test in the workplace. Research on Social Work Practice. 1997;7:99-114.
(14) McCann BS, Simpson TL, Ries R, Roy-Byrne P. Reliability and validity of screening instruments for drug and alcohol abuse in adults seeking evaluation for attention-deficit hyperactivity disorder. Am J Addict. 2000;9:1-9. [pmid: 10914288].
(15) Bastiaens L, Francis G, Lewis K. The RAFFT as a screening tool for adolescent substance use disorders. Am J Addict. 2000;9:10-16. [pmid: 10914289].
(16) Bastiaens L, Riccardi K, Sakhrani D. The RAFFT as a screening tool for adult substance use disorders. Am J Drug Alc Abuse. 2002;28:681-691.
(17) Knight JF, Goodman E, Pulerwitz T, DuRant R. Reliabilities of short substance abuse screening tests among adolescent medical patients. Pediatrics. 2000;105:948-953. [pmid: 10742352].