# Conclusion

There is fair evidence that standardized questionnaires considered short enough to be potentially useful in the practice setting have acceptable accuracy and reliability in screening for drug use/misuse. One instrument (the CRAFFT) has been adequately validated for screening adolescents for drug use/misuse. Three instruments of various lengths (ASSIST, CAGE-AID, and DAST-20) have been validated for screening adults. The evidence is not sufficient, however, to establish the positive predictive value of these tests when used in a general medical patient population with a predictably lower prevalence of drug use/misuse. The available evidence does not permit one to determine the overall clinical utility of these instruments when applied in a busy primary care practice setting, and especially in screening pregnant women for drug use.