# Discussion

While a fair amount of work has been completed since 1996 on the development and assessment of standardized instruments for screening for drug use and misuse, several studies were considered to be of only fair quality, due to small patient sample size or the failure to include within the sample patients from a general clinic or practice population. A few studies focusing on the accuracy (sensitivity and specificity) of an instrument were considered of only fair quality since they used some other validated instrument (e.g., POSIT) as their reference standard rather than a structured diagnostic interview.

This review was limited to questionnaires considered brief enough to be potentially useful for screening for drug use/misuse in the primary care setting. Toward this end, we set an arbitrary upper limit of 20 items and/or 5 minutes for administration/scoring of the instrument. When assessed, the Drug Abuse Screening Test (DAST), the longest of the instruments considered in this review, was shown to be an accurate and reliable test. The sensitivity and/or specificity of instruments consisting of six or fewer items were lower, though still acceptable. Further testing is needed to determine the optimal tradeoff between questionnaire length and accuracy/reliability of the instrument.

It has yet to be shown how well some of these instruments perform in screening large populations of patients in general medical clinics or practices, where a lower prevalence of drug misuse problems can be expected. For the CAGE-AID, CRAFFT, DAST and RAFFT, more than one published study provided calculations of the instrument's predictive value. Negative predictive values of greater than 90% were noted consistently for each instrument except the RAFFT, which had a NPV of 51–87%. However, more than two-fold variations in positive predictive value were noted between studies of the CAGE-AID, CRAFFT and DAST. Studies reporting the lower PPVs (<30%) were typically conducted among more general, non-selected patient populations in which a lower prevalence of drug problems can be expected. The positive and negative predictive values of ASSIST were not reported in published studies assessing this test.

The greatest gap in the evidence noticed in this review was the lack of studies that shed light on the feasibility and usefulness of applying screening instruments within a busy practice. Debriefing interviews conducted at the end of the initial testing of ASSIST (1) measured clarity, ease of use, and potential response bias, but the clinical utility of this or other instruments in an actual practice setting has yet to be assessed. In addition to data on rates of offering and completing the screens, qualitative data are needed on the acceptability of the additional burden placed on patients, clinicians, and staff when the test is used routinely in practice.