# Results

After our exclusion criteria were applied to all instruments described in the SASAI database, we were left with nine instruments potentially useful for screening for drug misuse in primary care practice settings:

- Alcohol, Smoking and Substance Involvement Screening Test (ASSIST);
- Cut down, Annoyed, Guilty, Eye-opener - Adapted to Include Drugs (CAGE-AID);
- Car, Relax, Alone, Forget, Friends, Trouble (CRAFFT);
- Drug Abuse Screening Test (DAST);
- Drug Use Disorders Identification Test (DUDIT);
- Relax, Alone, Forget, Friends, Trouble (RAFFT);
- Reduce, Annoyed, Guilty, Start (RAGS);
- Rapid Drug Problems Screen (RDPS),
- Simple Screening Instrument for Substance Abuse (SSI-SA).

The abstracts of a total of 340 articles, identified from literature searches conducted for each of the nine instruments, were reviewed for relevance using the screening criteria noted above. Of these, 37 citations were selected for review of full-text articles. Most of the excluded abstracts were not studies of the specified screening instrument (e.g., the instrument shared its acronym with some other entity). After full-text articles were reviewed, 16 studies were ultimately included that addressed the validity, reliability or clinical utility of the screening instrument. Of these, 2 evaluated ASSIST, 3 evaluated CAGE-AID, 4 evaluated CRAFFT, 4 evaluated DAST, 2 evaluated RAFFT, and 1 evaluated SSI-SA. No studies reporting on assessments of DUDIT, RAGS or RDPS met our criteria for inclusion.

Table 1 provides descriptive information about the length, focus, and method of administering the six screening instruments for which published evaluative studies were identified. The instruments ranged in length from the 4-item CAGE-AID to the 28-item DAST. The DAST was retained for further review based on evidence that a shorter (20-item) version of the instrument has comparable psychometric properties.

Table 1 Questionnaire Instruments Evaluated for Drug Misuse Screening

Instrument | #items/Time required | Target population | Measures recent or lifetime use? | Administered by patient or clinician?
ASSIST | 8 items | Adults | Recent and lifetime | Clinician
CAGE-AID | 4 items | Adults | Lifetime | Clinician
CRAFFT | 6 items | Adolescents | Lifetime | Patient
DAST | 28/20 items/* 5 minutes | Adults | Lifetime | Patient
RAFFT | 5 items | Adults or adolescents | Lifetime | Patient
SSI-SA | 16 items | Adults or Adolescents | Lifetime | Clinician or patient

* The 20-item version of DAST was found to have psychometric properties comparable with the original 28-item version.

The results of 16 studies of the accuracy and reliability of the six instruments are presented in Table 2. The sensitivities, specificities, and positive and negative predictive values reported are those noted using the cutoff score for a positive screen recommended by the developers of the instrument. A range of sensitivities and specificities has been noted if no specific score for a positive screen was established for the instrument.

Table 2 Results of Studies Assessing Questionnaires for Drug Misuse Screening

Instrument/Author (Reference #) | Study Population | Sample Size | Reference Standard | Sensitivity | Specificity | Positive Predictive Value | Negative Predictive Value | Internal Consistency (alpha) | Test-Retest (kappa)
ASSIST | 60% in drug Rx | 236 | | | | | | 0.85–0.91 | 0.58–0.90
WHO (1) | 40% from gen'l med facility
ASSIST | Primary care, Drug treatment | 150 | Other instrument | 90% | 78% | Not reported | Not Reported
Newcombe (2)
CAGE-AID | Academic Community FP | 124 | Diagnostic Interview | 79% | 77% | 78% | 78%
Brown (3)
CAGE-AID | Elderly abusers & non-abusers | 976 | Clinical Interview | 81–92% | 48–72% | 12–18% | 98–99%
Hinkin (4)
CAGE-AID | Am Indians at Diabetic clinic | 50 | | | | | | 0.92
Leonardson (5)
CRAFFT | Adolescents with known drug use | 99 | Personal Experience Inventory | 92% | 82% | Not reported | Not Reported | 0.79
Knight (6)
CRAFFT | Adolescent Clinic | 538 | Structured Diagnostic interview | 76% | 94% | 83% | 91% | 0.68
Knight (7)
CRAFFT | Am-Indian adolescents in clinics/schools | 70 | Structured Interview (CASI-A) | 86% | 76% | 29% | 98% | 0.81
Cummins (8)
CRAFFT | Adolescent clinic | 93 | | | | | | | 0.71–0.86
Levy (9)
DAST | Drug/alcohol Abuse clients | 256 | | | | | | 0.92
Skinner (10)
DAST | Psychiatric Patients | 250 | Diagnostic Interview | 82–96% | 81–91% | 63–75% | 94–98% | 0.92
Staley (11)
DAST | Adult workers | 176 | | | | | | 0.92 | 0.70
El-Bassel (12)
DAST | Adults evaluated for ADHD | 143 | Diagnostic Interview | 85% | 71% | 23% | 98% | 0.92
McCann (13)
RAFFT | Adolescents in ER with psych problem | 226 | Diagnostic Interview | 89% | 69% | 73% | 87%
Bastiaens (14)
RAFFT | Adults seen in psych ER | 215 | Neuropsych Interview | 84% | 67% | 91% | 51%
Bastiaens (15)
SSI-SA | Adolescent Clinic | 173 | | | | | | 0.83 | 0.9
Knight (16)

There was fair evidence of accuracy and good evidence of reliability of ASSIST; good evidence of accuracy and fair evidence of reliability of CAGE-AID; good evidence of both the accuracy and reliability of CRAFFT; and fair evidence of both the accuracy and reliability of DAST. No published studies were identified assessing the accuracy of the SSI-SA or the reliability of the RAFFT.

No published study reported on the feasibility or usefulness of any of the instruments when applied in the primary care clinical setting. There was also no evidence on the clinical utility of any instrument in screening pregnant women for drug use or misuse.